# Background

Percutaneous coronary interventions (PCI) with or without stents and coronary artery bypass graft surgery (CABG) are the two broad categories of interventions for mechanical revascularization of atherosclerotic coronary arteries in patients with coronary artery disease (CAD). The choice of revascularization procedure is often determined by coronary anatomy and the technical feasibility of either PCI or CABG. Therefore the clinical dilemma pertains to patients in whom both procedures are technically feasible and whose coronary disease is neither too limited nor too extensive. Generally, both approaches would be clinically relevant for patients with single-vessel disease of the proximal left anterior descending artery, most types of two-vessel disease, as well as patients with three-vessel disease that is not particularly extensive. Because PCI and CABG differ in their procedural risk and their initial and downstream costs, assessing their comparative effectiveness and safety is of great interest.

PCI and CABG have already been compared in several randomized controlled trials (RCTs)1–7 and analyses of large clinical registries.8–11 The aim of this report is to identify needs for future research in the comparison between PCI and CABG. We use as a basis the 2007 comparative effectiveness report (CER) by the Stanford–University of California at San Francisco Evidence-based Practice Center (Stanford–UCSF EPC) that assessed PCI vs. CABG for coronary artery disease (for brevity, we hereafter refer to the report as “Stanford CER”).12 The report summarized evidence published through 2006 to address the following key questions:

- Key Question 1a: In patients with ischemic heart disease and angiographically proven single- or multiple-vessel disease, what is the comparative effectiveness of PCI compared to CABG in reducing the occurrence of adverse objective outcomes^a^ and improving subjective outcomes?^b^
  a Long-term and short-term objective outcomes referred to outcomes that impacted patients’ health, including, but not limited to, periprocedural death or complications, non-fatal myocardial infarctions, congestive heart failure, stroke, nosocomial infections, respiratory failure or other pulmonary complications, acute or chronic renal failure, cardiac arrhythmias, and long-term survival and event-free survival (major adverse cardiac events).
  b Subjective outcomes referred to outcomes that impacted patients’ perceived quality of life, functional health status, or general health status. Subjective outcomes included freedom from angina and quality of life.
- Key Question 1b: Over what period are the comparative benefits of PCI and CABG sustained?
- Key Question 2: Is there evidence that the comparative effectiveness of PCI and CABG varies based on (predefined) patient and procedure related factors?^c^
  c Demographic factors (age, sex, race, or other demographic risk factors), comorbidities (coronary disease risk factors, diabetes, obesity or other comorbid disease), angiographic factors (extent of disease single and multi-vessel disease), left ventricular function, PCI/CABG-specific factors (bare metal stents, balloon angioplasty, and drug-eluting stents, use of minimally invasive techniques, use of internal mammary arteries), clinical presentation (stable angina or unstable angina, based on NYHA functional class I–IV).

## Findings of the Stanford CER

This is a distillation of the findings of the Stanford CER on Key Questions 1a and b:

1. Procedural (short-term) outcomes:
  a. Procedural survival was high for both interventions and was not significantly different between PCI and CABG.
  b. Freedom from procedural strokes significantly favored PCI compared with CABG.
  c. Freedom from procedural myocardial infarction was heterogeneously defined and was not significantly different between the two treatments.
2. Long-term objective outcomes:
  a. Long-term survival was significantly better for CABG compared to PCI in the older trials (pre 1994, where PCI procedures mostly were balloon angioplasties). However, long term survival was not significantly different between CABG and PCI in more recent trials (stent era).
  b. Similarly, long term freedom from myocardial infarction was not statistically significant between the compared treatments.
3. Long-term subjective outcomes
  a. Freedom from angina was greater for CABG rather than PCI interventions.
  b. Quality of life outcomes favored CABG over PCI between 6 months and 3 years of follow-up but equalized thereafter. The degree of improvement in quality of life was correlated with relief of angina.

Regarding Key Question 2, the Stanford CER evaluated the evidence for comparative effectiveness of PCI and CABG based on (predefined) patient-, provider-, disease- and intervention-related factors. However, the report noted that in contrast to the fairly robust evidence concerning overall clinical outcomes, there was much less evidence from randomized trials to gauge whether and how comparative effectiveness varied across these factors. Most clinical trials reported only on survival and did not report outcomes in key patient subgroups.

## Currency of the Stanford Report

The Stanford CER summarized evidence up to 2006 and includes most large RCTs that are available at this point. Therefore it is, as of this writing, a relevant report. However, some developments that were outside the scope of the original CER or occurred after the report was completed, need to be considered.

First, medical treatment was outside the scope of the Stanford CER. Therefore, the CER is applicable only to patients in whom revascularization is warranted. However, no revascularization (optimal medical therapy) is now considered a valid clinical option in patients with stable CAD, particularly after the publication of the COURAGE RCT.13 COURAGE (n=2287) did not find significant differences in mortality, myocardial infarction and other outcomes between PCI (mainly with bare metal stents, BMS) and optimal medical therapy (including aggressive cholesterol lowering therapy, beta blockers, angiotensin converting enzyme inhibitors, and antiplatelets when applicable). A subsequent network meta-analysis of COURAGE and several other RCTs did not find significant differences between medical therapy and PCI with BMS, or medical therapy and PCI with drug-eluting stents (DES).14 This makes it difficult to clearly specify the pool of CAD patients to whom the Stanford CER pertains, as there is randomized evidence that a large number of them can be treated without revascularization.

Further, additional evidence has been published since the completion of the Stanford CER, and this could affect the conclusions of the report on the comparative effectiveness and safety of PCI vs. CABG, as well as its recommendations for future research:

- Several RCTs that had been included in the Stanford CER have presented long term outcome data based on longer periods of followup.
- Several new RCTs have published results after the completion of the Stanford CER. Among them the SYNTAX trial,15 a large RCT comparing DES with CABG in patients with three-vessel or complex left main CAD, added a considerable amount of evidence for this comparison. In addition, the CARDia trial,16 a randomized trial in diabetic patients with multivessel CAD or complex single vessel disease informs the comparison of PCI with stents (68% DES) with CABG in this subgroup.
- Several ongoing RCTs are expected to report results in the next 2 or 3 years.

## Research Gaps Identified in the Stanford CER

Table 1 summarizes research gaps and proposals for future studies identified by the Stanford CER. The Stanford CER did not describe a specific methodology for identifying the research gaps, for suggesting what the future research needs are or how they should be addressed. We have mapped the research gaps to the key questions in the CER’s analytic framework.

Table 1 Research gaps and proposals for future research from the Stanford CER

Research gap | Suggestions for future research | Corresponding Key Question
Lack of analyses of PCI and CABG outcomes according to patient characteristics. Specifically:; - Sex; - Age; - Chronic kidney disease; - Left ventricular dysfunction | Collaborative pooling of individual patient-level data from randomized trials to (a) enhance statistical power and (b) reduce publication bias A more extensive collaborative study to pool individual patient data from both balloon-era and stent-era trials to increase the number of patients and outcome events improving statistical power even further in patient subpopulations. More direct assessments of the impact of stents on the comparative effectiveness of PCI and CABG and assessment of whether relative efficacy changes over extended followup. | KQ 1, KQ 2a and 2b
Paucity of data on the comparative effectiveness and safety of DES in particular, and especially in the long term. | Further clinical trials with extended followup and large enough to detect clinically meaningful differences in outcome to assess whether the availability of DES has affected the comparative efficacy of PCI and CABG Because the procedural risk of CABG in large registries has declined progressively over time, several trials comparing contemporary CABG with PCI using DES were anticipated (including the FREEDOM (NCT00086540) and SYNTAX trials (NCT 00114972)] | KQ 1, KQ 2d
Paucity of data on the relationship between procedural volume and outcomes of minimally invasive approaches to CABG. | Further research on the association of procedure volume with outcome to examine additional outcome measures, both short term (e.g., nonfatal myocardial infarction, completeness of revascularization) and long term (e.g., survival, angina relief, freedom from repeat procedures), preferably in large patient cohorts using contemporaneous CABG and PCI and applying the same analytic methods. | KQ 2d, KQ 2g
Paucity of data on metrics for quality of care for PCI and CABG procedures. | Development of evidence-based process measures for PCI and CABG to facilitate efforts to improve quality of care and provide better performance measures than procedure volume.

CABG, coronary artery bypass graft surgery; DES, drug eluting stents; PCI, percutaneous coronary intervention.

The analytic framework in Figure 1 illustrates the key questions of the Stanford CER, and maps the evidence gaps that were identified.^d^

d This analytic framework is not included in the Stanford CER. It was constructed by Tufts EPC to facilitate the description of the evidence gaps that were identified in the Stanford CER. These evidence gaps guided the future research recommendations section of the report.

Figure 1 Reconstructed analytic framework showing the evidence gaps identified by the Stanford CER

Figure 1 is an analytic framework depicting the key questions within the context of the population, interventions, comparators of interest, outcomes, timing, and settings (PICOTS). The patient population of interest is adult patients with stable ischemic heart disease (IHD) or IHD risk equivalents and preserved left ventricular (LV) function. Patient or population factors that may impact the effectiveness of angiotensin-converting enzyme (ACE) inhibitors and angiotensin II receptor blocker(s)/antagonist(s) (ARBs) include demographic factors (race/ethnicity, sex, age), comorbidities, and concurrent use of other medications. In general, the figure illustrates how the addition of ACE inhibitors, ARBs, or ACE inhibitor/ARB combination therapy to standard medical therapy for the specified patient population affects outcomes such as mortality (all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific) or morbidity (especially cardiovascular events [myocardial infarction (MI), stroke, heart failure, atrial fibrillation, revascularization], cerebral vascular disease or events, renal insufficiency, symptom reporting, hospitalization, and measures of quality of life) in comparison to treatment with standard medical therapy alone. In addition, adverse events (including impaired renal function, syncope, cough, hyperkalemia, diarrhea, hypotensive symptoms, and angioedema) may occur at any point after standard medical therapy alone or standard medical therapy plus ACE inhibitors, ARBs, or ACE inhibitor/ARB combination therapy are received.