# Appendixes

Appendix A Search Strategies

Appendix B Search Prioritization Tools

Appendix C Excluded Studies

Appendix D Methods and Results of Quantitative Analyses