# Excluded Studies

Appendix Table C1 List of excluded studies and reasons for exclusion

First author | Year of publication | Title | Journal | PMID | Reason for exclusion
Bypass Angioplasty Revascularization Investigation 2 Diabetes Study Group | 2008 | Baseline characteristics of patients with diabetes and coronary artery disease enrolled in the Bypass Angioplasty Revascularization Investigation 2 Diabetes (BARI 2D) trial | Am Heart J | 18760137 | No follow-up information
M. Y. Chan | 2008 | Prevalence, predictors, and impact of conservative medical management for patients with non-ST-segment elevation acute coronary syndromes who have angiographically documented significant coronary disease | JACC Cardiovasc Interv | 19463332 | Not relevant interventions
E. L. Eisenstein | 2009 | Long-term clinical and economic analysis of the Endeavor zotarolimus- eluting stent vs. the cypher sirolimus-eluting stent: 3-year results from the ENDEAVOR III trial (Randomized Controlled Trial of the Medtronic Endeavor Drug [ABT-578] Eluting Coronary Stent System Versus the Cypher Sirolimus-Eluting Coronary Stent System in De Novo Native Coronary Artery Lesions). | JACC Cardiovasc Interv | 20129546 | Not relevant interventions
M. E. Farkouh | 2008 | Design of the Future REvascularization Evaluation in patients with Diabetes mellitus: Optimal management of Multivessel disease (FREEDOM) Trial | Am Heart J | 18215589 | Trial protocol
Y. Y. Liu | 2009 | [Comparison between drug eluting stent and coronary artery bypass grafting surgery for the treatment of unprotected left main coronary artery disease in elderly patients] | Zhonghua Xin Xue Guan Bing Za Zhi | 20128370 | Not English
J. L. Martin | 2009 | Frequency of coronary artery bypass grafting following implantation of a paclitaxel-eluting or a bare-metal stent into a single coronary artery | Am J Cardiol | 19101222 | Not relevant interventions
A. C. Pereira | 2006 | Clinical judgment and treatment options in stable multivessel coronary artery disease: results from the one-year follow-up of the MASS II (Medicine, Angioplasty, or Surgery Study II). | J Am Coll Cardiol | 16949484 | Results from analyses comparing randomization arms not presented.
D. Poldermans | 2007 | A clinical randomized trial to evaluate the safety of a noninvasive approach in high-risk patients undergoing major vascular surgery: the DECREASE-V Pilot Study | J Am Coll Cardiol | 17466225 | Not relevant interventions and population
L. Schwartz | 2009 | Baseline coronary angiographic findings in the Bypass Angioplasty Revascularization Investigation 2 Diabetes trial (BARI 2D) | Am J Cardiol | 19231325 | No follow-up information
K. T. Stroupe | 2006 | Cost-effectiveness of coronary artery bypass grafts vs. percutaneous coronary intervention for revascularization of high-risk patients | Circulation | 16966588 | Cost-effectiveness analysis based on RCT
P. J. Vlaar | 2008 | Cardiac death and reinfarction after 1 year in the Thrombus Aspiration during percutaneous coronary intervention in Pcute myocardial infarction Study (TAPAS): a 1-year follow-up study | Lancet | 18539223 | Not relevant population
H. B. Ward | 2006 | Coronary artery bypass grafting is superior to percutaneous coronary intervention in prevention of perioperative myocardial infarctions during subsequent vascular surgery. | Ann Thorac Surg | 16928485 | CABG – PCI comparison was not randomized
R. C. Welsh | 2010 | Prior coronary artery bypass graft patients with ST-segment elevation myocardial infarction treated with primary percutaneous coronary intervention | JACC Cardiovasc Interv | 20298996 | Not relevant population
S. Vaina | 2009 | Effect of gender differences on early and mid-term clinical outcome after percutaneous or surgical coronary revascularisation in patients with multivessel coronary artery disease: insights from ARTS I and ARTS II | Euro-Intervention | 19284072 | Comparison of outcomes between the arms of a randomized trial (ARTS I) and an observational study (ARTS II)

CABG=coronary artery bypass graft surgery; PCI=percutaneous coronary intervention; PMID=PubMed identification number.