# Search Prioritization Tools

## Appendix B Step 1: Initial List of Evidence Gaps (List 1)

List 1 is the initial list of evidence gaps. It was generated based on the Stanford CER and input from key informants.

List 1 Initial list of evidence gaps

Population | Intervention/PCI | Comparator/CABG | Outcomes | Perspective; time horizon | Other
CAD in whom revascularization is considered.; - 1-vessel (proximal LAD); - Most 2-vessel CAD; - Less severe 3-vessel; Modifiers/Subgroups; - Age, sex (women), race (Asian); - Diabetes; - High BMI; - Heart failure; - Chronic kidney disease; - Angiographic factors, such as number of vessels; disease location (LM, LAD, RCA, CCA); type of lesions (long lesions, small diameter vessels, altered anatomy); - Presentation (silent ischemia, stable angina, unstable angina, ACS, MI, cardiogenic shock); - Comedications, adjunctive medical therapies? | Stents; - DES; - BMS; - Bioabsorbable; Angioplasty; - Laser; - Balloon; Other; - Atherectomy | Traditional (sternotomy); - On pump; - Off pump; Minimally invasive; - On pump; - Off pump; - Hybrid PCI/CABG; Graft type; - Saphenous vein; - Internal mammary artery; Cardioplegia; - Yes; - No (beating heart); Other with transmyocardial revascularization (TMR) | Short-term objective; - Completeness of revascularization; - Peri-procedural death; - Non-fatal MI; - Stroke; - Unplanned/urgent CABG during same PCI hospitalization; - Nosocomial infections; - Respiratory failure/Pulmonary complications; - Renal failure; - Other procedural complications; - Post procedure discharge to rehabilitation facilities; - Readmission rates; - Costs; Intermediate and long term objective; - Long-term overall survival; - Long-term cardiovascular survival; - Non fatal MI; - Event free survival (define events, e.g. MI free or repeat-revascularization-free); - Repeat revascularization procedures; - Target lesion revascularization; - PCI restenosis; - CABG graft closure; - Congestive heart failure; - Cardiac arrhythmias; - Use of anti-angina medications; Short and long term subjective; - QOL; - Freedom from angina; - Cognitive impairment; - Productivity and functional capacity | - Societal; - Researcher; - Payor; - Funder; - Patient; - 1–2 y; - 5 y; - 10 y | - Patient preferences; - Development and evaluation of decision aids for shared decision- making

ACS=acute coronary syndrome; BMI=Body mass index; BMS=bare metal stents; CABG=coronary artery bypass grafting; CCA=circumflex coronary artery DES=drug-eluting stents; LM=Left main; LAD=left anterior descending artery; MI=myocardial infarction PCI=percutaneous interventions; QOL=quality of life; RCA=right coronary artery

## Appendix B Step 2: Search Results and Interim Expanded List of Evidence Gaps

We then proceeded to further refine the list of evidence gaps. To inform additional discussions with the key informants, we searched for relevant recently published or ongoing studies that were not included in the Stanford CER.

### Searches

Appendix Figure B1 shows the flow of the literature. From a total of 101 citations retrieved by our searches we identified 32 potentially relevant studies that appeared after the completion of the Stanford CER and we reviewed them in full text. After full text screening, 18 studies were consider eligible and 14 were excluded (Appendix C lists the excluded studies and reasons for exclusion). Eleven publications were updated reports of RCTs included in the Stanford CER.1–11 Eight publications12–19 reported on 5 RCTs that were not included in the Stanford CER. Appendix Table B1 summarizes their findings. Appendix Table B2 shows ongoing RCTs identified in ClinicalTrials.gov.

Appendix Figure B1 Search flow

Reasons for exclusion are presented in Appendix C. RCTs, randomized controlled trials.

Appendix Table B1 Studies published since 2006

Author, year | Study short name (if available) | Sample size^a^ PCI/Surgery | Comparison | Population | Main findings
Updates of studies included in the Stanford CER report
Holper, 2007^7^ | BARI^b^ | 1816/1317 | Balloon vs. CABG | Patients with multivessel coronary artery disease with severe angina or objective evidence of ischemia requiring revascularization; CAD involving 2 or 3 vessels. | Patients with heart failure had increased mortality ten years after initial revascularization. In diabetic patients with heart failure and preserved LVEF there was a significant in cardiac mortality compared to patients without heart failure.
Holmes, 2007^6^ | BARI^c^ | 1371/2239 | Balloon vs. CABG | Patients with multivessel coronary artery disease with severe angina or objective evidence of ischemia requiring revascularization; CAD involving 2 or 3 vessels. | CABG was associated with significantly lower risk of sudden cardiac death but was not significantly associated with any other causes of long-term mortality at 7.7 years of follow-up.
BARI investigators, 2007^1^ | BARI^d^ | 915/914 | Balloon vs. CABG | Patients with multivessel coronary artery disease with severe angina or objective evidence of ischemia requiring revascularization; CAD involving 2 or 3 vessels. | PCI and CABG did not differ significantly regarding survival or angina rates at 10 years of follow-up. The PCI group had a substantially higher rate of revascularization. In a subgroup analysis by diabetes status, the CABG group had higher survival than the PCI group. Survival rates were identical among non diabetic subjects.
Martuscelli, 2008^10^ | CABRI | 120/103 | Balloon vs. CABG | Patients with LAD, circumflex or right coronary artery chronic occlusion (subgroup of the CABRI trial) | Death or Q-wave MI was significantly lower in the CABG group at a median follow-up of 30 months.
Lopes, 2008^9,e^ | MASS-I and MASS-II | 277/277 | BMS (>80%) vs. CABG | Single or multivessel CAD (>70% stenosis) | CABG was significantly associated with lower rates of a composite endpoint of death, myocardial infarction or refractory angina compared to PCI at 5 years of follow-up.
Hueb, 2007^8^ | MASS-II | 205/2003 | PCI (BMS, lasers, atherectomy, or balloon) vs. CABG | Angiographically documented proximal multivessel coronary stenosis (>70% stenosis) and documented ischemia | CABG was statistically significantly associated with lower rates of the composite endpoint of death, Q- wave MI or refractory angina requiring revascularization (primary endpoint). The difference in morality was nonsignificant at 5 years of follow up.
Favarato, 2007^4^ | MASS-II | 180/175 | PCI (BMS, lasers, atherectomy, or balloon) vs. CABG | Angiographically documented proximal multivessel coronary stenosis (>70% stenosis) and documented ischemia | Both therapeutic strategies presented significant improvement in all dimensions of the SF-36 hrQoL questionnaire during follow-up. The CABG group had significantly greater improvement in physical and social functioning, vitality and general health when compared to medical treatment and PCI.^f^
Goy, 2008^5^ | SIMA | 62/59 | BMS vs. CABG | Isolated proximal LAD stenosis and LVEF>45% | The incidence of death and MI were the same in the two groups at 10 years of follow-up. Patients in the PCI group had a significantly higher rate of the composite outcome of death, myocardial infarction or additional revascularization.
Booth, 2008^2^ | SoS | 488/500 | BMS vs. CABG | Symptomatic multivessel CAD and at least one lesion suitable for stent implantation. | Patients in the CABG group had significantly improved survival at a median follow-up of 6 years. There was no significant interaction of the treatment effect with baseline angina grade, severity of coronary artery disease or diabetic status.
Buszman, 2009^3^ | SoS | 50/50^g^ | BMS vs. CABG | Symptomatic multivessel CAD and at least one lesion suitable for stent implantation. | No significant difference was observed between the two groups at 10 years of follow-up. There was a significantly higher rate of repeat revascularizations and the composite outcome of death, MI, stroke or repeat revascularization in the PCI arm.
New studies (not included in the Stanford CER report)
BARI 2D Study Group, 2009^15^ | BARI 2D | 1605/763^h^ | Prompt coronary revascularization vs. medical therapy, randomization was stratified according to the method of revascularization (PCI vs. CABG) f | Patients with type 2 diabetes and CAD (≥50% stenosis of a major epicardial coronary artery associated with a positive stress test or ≥70% stenosis of a major epicardial coronary artery and classic angina) | In the PCI stratum there was no difference in the composite outcome of death, myocardial infarction or stroke between the revascularization and the medical therapy groups. In the CABG stratum, the rate of the composite outcome was significantly lower in the revascularization group than in the medical therapy group. This interaction between stratum and study group was statistically significant.
Chaitman14 | BARI 2D | 1605/763^j^ | Prompt coronary revascularization vs. medical therapy, randomization was stratified according to the method of revascularization (PCI vs. CABG) | Patients with type 2 diabetes and CAD (≥50% stenosis of a major epicardial coronary artery associated with a positive stress test or ≥70% stenosis of a major epicardial coronary artery and classic angina) | In the CABG stratum, MI events and the composite outcomes of death or MI and cardiac death or MI were significantly less frequent in the revascularization plus intensive medical therapy group compared to the group that received intensive medical therapy alone at an average of 5.3 years of follow-up.
Kapur, 2010^16^ | CARDia | 256/254 | BMS (32%) or DES (68%) vs. CABG | Patients with diabetes and either multivessel CAD or complex single vessel disease^k^ | There was no statistically significant difference in mortality or a composite outcome of death, non-fatal MI, or non-fatal stroke at one year (primary outcome). There was a significant difference in favor of CABG in the composite outcome of death, non-fatal MI, non-fatal stroke, and repeat revascularization (secondary outcome). All comparisons were done at 1 year of follow-up.
Buszman, 2008^13^ | LE MANS | 52/53 | BMS (65%) or DES (35%) vs. CABG | Unprotected left main CAD (>50% stenosis) | Patients in the PCI group had a significantly higher improvement in LVEF compared to patients in the CABG group at 1 year of follow-up (primary outcome). Patients in both groups performed equally well on stress tests and had similar improvements in angina status. At 1 year of followup, the rates of mortality and the composite outcome of cardiac death, MI, stroke, repeat intervention or in-stent thrombosis were comparable between the two arms. The difference in overall survival was non-significant at an average follow-up of 28 months.
Thiele, 2009^19^ | NA | 65/65 | DES vs. MIDCAB | Isolated proximal LAD stenosis (>50% stenosis) | DES was non-inferior to MIDCAB at 12-month follow-up with respect to the composite outcome of cardiovascular death, MI or the need for repeated target vessel revascularization.
Serruys, 2009^18^ | SYNTAX | 903/897 | DES vs. CABG | Three-vessel or complex left main CAD | CABG resulted in lower rates of the composite outcome of death from any cause, stroke, MI or repeat revascularization at 1 year compared to PCI.
Morice, 2010^17^ | SYNTAX | 357/348 | DES vs CABG | Left main CAD (subgroup analysis of Serruys, 2009^18^) | PCI and CABG had comparable outcomes in regards to the composite outcome of all-cause death, cerebrovascular accident/stroke, MI or repeat revascularizations at one year of follow-up.
Banning, 2010^12^ | SYNTAX | 903/897 | DES vs CABG | Three-vessel or complex left main CAD | Among diabetic patients, patients on the CABG group had lower rates of the composite outcome of death from any cause, stroke, MI or repeat revascularization compared to patients on the PCI group at 1 year of follow-up. The difference was not significant among non-diabetic patients. The repeat revascularization rate was higher on the PCI arm compared to the CABG arm, regardless of diabetes status.

BMS=bare metal stent; CABG=coronary artery bypass grafting surgery; CAD=coronary artery disease; DES=drug-eluting stent; EPC=Evidence-based Practice Center; hrQoL=health-related quality of life; LAD=left anterior descending; LVEF=left ventricular ejection fraction; MI=myocardial infarction; MIDCAB=minimally invasive direct coronary artery bypass; NA=not available; PCI=percutaneous coronary intervention. Studies are separated by whether they were updates of studies in included in the Stanford CER or presented their first results subsequent to the report. Studies are listed alphabetically; when multiple publications are available from the same study they are listed by year of publication and then by author name.

a Patients for whom outcomes were reported in each study (intention-to-treat populations when data were available). Many of the studies reported subgroup analyses of larger randomized trials.

b Included patients both from the randomized (patients randomized to PCI or CABG) and the observational component of the BARI study (patients eligible for randomization who refused to be randomized were entered into a registry and underwent the same baseline investigations).

c Included patients both from the randomized (patients randomized to PCI or CABG) and the observational component of the BARI study (patients eligible for randomization who refused to be randomized were entered into a registry and underwent the same baseline investigations).

d Final 10-year follow-up data from the BARI study randomized component.

e We did not extract data regarding patients assigned to medical therapy (no revascularization).

f The MASS-II trial had a three arm design, comparing PCI, CABG and medical therapy.

g Subgroup analysis of 100 patients enrolled in the SoS trial in centers in Poland. The original SoS trial included 988 patients and was conducted in 53 European and Canadian centers.

h Patients in the PCI / CABG randomization strata.

i The BARI 2D trial had a 2x2 factorial design: in the first strategy patients were randomized to undergo either prompt coronary revascularization or medical therapy; in the second strategy patients were assigned to either insulin-sensitization therapy or insulin provision therapy to achieve a target glycated hemoglobin of less than 7.0%. We only abstracted data regarding the revascularization strategies.

j Patients in the PCI/CABG randomization strata.

k Complex disease was defined as ostial or proximal left anterior descending coronary artery disease.

Appendix Table B2 Ongoing studies comparing PCI vs. CABG (from clinicaltrials.gov)

Study | NCT number | Size | Comparison | Population | Completion
FREEDOM | NCT00086450 | 2400 | PCI vs CABG | Diabetes (T1 or 2) | [soon]
Leipzig | NCT00176397 | 200 | DES vs CABG | Left main | [soon]
VACARDS | NCT00326196 | 790 | DES vs CABG | Diabetes (severe ischemic disease) | Terminated
REHEAT2 | NCT00388245 | 150 | PCI vs CABG | Ischemic cardiomyopathy; low left ventricular ejection fraction | [soon]
China | NCT01035034 | 400 | DES vs Hybrid | 2–3 vessel disease with left main involvement and denovo lesions of left anterior descending artery | 12/2012

DES=drug eluting stents; Hybrid=Hybrid PCI/MIDCAB intervention; MIDCAB=minimally invasive CABG.

The five RCTs published after the completion of the Stanford CER generally used DES in their PCI arms, either exclusively, or in combination with BMS. None included balloon angioplasty. Two of the 5 RCTs included well over 1,500 patients,15,18 one included approximately 500 patients16 and the remaining two less than 200.^3,19^ Two of the largest RCTs enrolled only diabetic patients: CARDia compared DES or BMS with CABG16 while BARI 2D15 randomized patients to either prompt revascularization with intensive medical therapy vs. intensive medical therapy alone but stratified randomization by the choice of revascularization method (PCI vs. CABG).

### Evidence Gaps After One-to-One Interviews with the Key Informants (List 2)

List 2 is presented as stem questions and options to complete the questions. In the comment columns, we list ongoing studies identified in ClinicalTrials.gov.

List 2 Interim expanded list of evidence gaps

Populations
Imagine that we can order a well designed and conducted study that provides a conclusive answer to the following question
Stem question | Subgroup | Comment
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of PCI vs. CABG in THIS SUBGROUP? | A. Diabetes | • Lancet MIPD; FREEDOM (n=2400); VACARDS (n=790)
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of PCI vs. CABG in THIS SUBGROUP? | B. Older adults (>71 or >75) | •
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of PCI vs. CABG in THIS SUBGROUP? | C. High body mass index | •
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of PCI vs. CABG in THIS SUBGROUP? | D. LV ejection fraction<35% or ischemic heart failure | • Lancet MIPD; REHEAT2 (n=150)
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of PCI vs. CABG in THIS SUBGROUP? | E. Renal disease (stage 3 or 4), prior to replacement therapy | •
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of PCI vs. CABG in THIS SUBGROUP? | F. [struck: Left Main disease] | • SYNTAX (n=1800); Leipzig_1 (n=200); China_2 (n=400)
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of PCI vs. CABG in THIS SUBGROUP? | G. Women | •
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of PCI vs. CABG in THIS SUBGROUP? | H. Race (Asian? Smaller body size?) | •
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of PCI vs. CABG in THIS SUBGROUP? | I. Prior CABG | •
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of PCI vs. CABG in THIS SUBGROUP? | J. Prior PCI | •
Crossed out font: suggested as a nonmajor gap in key informant interviews (CABG consistently better).

Interventions
Imagine that we can order a well designed and conducted study that provides a conclusive answer to the following question
Stem question | Treatment variant | Comment
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of THIS_PCI_VARIANT vs. THIS_CABG_VARIANT? | A. PCI: Bare metal stents | •
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of THIS_PCI_VARIANT vs. THIS_CABG_VARIANT? | B. PCI: Drug eluting stents | • SYNTAX (n=1800); Leipzig_1 (n=200); VACARDS (n=790) China_2 (n=400); Leipzig_2 (n=130);
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of THIS_PCI_VARIANT vs. THIS_CABG_VARIANT? | C. [struck: CABG: Minimally invasive surgery [MIDCAB]] | • Leipzig_2 (n=130);
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of THIS_PCI_VARIANT vs. THIS_CABG_VARIANT? | D. [struck: CABG: Hybrid minimally invasive surgery with PCI] | • China_2 (n=400); • For Hybrid vs CABG: China_1 (n=400); POL-MIDES (n=200)
For patients with coronary artery disease who may be eligible for both PCI or CABG: What is the comparative effectiveness or safety of THIS_PCI_VARIANT vs. THIS_CABG_VARIANT? | E. Medical treatment | • [If the topic were broader, an important set of questions has to do with Medical vs invasive treatment… ]
Crossed out font: suggested as a nonmajor gap in key informant interviews (not routinely used).

Testing To Inform Treatment Decisions
Imagine that we can order a well designed and conducted study that provides a conclusive answer to the following question
Stem question | Test to guide treatment choice | Comment
For patients with coronary artery disease who may be eligible for both PCI or CABG: Does THIS_TESTING have the ability to predict differential response to PCI or CABG? [struck: What is the impact of testing with THIS_TEST for guiding treatment choice (PCI vs. CABG) on patient-relevant outcomes?] | A. Stress test | • [STICH-DECIPHER uses dobutamine echocardiography but measured also several other tests but CABG vs medical therapy]
| B. SPECT | • WOMEN study
| C. MR angiography | •
| D. CT angiography | • [faCTor64 screening of asymptomatic people]; [struck: CTPRIME (terminated)]
| E. [struck: Calcification score] | •
| F. [struck: SYNTAX score] | •
Crossed out font: based on key informant input it was deemed that the second stem question (leftmost column) depends on the question above it, which should be addressed first. In the second column, key informants suggested dropping these tests; in the last column, the CTPRIME study was terminated.
[Comment: The question refers to testing to inform treatment choice. We are not asking the important question of testing to screen asymptomatic individuals for CAD, to choose between e.g., no treatment, medical treatment, or some kind of revascularization. The screening question is deemed to be too peripheral to our topic.]

Preferences of Patients or Referring Physicians, and Decision Aids
Imagine that we can order a well designed and conducted study that provides a conclusive answer to the following question
Question | Comment
A. For patients with coronary artery disease who may be eligible for both PCI or CABG: What are the preferences of the patients regarding treatment choice, and which factors influence them? | •
B. For (primary care) physicians whose patients have coronary artery disease and may be eligible for both PCI or CABG: What are the preferences of the referring physician regarding treatment choice, and which factors influence them? | •
C. For patients with coronary artery disease who may be eligible for both PCI or CABG, and their referring physicians: Develop a decision support tool to help physicians and patients in their shared decisionmaking regarding treatment choice. | •

Study of Inequalities and Performance Measures
Imagine that we can order a well designed and conducted study that provides a conclusive answer to the following question
Question | Comment
A. How can we develop suitable performance measures for institutions and for individual physicians (CABG surgeons or PCI interventionists) | •
B. For patients with coronary artery disease who may be eligible for both PCI or CABG: What are the major factors that contribute to inequalities in accessing health care? | •

## Appendix B Step 3: Final List of Evidence Gaps After Internal Prioritization (List 3)

See the “Background information provided to key informants” in the next section for a justification of our selection of the items in the final list of evidence gaps (List 3).

List 3 Pruned (final) list of important evidence gaps

Thematic area | List of evidence gaps
Thematic area 1: Comparative effectiveness of PCI vs. CABG | Populations:; - Age >75 years; - Prior PCI; - Diabetes; - Women; - Congestive heart failure; - Stage 3 or 4 of chronic kidney disease; Interventions:; - PCI: Bare metal stents; - PCI: Drug eluting stents; - CABG: On pump traditional CABG with arterial grafts; Outcomes:; - 30-day outcomes -objective:; - Periprocedural death; - Nonfatal MI; - Nonfatal stroke; - Unplanned urgent revascularization with CABG during the PCI; - Renal failure requiring renal replacement therapy; - Post procedural discharge to rehabilitation facilities; - Health care costs; - Readmission rates for cardiac reasons such as heart failure and unstable angina; - Others like nosocomial infections are most relevant to CABG, and pulmonary complications affect the length of stay; - Intermediate outcomes (objective) at 1 year. The relative ranking would be similar to the applicable 30 day outcomes.; - Longer term outcomes (objective) would be 5 years. The relative ranking would be similar to the applicable 30 day outcomes.; - Subjective outcomes:; - QoL is very important and can be measured by generic or disease-specific instruments
Thematic area 2: Testing to inform choice of revascularization procedure | The evidence gap pertains to whether testing before revascularization can guide the choice of revascularization procedure, e.g., by predicting clinical response in the long term. Examples of invasive and non-invasive tests:; - Invasive coronary arteriography; - Non-invasive CT angiography or MR angiography; - Resting or exercise SPECT; - Exercise treadmill test with or without echocardiography
Thematic area 3: Enhancing patient participation | - Eliciting and measuring patient preferences; - Facilitating shared decisionmaking between patients and their physicians by developing and then evaluating decision support tools.
Thematic area 4: Assessing performance | - Based on prior key informant input, there are no validated process-based performance measures that could quantify optimal care

BMS=bare metal stents; CABG=coronary artery bypass grafting; CTA=computerized tomography-based angiography; DES=drug eluting stents; MI=myocardial infarction; MRA=magnetic resonance angiography; PCI=percutaneous coronary intervention; QoL=quality of life; SPECT=single photon emission computerized tomography

## Appendix B Step 4: Background Information Provided to Key Informants

### Relative Disease Burden of CAD Subpopulations

In the teleconference, and in one-to one calls with several of the key informants we identified a list of factors that define subpopulations of interest for the comparative effectiveness of PCI vs. CABG. Appendix Table B3 summarizes data on the prevalence of these factors from 4 analyses of large clinical registries of patients with coronary artery disease who received revascularization (identified from the Stanford CER20). These included patients treated in the 1990’s in North America or Europe, describe at least 1,000 patients treated with PCI and 1,000 treated with CABG, report patient characteristics and performed multivariate statistical analyses.

Appendix Table B3 Characteristics of patients who underwent PCI or CABG in selected large clinical registries

| Hannan et al. 2005^21^ | Malenka et al. 2005^23^ | Pell et al. 2001^24^ | Dzavik et al. 2001^25^
Description | No prior revascularization, no LM (>50%) | Multivessel disease, <80y, no prior revascularization, no LM (>50%) | Patients who received the interventions | CAD patients who were revascularized
Sample size | 59314 | 14493 | 9890 | 22690
Years | 1997–2000 | 1994–2001 | 1997–1999 | 1995–1998
Location | NY Registries, US | Northern New England, US | Scotland | Alberta, Canada
Percentages
Age >75 years | 41 | 33^a^ | 5 | <50
2^nd^ revascularization (1^st^ was PCI)^b^ | 35 | ND | 23 | 13
Diabetes | 30 | 32 | 12 | 26
Women | 30 | 28 | 28 | 22
Congestive heart failure | 16 | 14 | ND | 17
Non-European descent (non-white) | 12 | ND | ND | ND
Left ventricular ejection fraction <30% | 8 | 12 | 42 | ND
Renal disease^*^ | 3^c^ | [3]^d^ | ND | 3^e^
2^nd^ revascularization (1^st^ was CABG)^f^ | 5 | ND | 2 | 13
Body mass index >30 kg/m^2^ | ND | ND | 27 | ND
Left main disease (e.g. >50% stenosis) | NE | NE | ND | ND

ND=no data; NE=not estimable

* Unfortunately, the percentage of patients who had chronic kidney disease stage 3 or 4 was not explicitly mentioned (what is shown corresponds to creatinine >2 or >2.5 mg/dL, or roughly, stages 4 or 5). Stage 3 is more prevalent—and therefore we believe that “renal disease stages 3 or 4” will be among the 6 most prevalent factors in Hannan et al.

a >70years but note that there is an upper cutoff of 80 years of age; however in other registries >80y is a small percentage (<5%).

b Calculated as proportion revascularized (during the followup) among those who received PCI.

c Renal failure (dialysis or creatinine >2.5 mg/dL).

d Renal failure or creatinine >2 mg/dL.

e Creatinine >200 mmol, approximately >200/88= 2.3 mg/dL but not on dialysis.

f Calculated as proportion revascularized (during the followup) among those who received CABG.

Broadly, percentages in Appendix Table B3 fall into similar ranges for most factors. Obviously there are differences that can be ascribed to difference in settings, time period—type of PCI or CABG, eligibility criteria for the analyses, or health policy differences across countries. The rows of the Table are ordered by decreasing percentages in Hannan et al.21 Hannan et al. is the largest of the four, and is based on two comprehensive registries from the state of New York. The percentages in this study are a crude index of the relative “disease burden” in CAD subpopulations defined by the pertinent factors. The five top factors are old age (>75 years), prior PCI revascularization, diabetes, female sex, and congestive heart failure.

Especially for renal disease, the registries report only percentage with creatinine >2 or >2.5 mg/dL. In all likelihood this corresponds to stage 4 or stage 5 (renal replacement therapy). Stage 3 will be quite more frequent, and therefore we include renal disease (stage 3 or 4) as a top 6th subpopulation.

### Data on Treatment Effect Modification in CAD Subpopulations

The meta-analysis of individual patient data by Hlatky 2009^22^ found that age (3 categories using cutoffs at 55 and 65 years) and diabetes modify the effects of treatment on survival (p=0.002 and 0.014, respectively). The magnitude of the treatment effect modification was clinically important. They found no significant effect modification for sex (p=0.25), heart failure (p=0.46), or abnormal LV function (p=0.87). Racial descent, previous PCI or CABG, body mass index, renal function and left main disease were not examined.

### Ongoing Trials of PCI vs. CABG in CAD Subpopulations

There are two ongoing trials (FREEDOM, n=2400 and VACARDS, n=790) that enrolled diabetics and their results will likely be presented within the next 2–3 years. Other ongoing trials are listed in Table B2.

### Criteria to Prioritize Research Questions

Appendix Table B4 lists the criteria that we use to rate the future research needs for PCI vs. CABG. Briefly, we use 6 criteria:

Table B4 Criteria to qualitatively rank future research needs

Criterion short name | Description | Comment
Disease burden | The research question pertains to/corresponds to/addresses an important disease burden, or a high-priority population? | - High prevalence of a condition suggests a high disease burden; - An important subpopulation can be relatively rare
Impact on practice | Answering the research question has the potential to change practice | - Physicians are likely to adopt the intervention in practice
Impact on patient health Impact on patient satisfaction | Answering the research question has the potential to improve patients’ health Answering the research question has the potential to improve patients’ satisfaction | - If the study finds an effective intervention, can it affect patient health directly?; - e.g., testing affects health indirectly e.g., through treatment choices; - Relates to patient’s preferences
Address health inequalities | Answering the research question has the potential to reduce health inequalities without adverse impact on specific subpopulations | - Variation in practice; - Variation in access; - Variation in measured performance (for institutions)
Address ethical, legal or social issues | Answering the research question has the potential to allow assessment of ethical, legal or social issues (ELSI) pertaining to the disease | - Malpractice; - Minorities; - Other ethical concerns
Costs | Answering the research question will have nontrivial impact on costs/economic considerations | - High unit cost; - High volume; - High opportunity costs

We will rate each research need in each criterion as:

1=I strongly disagree; 2=I disagree; 3=I am indifferent; 4=I agree; 5=I strongly agree.

Disease burden; impact on practice; impact on patient health; impact on patient satisfaction; address health inequalities; address ethical, legal or social issues (ELSI); costs

## Appendix B Step 4: Questionnaire to Key Informants

## Appendix B References

1 The final 10-year follow-up results from the BARI randomized trial. J Am Coll Cardiol. Apr. 17. 2007;49(15):1600-1606. [pmid: 17433949].
2 Booth J, Clayton T, Pepper J, et al. Randomized, controlled trial of coronary artery bypass surgery versus percutaneous coronary intervention in patients with multivessel coronary artery disease: six-year follow-up from the Stent or Surgery Trial (SoS). Circulation. Jul. 22. 2008;118(4):381-388. [pmid: 18606919].
3 Buszman P, Wiernek S, Szymanski R, et al. Percutaneous versus surgical revascularization for multivessel coronary artery disease: a single center 10 year follow-up of SOS trial patients. Catheter Cardiovasc Interv. Sept. 1. 2009;74(3):420-426. [pmid: 19360866].
4 Favarato ME, Hueb W, Boden WE, et al. Quality of life in patients with symptomatic multivessel coronary artery disease: a comparative post hoc analyses of medical, angioplasty or surgical strategies-MASS II trial. Int J Cardiol. Apr. 4. 2007;116(3):364-370. [pmid: 16876891].
5 Goy JJ, Kaufmann U, Hurni M, et al. 10-year follow-up of a prospective randomized trial comparing bare-metal stenting with internal mammary artery grafting for proximal, isolated de novo left anterior coronary artery stenosis the SIMA (Stenting versus Internal Mammary Artery grafting) trial. J Am Coll Cardiol. Sept. 2. 2008;52(10):815-817. [pmid: 18755343].
6 Holmes DR Jr, Kim LJ, Brooks MM, et al. The effect of coronary artery bypass grafting on specific causes of long-term mortality in the Bypass Angioplasty Revascularization Investigation. J Thorac Cardiovasc Surg. Jul. 2007;134(1):38-46. [pmid: 17599484].
7 Holper EM, Brooks MM, Kim LJ, et al. Effects of heart failure and diabetes mellitus on long-term mortality after coronary revascularization (from the BARI Trial). Am J Cardiol. Jul. 15. 2007;100(2):196-202. [pmid: 17631069].
8 Hueb W, Lopes NH, Gersh BJ, et al. Five-year follow-up of the Medicine, Angioplasty, or Surgery Study (MASS II): a randomized controlled clinical trial of 3 therapeutic strategies for multivessel coronary artery disease. Circulation. Mar. 6. 2007;115(9):1082-1089. [pmid: 17339566].
9 Lopes NH, Paulitsch FS, Gois AF, et al. Impact of number of vessels disease on outcome of patients with stable coronary artery disease: 5-year follow-up of the Medical, Angioplasty, and bypass Surgery study (MASS). Eur J Cardiothorac Surg. Mar. 2008;33(3):349-354. [pmid: 18249128].
10 Martuscelli E, Clementi F, Gallagher MM, et al. Revascularization strategy in patients with multivessel disease and a major vessel chronically occluded; data from the CABRI trial. Eur J Cardiothorac Surg. Jan. 2008;33(1):4-8. [pmid: 17988889].
11 Vaina S, Voudris V, Morice MC, et al. Effect of gender differences on early and mid-term clinical outcome after percutaneous or surgical coronary revascularisation in patients with multivessel coronary artery disease: insights from ARTS I and ARTS II. EuroIntervention. Jan. 2009;4(4):492-501. [pmid: 19284072].
12 Banning AP, Westaby S, Morice MC, et al. Diabetic and nondiabetic patients with left main and/or 3-vessel coronary artery disease: comparison of outcomes with cardiac surgery and paclitaxel-eluting stents. J Am Coll Cardiol. Mar. 16. 2010;55(11):1067-1075. [pmid: 20079596].
13 Buszman PE, Kiesz SR, Bochenek A, et al. Acute and late outcomes of unprotected left main stenting in comparison with surgical revascularization. J Am Coll Cardiol. Feb. 5. 2008;51(5):538-545. [pmid: 18237682].
14 Chaitman BR, Hardison RM, Adler D, et al. The Bypass Angioplasty Revascularization Investigation 2 Diabetes randomized trial of different treatment strategies in type 2 diabetes mellitus with stable ischemic heart disease: impact of treatment strategy on cardiac mortality and myocardial infarction. Circulation. Dec. 22. 2009;120(25):2529-2540. [pmid: 19920001].
15 Frye RL, August P, Brooks MM, et al. A randomized trial of therapies for type 2 diabetes and coronary artery disease. N Engl J Med. Jun. 11. 2009;360(24):2503-2515. [pmid: 19502645].
16 Kapur A, Hall RJ, Malik IS, et al. Randomized comparison of percutaneous coronary intervention with coronary artery bypass grafting in diabetic patients. 1-year results of the CARDia (Coronary Artery Revascularization in Diabetes) trial. J Am Coll Cardiol. Feb. 2. 2010;55(5):432-440. [pmid: 20117456].
17 Morice MC, Serruys PW, Kappetein AP, et al. Outcomes in patients with de novo left main disease treated with either percutaneous coronary intervention using paclitaxel-eluting stents or coronary artery bypass graft treatment in the Synergy Between Percutaneous Coronary Intervention with TAXUS and Cardiac Surgery (SYNTAX) trial. Circulation. Jun. 22. 2010;121(24):2645-2653. [pmid: 20530001].
18 Serruys PW, Morice MC, Kappetein AP, et al. Percutaneous coronary intervention versus coronary-artery bypass grafting for severe coronary artery disease. N Engl J Med. Mar. 5. 2009;360(10):961-972. [pmid: 19228612].
19 Thiele H, Neumann-Schniedewind P, Jacobs S, et al. Randomized comparison of minimally invasive direct coronary artery bypass surgery versus sirolimus-eluting stenting in isolated proximal left anterior descending coronary artery stenosis. J Am Coll Cardiol. Jun. 23. 2009;53(25):2324-2331. [pmid: 19539141].
20 Bravata D, McDonald K, Gienger A, et al. Comparative effectiveness of percutaneous coronary interventions and coronary artery bypass grafting for coronary artery disease, Comparative Effectiveness Review No 9 (prepared by Stanford UCSF-EPC). 2007.
21 Hannan EL, Racz MJ, Walford G, et al. Long-term outcomes of coronary-artery bypass grafting versus stent implantation. N Engl J Med. May. 26. 2005;352(21):2174-2183. [pmid: 15917382].
22 Hlatky MA, Boothroyd DB, Bravata DM, et al. Coronary artery bypass surgery compared with percutaneous coronary interventions for multivessel disease: a collaborative analysis of individual patient data from ten randomised trials. Lancet. Apr. 4. 2009;373(9670):1190-1197. [pmid: 19303634].
23 Malenka DJ, Leavitt BJ, Hearne MJ, et al. Comparing long-term survival of patients with multivessel coronary disease after CABG or PCI: analysis of BARI-like patients in northern New England. Circulation. Aug. 30. 2005;112(9 Suppl):I371-I376. [pmid: 16159849].
24 Pell JP, Walsh D, Norrie J, et al. Outcomes following coronary artery bypass grafting and percutaneous transluminal coronary angioplasty in the stent era: a prospective study of all 9890 consecutive patients operated on in Scotland over a two year period. Heart. Jun. 2001;85(6):662-666. [pmid: 11359748].
25 Dzavik V, Ghali WA, Norris C, et al. Long-term survival in 11,661 patients with multivessel coronary artery disease in the era of stenting: a report from the Alberta Provincial Project for Outcome Assessment in Coronary Heart Disease (APPROACH) Investigators. Am Heart J. Jul. 2001;142(1):119-126. [pmid: 11431667].