# Search Strategies

## PubMed

We searched PubMed for randomized controlled trial reports published after the completion of the Stanford CER (our search covered the period from 2006 to August 4, 2010).

We used the simple search strategy:

“coronary artery bypass[MH] AND (angioplasty[MH] OR stents[MH] OR percutaneous coronary intervention)” and set limits for “Randomized controlled trial” or “Controlled Clinical Trial” or “Clinical Trial, Phase III” or “Clinical Trial, Phase IV” as publication type. We only considered studies published in English.

## ClinicalTrials.gov

We searched the ClinicalTrials.gov database to identify ongoing studies comparing any PCI intervention with any type of CABG, including “hybrid” interventions that combine PCI and CABG.

We searched for “coronary artery bypass” and “percutaneous coronary intervention” and selecting the age groups “Adult” and “Adult Senior” and study type “Interventional studies” and separately for “Observational studies.”