# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BMS: Bare metal stent
CABG: Coronary artery bypass graft surgery
CAD: Coronary artery disease
CER: Comparative effectiveness report
CKD: Chronic Kidney Disease
CTA: Computerized tomography angiography
DES: Drug eluting stent
EPC: Evidence-based Practice Center
EVPI: Expected value of perfect information
EVPPI: Expected value of perfect information for parameters
HF: Heart failure
HR: Hazard ratio
hrQoL: Health related quality of life
ICER: Incremental cost-effectiveness ratio
LAD: Left anterior descending coronary artery
LVEF: Left ventricular ejection fraction
MH: Medical subject heading
MI: Myocardial infarction
MIDCAB: Minimally invasive direct coronary artery bypass surgery
MIPD: Meta-analysis of individual patient data
MRA: Magnetic resonance angiography
NA: Not applicable
NCT: Clinical trial registry number
NYHA: New York Heart Association
PCI: Percutaneous coronary intervention
QALY: Quality adjusted life year
RCT: Randomized controlled trial
RR: Relative risk
SCHIP: State Children’s Health Insurance Program
SF-36: Short Form-36 questionnaire
SPECT: Single photon emission computed tomography
UCSF: University of California at San Francisco
VOI: Value of information