# Vaccines

## COVID-19 Vaccines

The HHS Secretary declared that circumstances exist justifying the authorization of emergency use of drugs and biological products during the COVID-19 pandemic, pursuant to section 564 of the FD&C Act, effective March 27, 2020. The EUAs subsequently issued by FDA are listed in the table below.

Date of First EUA Issuance | Product | Authorized Use | Additional Information
07/13/2022 | Novavax COVID-19 Vaccine, Adjuvanted | For the prevention of Coronavirus Disease 2019 (COVID-19) for individuals 18 years of age and older | More information about the Novavax COVID-19 Vaccine (https://www.fda.gov/vaccines-blood-biologics/coronavirus-covid-19-cber-regulated-biologics/novavax-covid-19-vaccine-adjuvanted); Novavax COVID-19 Vaccine, Adjuvanted decision memos and regulatory documents (ZIP file)
12/18/2020 | Moderna COVID-19 Vaccine | For the prevention of 2019 coronavirus disease (COVID-19) in individuals 6 months and older; On January 31, 2022, FDA approved the Moderna COVID-19 Vaccine, now known as Spikevax (https://www.fda.gov/vaccines-blood-biologics/spikevax), for the prevention of COVID-19. | More information about the Moderna COVID-19 Vaccine (https://www.fda.gov/vaccines-blood-biologics/coronavirus-covid-19-cber-regulated-biologics/moderna-covid-19-vaccines); Moderna COVID-19 Vaccine decision memos and regulatory documents (ZIP file)
12/11/2020 | Pfizer-BioNTech COVID-19 Vaccine | For the prevention of 2019 coronavirus disease (COVID-19) in individuals 6 months and older; On August 23, 2021, FDA approved the Pfizer-BioNTech COVID-19 Vaccine, now known as Comirnaty (https://www.fda.gov/vaccines-blood-biologics/comirnaty), for the prevention of COVID-19. | More information about the Pfizer-BioNTech COVID-19 Vaccine (https://www.fda.gov/vaccines-blood-biologics/coronavirus-covid-19-cber-regulated-biologics/pfizer-biontech-covid-19-vaccines); Pfizer-BioNTech COVID-19 Vaccine decision memos and regulatory documents (ZIP file)

## Convalescent Plasma

Date of First EUA Issuance | Most Recent Letter of Authorization (PDF) | Authorized Use | Fact Sheets and Manufacturer Instructions/Package Insert (PDF) | Federal Register Notice for EUA
08/23/2020 | COVID-19 convalescent plasma (365KB) (Reissued February 23, 2021, March 9, 2021 and December 28, 2021); Letter Granting EUA Amendment (June 2, 2021) (107KB); Letter Granting EUA Amendment (February 9, 2022) (26KB) | COVID-19 convalescent plasma with high titers of anti-SARS-CoV-2 antibodies is authorized for the treatment of COVID-19 in patients with immunosuppressive disease or receiving immunosuppressive treatment, in inpatient or outpatient settings. | Healthcare Providers (Updated December 28, 2021) (192KB); Patients and Parents/ Caregivers (Updated December 28, 2021) (151KB); Decision Memorandum (166KB); Decision Memorandum (December 27, 2021) (242KB) | - Federal Register notice, February 19, 2021 (https://www.federalregister.gov/documents/2021/02/19/2021-03429/authorizations-of-emergency-use-of-certain-drug-and-biological-products-during-the-covid-19-pandemic)

## Novavax Decision Memorandum – July 13, 2022 - References

Boehmer TK, Kompaniyets L, Lavery AM, et al. (2020). -January 2021. MMWR Morb Mortal Wkly Rep. 2021;70(35):1228-1232. Published.
Centers for Disease Control and Prevention (CDC), 2022a, COVID Data Tracker Trends in Number of COVID-19 Cases and Deaths in the US Reported to CDC, by State/Territory, https://covid.cdc.gov/covid-data-tracker/#trends dailytrendscases. Accessed May 13, 2022. CDC, 2022b, COVID Data Tracker Variant Proporitons, https://covid.cdc.gov/covid-datatracker/#variant-proportions. Accessed May 13, 2022.
CDC, 2022c, COVID Data Tracker COVID-NET Laboratory-confirmed COVID-19 hospitalizations, https://covid.cdc.gov/covid-data-tracker/#covidnet-hospitalization-network. Accessed May 13, 2022.
Chen C, Haupert SR, Zimmermann L, et al. Global Prevalence of Post COVID-19 Condition or Long COVID: A Meta-Analysis and Systematic Review, J. Infect. Dis., 2022;, jiac136, 10.1093/infdis/jiac136.
Daugherty SE, Guo Y, Heath K, et al. Risk of clinical sequelae after the acute phase of SARSCoV-2 infection: retrospective cohort study. BMJ. 2021;373:n1098. Published 2021 May 19. Doi:10.1136/bmj.n1098.
European Medicines Agency (EMA), 2020, EMA commissions independent research to prepare for real-world monitoring of COVID-19 vaccines 2020. Available from: https://www.ema.europa.eu/en/news/ema-commissions-independent-research-prepare-realworld-monitoring-covid-19-vaccines. Accessed May 27, 2022.
Heymans S, Cooper LT. (2022). Myocarditis after COVID-19 mRNA vaccination: clinical observations and potential mechanisms. Nat Rev Cardiol.
Murk W, Gierada M, Fralick M, et al. (2021). Diagnosis-wide analysis of COVID-19 complications: an exposure-crossover study. CMAJ.
Plumb ID, Feldstein LR, Barkley E, et al. (2022). Effectiveness of COVID-19 mRNA Vaccination in Preventing COVID-19–Associated Hospitalization Among Adults with Previous SARS-CoV-2 Infection — United States, June 2021–February 2022. Morb Mortal Wkly Rep.
Shimabukuro T, Nguyen M, Martin D, DeStefano F. (2015). Safety monitoring in the Vaccine Adverse Event Reporting System (VAERS). Vaccine.
Uppsala Monitoring Centre (UMC), 2021, Caveat Document 2021. Available from: https://whoumc.org/media/yzpnzmdv/umc_caveat.pdf. Accessed May 26, 2022.
UMC, 2022a, PV Products: VigiLyze 2022 (updated May 13, 2022). Available from: https://whoumc.org/pv-products/vigilyze/. Accessed May 27, 2022.
UMC, 2022b, About VigiBase, 2022b. Available from: https://who-umc.org/vigibase/. Accessed May 26, 2022.
VAC4EU, 2019, Toolbox: Dashboard Background rates of Adverse Events of Special Interest for COVID-19 vaccines 2019. Available from: https://vac4eu.org/covid-19-tool/. Accessed May 27, 2022.
Vojdani A, Kharrazian D. (2020). Potential antigenic cross-reactivity between SARS-CoV-2 and human tissue with a possible link to an increase in autoimmune diseases. Clin Immunol.
World Health Organization (WHO), 2022, WHO Coronavirus (COVID-19) Dashboard, https://covid19.who.int/. Accessed May 26, 2022.
Zou G. (2004). A modified Poisson regression approach to prospective studies with binary data. Am J Epidemiol.

## Novavax Decision Memorandum – October 19, 2022 - References

1 Johns Hopkins Coronavirus Resource Center (website) https://coronavirus.jhu.edu/ Accessed October 18, 2022
2 Centers for Disease Control and Prevention, 2022. Underlying Medical Conditions Associated with Higher Risk for Severe COVID-19: Information for Healthcare Professionals. (website) https://www.cdc.gov/coronavirus/2019- ncov/hcp/clinical-care/underlyingconditions.html Accessed August 26, 2022.
3 Centers for Disease Control and Prevention, 2021. Post-COVID Conditions: Overview for Healthcare Providers. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/post-covid-conditions.html Accessed August 26, 2022.
4 Irfan O., Muttalib F., Tang K., Jiang L., Lassi Z. S., Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Archives of disease in childhood.
5 Liguoro I., Pilotto C., Bonanni M., et al. (2020). SARS-COV-2 infection in children and newborns: a systematic review. European journal of pediatrics.
6 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-datatracker/#trends dailytrendscases Accessed October 18, 2022.
7 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-datatracker/#demographics Accessed October 18, 2022.
8 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-datatracker/#nowcast-heading Accessed October 18, 2022.
9 Pulliam J., van Schalkwyk C., Govender N., von Gottberg A., Cohen C., Groome M. J., Dushoff J., Mlisana K., Moultrie H. (2022). Increased risk of SARS-CoV-2 reinfection associated with emergence of Omicron in South Africa. Science (New York, N.Y.).
10 Tseng HF, Ackerson BK, Luo Y, et al. Accepted, Nature Medicine. Effectiveness of mRNA-1273 against SARSCoV-2 Omicron and Delta variants. Nature Medicine, 2022. 10.1038/s41591-022-01753-y.
11 Andrews N, Stowe J, Kirsebom F, et al. Covid-19 Vaccine Effectiveness against the Omicron (B.1.1.529) Variant. The New England Journal of Medicine.
12 Taylor CA, Whitaker M, Anglin O, et al. (2022). COVID-19–Associated Hospitalizations Among Adults During SARS-CoV-2 Delta and Omicron Variant Predominance, by Race/Ethnicity and Vaccination Status — COVID-NET, 14 States, July 2021–January 2022. MMWR Morb Mortal Wkly Rep.
13 Korves C., Izurieta H. S., Smith J., et al. (2022). Relative effectiveness of booster vs. 2-dose mRNA Covid-19 vaccination in the Veterans Health Administration: Self-controlled risk interval analysis. Vaccine.
14 Stowe J, Andrews N, Kirsebom F et al. Effectiveness of COVID-19 vaccines against Omicron and Delta hospitalisation: test negative case-control study. Preprint. https://khub.net/documents/135939561/430986542/Effectiveness+of+COVID19+vaccines+against+Omicron+and+Delta+hospitalisation+-+test+negative+case-control+study.pdf/d0e803c0- 3dd2-0c1b-03b8-0a12fd211980
15 Ferdinands JM, Rao S, Dixon BE, et al. (2022). Waning 2-Dose and 3-Dose Effectiveness of mRNA Vaccines Against COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep.
16 Chemaitelly H., Ayoub H. H., AlMukdad S., et al. (2022). Duration of mRNA vaccine protection against SARSCoV-2 Omicron BA.1 and BA.2 subvariants in Qatar. Nature communications.
17 Tenforde MW, Patel MM, Gaglani M, et al. (2022). Effectiveness of a Third Dose of Pfizer-BioNTech and Moderna Vaccines in Preventing COVID-19 Hospitalization Among Immunocompetent and Immunocompromised Adults — United States, August–December 2021. MMWR Morb Mortal Wkly Rep.
18 Arbel R, Sergienko R, Friger M, et al: BNT162b2 vaccine booster and mortality due to COVID
19 Engl N, Med J. (2021). 385:2413-2420. 19 Bar-On, Y. M., Goldberg, Y., Mandel, M., Bodenheimer, O., Amir, O., Freedman, L., Alroy-Preis, S., Ash, N., Huppert, A., & Milo, R. (2022). Protection by a Fourth Dose of BNT162b2 against Omicron in Israel. The New England journal of medicine.
20 Gazit S, Saciuk Y, Perez G, et al. Relative Effectiveness of Four Doses Compared to Three Dose of the BNT162b2 Vaccine in Israel. medRxiv.
21 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/media/139638/download
22 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. February 2021. https://www.fda.gov/media/142749/download
23 LiverTox: Clinical and Research Information on Drug-Induced Liver Injury [Internet]. Bethesda (MD): National Institute of Diabetes and Digestive and Kidney Diseases; 2012-. Covid-19 Vaccines. [Updated 2021 Oct 28]. Available from: https://www.ncbi.nlm.nih.gov/books/NBK570468/
24 Munro A., Janani L., Cornelius V., et al., COV-BOOST study group. (2021). Safety and immunogenicity of seven COVID-19 vaccines as a third dose (booster) following two doses of ChAdOx1 nCov-19 or BNT162b2 in the UK (COV-BOOST): a blinded, multicentre, randomised, controlled, phase 2 trial. Lancet (London, England).
25 Thompson MG, Natarajan K, Irving SA, et al. (2022). Effectiveness of a Third Dose of mRNA Vaccines Against COVID-19– Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep.

## Janssen Decision Memorandum - February 4, 2021 - References

1 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. February 2021. https://www.fda.gov/media/142749/download.
2 Zhu N, Zhang D, Wang W, et al. (2020). A Novel Coronavirus from Patients with Pneumonia in China, 2019. The New England journal of medicine.
3 Coronaviridae Study Group of the International Committee on Taxonomy of V. The species Severe acute respiratory syndrome-related coronavirus: classifying 2019-nCoV and naming it SARS-CoV-2.
4 Lu R, Zhao X, Li J, et al. (2020). Genomic characterisation and epidemiology of 2019 novel coronavirus: implications for virus origins and receptor binding. Lancet (London,England).
5 Hoffmann M, Kleine-Weber H, Schroeder S, et al. (2020). SARS-CoV-2 Cell Entry Depends onACE2 and TMPRSS2 and Is Blocked by a Clinically Proven Protease Inhibitor. Cell.
6 Federal Food, Drug and Cosmetic Act, 21 U.S.C. § 360bbb–3 and 360bbb-3b. (2011).
7 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID19. June 2020. https://www.fda.gov/regulatory-information/search-fda-guidancedocuments/development-and-licensure-vaccines-prevent-covid-19.
8 National Vaccine Injury Compensation Program. Vaccine Injury Table, Revised and Effective March 21, 2017. https://www.hrsa.gov/sites/default/files/hrsa/vaccinecompensation/vaccine-injury-table.pdf.
9 Roush SW, Murphy TV, Vaccine-Preventable Disease Table Working Group, the. (2007). Historical Comparisons of Morbidity and Mortality for Vaccine-Preventable Diseases in the United States. JAMA.
10 Verhees RAF, Dondorp W, Thijs C, Dinant GJ, Knottnerus JA. (2018). Influenza vaccination in the elderly: Is a trial on mortality ethically acceptable?. Vaccine.
11 Flannery B, Reynolds SB, Blanton L, et al. Influenza Vaccine Effectiveness Against Pediatric Deaths: 2010–2014. 2017;139(5):e20164244.
12 Rolfes MA, Flannery B, Chung JR, et al. (2019). Effects of Influenza Vaccination in the United States During the 2017-2018 Influenza Season. Clinical infectious diseases : an official publication of the Infectious Diseases Society of America.

## Janseen – Memorandum to the file - October 4, 2021 - References

1 Woo EJ, Mba-Jonas A, Dimova RB, Alimchandani M, Zinderman CE, Nair N. Association of Receipt of the Ad26.COV2.S COVID-19 Vaccine With Presumptive Guillain-Barré Syndrome, February-July 2021. JAMA.
2 Federal Food Drug and Cosmetic Act. 21 U.S.C. § 360bbb–3 and 360bbb-3b. (2011). 2011.
3 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/media/139638/download
4 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. February 2021. https://www.fda.gov/media/142749/download
5 FDA. Emergency Use Authorization Review Memorandum for the Janssen COVID-19 Vaccine/ Ad26.COV2.S. December 11, 2020. https://www.fda.gov/media/146338/download

## Moderna Decision Memorandum - November 30, 2020 - References

1 Zhu N, Zhang D, Wang W, et al. (2020). A Novel Coronavirus from Patients with Pneumonia in China, 2019. The New England journal of medicine.
2 Coronaviridae Study Group of the International Committee on Taxonomy of V. The species Severe acute respiratory syndrome-related coronavirus: classifying 2019-nCoV and naming it SARS-CoV-2.
3 Lu R, Zhao X, Li J, et al. (2020). Genomic characterisation and epidemiology of 2019 novel coronavirus: implications for virus origins and receptor binding. Lancet (London, England).
4 Hoffmann M, Kleine-Weber H, Schroeder S, et al. (2020). SARS-CoV-2 Cell Entry Depends on ACE2 and TMPRSS2 and Is Blocked by a Clinically Proven Protease Inhibitor. Cell.
5 Federal Food, Drug and Cosmetic Act, 21 U.S.C. § 360bbb–3 and 360bbb-3b. (2011).
6 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. October 2020. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/emergency-use-authorization-vaccines-prevent-covid-19.
7 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/development-and-licensure-vaccines-prevent-covid-19.
8 National Vaccine Injury Compensation Program. Vaccine Injury Table, Revised and Effective March 21, 2017. https://www.hrsa.gov/sites/default/files/hrsa/vaccine-compensation/vaccine-injury-table.pdf.
9 International Coalition of Medicines Regulatory Authorities. Statement on continuation of vaccine trials. http://www.icmra.info/drupal/en/covid-19/statement on continuation of vaccine trials. 2020.
10 Krause PR, Fleming TR, Longini IM, et al. (2020). Placebo-Controlled Trials of Covid-19 Vaccines - Why We Still Need Them. The New England journal of medicine.
11 Wendler D, Ochoa J, Millum J, Grady C, Taylor HA. (2020). COVID-19 vaccine trial ethics once w e have efficacious vaccines. Science.
12 Centers for Disease Control and Prevention. Evidence used to update the list of underlying medical conditions that increase a person’s risk of severe illness from COVID-19. 2020. https://www.cdc.gov/coronavirus/2019-ncov/need-extra-precautions/evidence-table.html.
13 Roush SW, Murphy TV, Vaccine-Preventable Disease Table Working Group, the. (2007). Historical Comparisons of Morbidity and Mortality for Vaccine-Preventable Diseases in the United States. JAMA.
14 Verhees RAF, Dondorp W, Thijs C, Dinant GJ, Knottnerus JA. (2018). Influenza vaccination in the elderly: Is a trial on mortality ethically acceptable?. Vaccine.
15 Flannery B, Reynolds SB, Blanton L, et al. Influenza Vaccine Effectiveness Against Pediatric Deaths: 2010–2014. 2017;139(5):e20164244.
16 Rolfes MA, Flannery B, Chung JR, et al. (2019). Effects of Influenza Vaccination in the United States During the 2017-2018 Influenza Season. Clinical infectious diseases : an official publication of the Infectious Diseases Society of America.

## Moderna Review Memorandum - September 3, 2021 – References

1 CDC. (2021). COVID-19 Response Team. Allergic Reactions Including Anaphylaxis After Receipt of the First Dose of Moderna COVID-19 Vaccine - United States, December 21, 2020-January 10, 2021. MMWR Morb Mortal Wkly Rep.
2 CDC. COVID-19 Breakthrough Case Investigations and Reporting. COVID-19 Breakthrough Case Investigations and Reporting | CDC. Accessed, September 21, 2021.
3 Federal Food Drug and Cosmetic Act. 21 U.S.C. § 360bbb–3 and 360bbb-3b. (2011). 2011.
4 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/media/139638/download
5 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. February 2021. https://www.fda.gov/media/142749/download
6 Fact Sheet for Healthcare Providers Administering Vaccine (Vaccination Providers) Emergency Use Authorization (EUA) of the Moderna Covid-19 Vaccine to Prevent Coronavirus Disease 2019 (Covid-19). August 27, 2021. https://www.fda.gov/media/144637/download

## Moderna Decision Memorandum - October 20, 2021 - References

1 CDC. (2021). COVID-19 Response Team. Allergic Reactions Including Anaphylaxis After Receipt of the First Dose of Moderna COVID-19 Vaccine - United States, December 21, 2020-January 10, 2021. MMWR Morb Mortal Wkly Rep.
2 CDC. COVID-19 Breakthrough Case Investigations and Reporting. COVID-19 Breakthrough Case Investigations and Reporting | CDC. Accessed, September 21, 2021.
3 Federal Food Drug and Cosmetic Act. 21 U.S.C. § 360bbb–3 and 360bbb-3b. (2011). 2011.
4 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/media/139638/download
5 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. February 2021. https://www.fda.gov/media/142749/download
6 Fact Sheet for Healthcare Providers Administering Vaccine (Vaccination Providers) Emergency Use Authorization (EUA) of the Moderna Covid-19 Vaccine to Prevent Coronavirus Disease 2019 (Covid-19). August 27, 2021. https://www.fda.gov/media/144637/download

## Moderna Decision Memorandum – June 17, 2022 - References

1 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Arch Dis Child.
2 Liguoro I, Pilotto C, Bonanni M, et al. (2020). SARS-COV-2 infection in children and newborns: a systematic review. Eur J Pediatr.
3 Irfan, 2021.
4 Assaker R, Colas A-E, Julien-Marsollier F, et al. (2020). Presenting Symptoms of COVID-19 in Children: A Meta-Analysis of Published Studies. Br J Anaesth.
5 Poline J, Gaschignard J, Leblanc C, et al. (2021). Systematic Severe Acute Respiratory Syndrome Coronavirus 2 Screening at Hospital Admission in Children: A French Prospective Multicenter Study. Clin Infect Dis.
6 Office of National Statistics. Updated estimates of the prevalence of ongoing symptoms following coronavirus (COVID-19) infection in the UK. https://www.ons.gov.uk/peoplepopulationandcommunity/healthandsocialcare/conditionsanddiseases/datasets/alldatarelatingtoprevalenceofongoingsymptomsfollowingcoronaviruscovid19infectionintheuk Accessed April 1, 2022.
7 Johns Hopkins Coronavirus Resource Center (website) https://coronavirus.jhu.edu/ Accessed June 2, 2022.
8 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trends_dailytrendscases Accessed June 2, 2022.
9 Centers for Disease Control and Prevention. COVID-19 Vaccine Effectiveness in Children and Adults. Presented at the meeting of the Advisory Committee on Immunization Practices, September 22, 2021. https://www.cdc.gov/vaccines/acip/meetings/downloads/slides-2021-09-22/04-COVID-Link-Gelles508.pdf
10 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#nowcasting Accessed June 2, 2022.
11 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#nowcasting Accessed June 2, 2022.
12 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics Accessed June 2, 2022.
13 Centers for Disease Control and Prevention. COVID Data Tracker (website).Counts of Hospitalizations by Age from the COVID-NET Network (data downloaded on June 2, 2022. https://covid.cdc.gov/coviddata-tracker/#covidnet-hospitalization-network Accessed June 2, 2022.
14 Centers for Disease Control and Prevention. COVID Data Tracker (website) https://covid.cdc.gov/coviddata-tracker/#demographics Accessed June 2, 2022.
15 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#pediatric-data Accessed June 2, 2022.
16 Kim L, Whitaker M, O'Halloran A, et al. (2020). Hospitalization Rates and Characteristics of Children Aged< 18 Years Hospitalized with Laboratory-Confirmed COVID-19 -COVID-NET, 14 States, March 1-July 25, 2020. MMWR Morb Mortal Wkly Rep.
17 McCormick DW, Richardson LC, Young PR, et al. (2021). Deaths in Children and Adolescents Associated With COVID-19 and MIS-C in the United States. Pediatrics.
18 Murk W, Gierada M, Fralick M, Weckstein A, Klesh R, Rassen JA. (2021). Diagnosis-wide analysis of COVID19 complications: an exposure-crossover study. CMAJ.
19 Daugherty SE, Guo Y, Heath K, et al. Risk of clinical sequelae after the acute phase of SARS-CoV-2 infection: retrospective cohort study. BMJ. 2021;373:n1098. Published 2021 May 19.
20 Dufort EM, et al. (2020). COVID-19: Multisystem inflammatory syndrome in children (MIS-C) clinical features, evaluation, and diagnosis. N Engl J Med.
21 Centers for Disease Control and Prevention. Health Department-Reported Cases of Multisystem Inflammatory Syndrome in Children (MIS-C) in the United States. October 17, 2021. https://covid.cdc.gov/covid-data-tracker/#mis-national-surveillance
22 Feldstein, et al. (2021). Characteristics and Outcomes of US Children and Adolescents with Mulitsystem Inflammatory Syndrome in Children (MIS-C) Compared with Severe Acute COVID-19. JAMA.
23 Farooqi KM, Chan A, Weller RJ, et al. (2021). Longitudinal Outcomes for Multisystem Inflammatory Syndrome in Children. Pediatrics.
24 Farooqi, 2021.
25 Hillis SD, Blenkinsop A, Villaveces A, et al. (2021). COVID-19-Associated Orphanhood and Caregiver Death in the United States. Pediatrics.
26 Racine N, Cooke JE, Eirich R, Korczak DJ, McArthur B, Madigan S. (2020). Child and adolescent mental illness during COVID-19: A rapid review. Psychiatry Res.
27 Magson NR, Freeman JYA, Rapee RM, Richardson CE, Oar EL, Fardouly J. (2021). Risk and Protective Factors for Prospective Changes in Adolescent Mental Health during the COVID-19 Pandemic. J Youth Adolesc.
28 Hill RM, Rufino K, Kurian S, et al. (2021). Suicide Ideation and Attempts in a Pediatric Emergency Department Before and During COVID-19. Pediatrics.
29 Shi DS, Whitaker M, Marks KJ, et al. (2022). Hospitalizations of Children Aged 5–11 Years with LaboratoryConfirmed COVID-19 — COVID-NET, 14 States, March 2020–February 2022. MMWR Morb Mortal Wkly Rep.
30 Tseng, 2022.
31 Nasreen S, Chung H, He S, et al. (2022). Effectiveness of COVID-19 vaccines against symptomatic SARSCoV-2 infection and severe outcomes with variants of concern in Ontario. Nat Microbiol.
32 Lauring AS, Tenforde MW, Chappell JD, et al. Clinical severity of, and effectiveness of mRNA vaccines against, covid-19 from omicron, delta, and alpha SARS-CoV-2 variants in the United States: prospective observational study. BMJ. 2022;376:e069761. Published 2022 Mar 9. doi:10.1136/bmj2021-069761
33 Centers for Disease Control and Prevention. COVID-19 Vaccine Effectiveness in Children and Adults. Slide presentation at a meeting of the Vaccines and Related Biological Products Advisory Committee, April 6, 2022. https://www.fda.gov/media/157475/download
34 Centers for Disease Control and Prevention. COVID Data Tracker: Vaccinations in the US (website) Accessed May 13, 2022.
35 Gee J, Marquez P, Su J, et al. (2021). First Month of COVID-19 Vaccine Safety Monitoring — United States, December 14, 2020–January 13, 2021. MMWR Morb Mortal Wkly Rep.
36 Allergic Reactions Including Anaphylaxis After Receipt of the First Dose of Pfizer-BioNTech COVID-19 Vaccine — United States. (2021). December 14–23, 2020. MMWR Morb Mortal Wkly Rep.
37 Montgomery J, Ryan M, Engler R, et al. (2021). Myocarditis Following Immunization With mRNA COVID-19 Vaccines in Members of the US Military. JAMA Cardiol.
38 Rosner CM, Genovese L, Tehrani BN, et al. (2021). Myocarditis temporally associated with COVID-19 vaccination. Circulation.
39 Kim HW, Jenista ER, Wendell DC, et al. (2021). Patients with acute myocarditis following mRNA COVID-19 vaccination. JAMA Cardiol.
40 Marshall M, Ferguson ID, Lewis P, et al. (2021). Symptomatic acute myocarditis in 7 adolescents after PfizerBioNTech COVID-19 vaccination. Pediatrics.
41 Diaz GA, Parsons GT, Gering SK, et al. (2021). Myocarditis and pericarditis after vaccination for COVID-19. JAMA.
42 Klein NP, Lewis N, Goddard K, et al. (2021). Surveillance for Adverse Events After COVID-19 mRNA Vaccination. JAMA.
43 Results shared with US Food and Drug Administration under confidentiality agreements.
44 CDC. COVID-19 vaccine safety updates. Advisory Committee on Immunization Practices (ACIP) October 21, 2021 meeting presentation, 2021. Available at: https://www.cdc.gov/vaccines/acip/meetings/downloads/slides-2021-10-20-21/08-COVID-Klein508.pdf. Accessed May 2022.
45 Vaccine Adverse Event Reporting System (VAERS). Observed versus expected analysis performed by FDA/ CBER/OBPV/Division of Epidemiology on data through July 7, 2021 for men aged 18-24 years with 0-7 days risk window.
46 US Food and Drug Administration. Vaccines and Related Biological Products Advisory Committee October 14–15, 2021 meeting presentation. 2021. Available at: https://www.fda.gov/media/153090/download. Accessed May 2022.
47 Abraham N, Spruin S, Rossi T, et al. Myocarditis and/or pericarditis risk after mRNA COVID-19 vaccination: a Canadian head-to-head comparison of BNT162b2 and mRNA-1273 vaccines. Vaccine. Pre-proof posted: May 2022. Available at: https://www.sciencedirect.com/science/article/pii/S0264410X22006673. Accessed June 1, 2022
48 Buchan SA. Seo CY, Johnson C, et al. Epidemiology of myocarditis and pericarditis following mRNA vaccines in Ontario, Canada: by vaccine product, schedule and interval. Preprint posted: December 5, 2021. Available at: https://www.medrxiv.org/content/10.1101/2021.12.02.21267156v1. Accessed May 2022.
49 Patone M, Mei XW, Handunnetthi L et al. Risk of myocarditis following sequential COVID-19 vaccinations by age and sex. Preprint posted: December 25, 2021. Available at: https://www.medrxiv.org/content/10.1101/2021.12.23.21268276v1. Accessed May 2022
50 Husby A, Hansen JV, Fosbøl E, et al. (2021). SARS-CoV-2 vaccination and myocarditis or myopericarditis: population based cohort study. BMJ.
51 Karlstad Ø, Hovi P, Husby A, et al. (2022). SARS-CoV-2 Vaccination and Myocarditis in a Nordic Cohort Study of 23 Million Residents. JAMA Cardiol.
52 Massari M, Spila-Alegiani S, Morciano C, et al. Post-marketing active surveillance of myocarditis and pericarditis following vaccination with COVID-19 mRNA vaccines in persons aged 12-39 years in Italy: a multi-database, self-controlled case series study. Preprint posted: February 08, 2022. Available at: https://www.medrxiv.org/content/10.1101/2022.02.07.22270020v1.
53 European Medicines Agency. Pharmacovigilance Risk Assessment Committee (PRAC). Signal assessment report on myocarditis and pericarditis with Spikevax - COVID-19 mRNA vaccine (nucleoside-modified) (French case-control study mentioned on pages 17-19). Available at: https://www.ema.europa.eu/en/documents/prac-recommendation/signal-assessment-reportmyocarditis-pericarditis-spikevax-previously-covid-19-vaccine-moderna-covid_en.pdf. Accessed June 2022
54 Oster ME, Shay DK, Su JR, et al. (2022). Myocarditis cases reported after mRNA-based COVID-19 vaccination in the US from December 2020 to August 2021. JAMA.
55 Klein N. Myocarditis analyses in the vaccine safety datalink: rapid cycle analyses and “head-to-head” product comparisons. Feb 4, 2022. Available at: https://www.cdc.gov/vaccines/acip/meetings/downloads/slides-2022-02-04/10-COVID-Klein-508.pdf. Accessed May 2022.
56 Wong HL, Hu M, Zhou CK, et al. (2022). Risk of myocarditis and pericarditis after the COVID-19 mRNA vaccination in the USA: a cohort study in claims databases. Lancet.
57 Oster, 2022.
58 Wong, 2022.
59 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. March 2022. https://www.fda.gov/media/142749/download
60 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/development-andlicensure-vaccines-prevent-covid-19
61 Racine N, McArthur BA, Cooke JE, Eirich R, Zhu J, Madigan S. (2021). Global Prevalence of Depressive and Anxiety Symptoms in Children and Adolescents During COVID-19: A Metaanalysis. JAMA Pediatr.
62 FDA. BLA Clinical Review Memorandum for Spikevax (Moderna COVID-19 Vaccine). January 28, 2022. https://www.fda.gov/media/156342/download
63 Gargano JW, Wallace M, Hadler SC, et al. Use of mRNA COVID-19 Vaccine After Reports of Myocarditis Among Vaccine Recipients: Update from the Advisory Committee on Immunization Practices - United States, June 2021. MMWR Morb Mortal Wkly Rep. 2021;70(27):977-982. Published 2021 Jul 9. https://www.cdc.gov/mmwr/volumes/70/wr/pdfs/mm7027e2-H.pdf
64 Gargano, 2021.
65 Tseng, 2022.
66 Gargano, 2021.
67 Tseng, 2022.
68 Girard B, Tomassini JE, Deng W, et al. mRNA-1273 Vaccine-elicited Neutralization of SARS-CoV-2 Omicron in Adolescents and Children. medRxiv.
69 Tseng 2022.
70 Centers for Disease Control and Prevention. COVID-19 Vaccine Effectiveness in Children and Adults. Slide presentation at a meeting of the Vaccines and Related Biological Products Advisory Committee, April 6, 2022. https://www.fda.gov/media/157475/download
71 Tseng, 2022.
72 Plumb ID, Feldstein LR, Barkley E, et al. (2022). Effectiveness of COVID-19 mRNA Vaccination in Preventing COVID-19–Associated Hospitalization Among Adults with Previous SARS-CoV-2 Infection — United States, June 2021–February 2022. Morb Mortal Wkly Rep.
73 Gee, et al. (2022). Effectiveness of mRNA-1273 against SARS-CoV-2 Omicron and Delta variants [published correction appears in Nat Med. 2022 Apr 21. Nat Med.

## Moderna Decision Memorandum – August 31, 2022 - References

1 Johns Hopkins Coronavirus Resource Center (website) https://coronavirus.jhu.edu/ Accessed August 26, 2022
2 Centers for Disease Control and Prevention, 2022. Underlying Medical Conditions Associated with Higher Risk for Severe COVID-19: Information for Healthcare Professionals. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/underlyingconditions.html Accessed August 26, 2022.
3 Centers for Disease Control and Prevention, 2021. Post-COVID Conditions: Overview for Healthcare Providers. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/post-covidconditions.html Accessed August 26, 2022.
4 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trends dailytrendscases Accessed August 26, 2022.
5 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics Accessed August 26, 2022.
6 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#nowcast-heading Accessed August 26, 2022.
7 Pulliam J., van Schalkwyk C., Govender N., von Gottberg A., Cohen C., Groome M. J., Dushoff J., Mlisana K., Moultrie H. (2022). Increased risk of SARS-CoV-2 reinfection associated with emergence of Omicron in South Africa. Science (New York, N.Y.).
8 Tseng HF, Ackerson BK, Luo Y, et al. (2022). Effectiveness of mRNA-1273 against SARS-CoV-2 Omicron and Delta variants. Nat Med.
9 Andrews N, Stowe J, Kirsebom F, et al. (2022). Covid-19 Vaccine Effectiveness against the Omicron (B.1.1.529) Variant. N Engl J Med.
10 Taylor CA, Whitaker M, Anglin O, et al. (2022). COVID-19–Associated Hospitalizations Among Adults During SARS-CoV-2 Delta and Omicron Variant Predominance, by Race/Ethnicity and Vaccination Status — COVID-NET, 14 States, July 2021–January 2022. MMWR Morb Mortal Wkly Rep.
11 Korves C, Izurieta HS, Smith J, et al. (2022). Relative effectiveness of booster vs. 2-dose mRNA Covid-19 vaccination in the Veterans Health Administration: Self-controlled risk interval analysis. Vaccine.
12 Stowe J, Andrews N, Kirsebom F, Ramsay M, Bernal JL. (2022). Effectiveness of COVID-19 vaccines against Omicron and Delta hospitalisation: test negative case-control study. medRxiv.
13 Ferdinands JM, Rao S, Dixon BE, et al. (2022). Waning 2-Dose and 3-Dose Effectiveness of mRNA Vaccines Against COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep.
14 Chemaitelly H, Ayoub HH, AlMukdad S, et al. Duration of mRNA vaccine protection against SARSCoV-2 Omicron BA.1 and BA.2 subvariants in Qatar. Nat Commun. 2022;13(1):3082. Published 2022 Jun 2.
15 Tenforde MW, Patel MM, Gaglani M, et al. (2022). Effectiveness of a Third Dose of Pfizer-BioNTech and Moderna Vaccines in Preventing COVID-19 Hospitalization Among Immunocompetent and Immunocompromised Adults — United States, August–December 2021. MMWR Morb Mortal Wkly Rep.
16 Arbel R, Sergienko R, Friger M, et al. (2021). BNT162b2 vaccine booster and mortality due to COVID 19. N Engl J Med.
17 Bar-On YM, Goldberg Y, Mandel M, et al. (2022). Protection by a Fourth Dose of BNT162b2 against Omicron in Israel. N Engl J Med.
18 Gazit S, Saciuk Y, Perez G, et al. Relative Effectiveness of Four Doses Compared to Three Dose of the BNT162b2 Vaccine in Israel. medRxiv.
19 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. March 2022. https://www.fda.gov/media/142749/download
20 Atmar RL, Lyke KE, Deming ME, et al. (2022). Homologous and Heterologous Covid-19 Booster Vaccinations. N Engl J Med.
21 World Health Organization (2021). Interim recommendations for heterologous COVID-19 vaccine schedules. https://www.who.int/publications/i/item/WHO-2019-nCoV-vaccines-SAGE-recommendationheterologous-schedules
22 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#vaccinations vacc-total-admin-rate-total Accessed August 26, 2022.
23 Gee J, Marquez P, Su J, et al. (2021). First Month of COVID-19 Vaccine Safety Monitoring — United States, December 14, 2020–January 13, 2021. MMWR Morb Mortal Wkly Rep.
24 Centers for Disease Control and Prevention. Myocarditis following mRNA COVID-19 vaccination. Presented at the meeting of the Advisory Committee on Immunization Practices, July 19, 2022. https://www.cdc.gov/vaccines/acip/meetings/downloads/slides-2022-07-19/03-covid-shimabukuro508.pdf
25 Lauring AS, Tenforde MW, Chappell JD, Gaglani M, Ginde AA, McNeal T, Ghamande S, Douin DJ, Talbot HK, Casey JD, Mohr NM. (2022). Clinical severity and mRNA vaccine effectiveness for omicron, delta, and alpha SARS-CoV-2 variants in the United States: a prospective observational study. MedRxiv.
26 Dorabawila V, Hoefer D, Bauer UE, Bassett M, Lutterloh E, Rosenberg E. (2022). Effectiveness of the BNT162b2 vaccine among children 5-11 and 12-17 years in New York after the Emergence of the Omicron Variant. medRxiv.
27 Kislaya I, Casaca P, Borges V, Sousa C, Ferreira B, Fernandes E, Dias CM, Duarte S, Almeida JP, Coelho L, Grenho I. (2022). SARS-CoV-2 BA. 5 vaccine breakthrough risk and severity compared with BA. 2: a case-case and cohort study using Electronic Health Records in Portugal. medRxiv.
28 Wong HL, Hu M, Zhou CK, et al. (2022). Risk of myocarditis and pericarditis after the COVID-19 mRNA vaccination in the USA: a cohort study in claims databases. Lancet.

## Moderna Decision Memorandum – April 18, 2023 - References

1 World Health Organization Coronavirus (COVID-19) Dashboard (website) https://covid19.who.int/, Accessed April 8, 2023.
2 Centers for Disease Control and Prevention, 2022. Underlying Medical Conditions Associated with Higher Risk for Severe COVID-19: Information for Healthcare Professionals. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/underlyingconditions.html Accessed August 26, 2022.
3 Centers for Disease Control and Prevention, 2021. Post-COVID Conditions: Overview for Healthcare Providers. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/post-covid-conditions.html Accessed August 26, 2022.
4 Liguoro I, Pilotto C, Bonanni M, et al. (2020). SARS-COV-2 infection in children and newborns: a systematic review. Eur J Pediatr.
5 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Arch Dis Child.
6 Assaker R, Colas AE, Julien-Marsollier F, et al. (2020). Presenting symptoms of COVID-19 in children: a meta-analysis of published studies. Br J Anaesth.
7 Poline J, Gaschignard J, Leblanc C, et al. (2021). Systematic Severe Acute Respiratory Syndrome Coronavirus 2 Screening at Hospital Admission in Children: A French Prospective Multicenter Study. Clin Infect Dis.
8 Centers for Disease Control and Prevention. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trendsdailytrendscases Accessed April 14, 2023.
9 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics Accessed August 26, 2022.
10 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#nowcast-heading Accessed August 26, 2022.
11 Pulliam JRC, van Schalkwyk C, Govender N, et al. (2022). Increased risk of SARS-CoV-2 reinfection associated with emergence of Omicron in South Africa. Science.
12 Tseng HF, Ackerson BK, Luo Y, et al. (2022). Effectiveness of mRNA-1273 against SARS-CoV-2 Omicron and Delta variants. Nat Med.
13 Andrews N, Stowe J, Kirsebom F, et al. (2022). Covid-19 Vaccine Effectiveness against the Omicron (B.1.1.529) Variant. N Engl J Med.
14 Taylor CA, Whitaker M, Anglin O, et al. COVID-19–Associated Hospitalizations Among Adults During SARS-CoV-2 Delta and Omicron Variant Predominance, by Race/Ethnicity and Vaccination Status— COVID-NET, 14 States, July 2021–January 2022. MMWR Morb Mortal Wkly Rep 2022;71:466–473. DOI: https://www.cdc.gov/mmwr/volumes/71/wr/mm7112e2.htm.
15 Korves C, Izurieta HS, Smith J, et al. (2022). Relative effectiveness of booster vs. 2-dose mRNA Covid-19 vaccination in the Veterans Health Administration: Self-controlled risk interval analysis. Vaccine.
16 Stowe J, Andrews N, Kirsebom F, Ramsay M, Bernal JL. (2022). Effectiveness of COVID-19 vaccines against Omicron and Delta hospitalisation: test negative case-control study. medRxiv.
17 Ferdinands JM, Rao S, Dixon BE, et al. Waning 2-Dose and 3-Dose Effectiveness of mRNA Vaccines Against COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep 2022;71:255–263. DOI: https://www.cdc.gov/mmwr/volumes/71/wr/mm7107e2.htm
18 Chemaitelly H, Ayoub HH, AlMukdad S, et al. Duration of mRNA vaccine protection against SARS- CoV-2 Omicron BA.1 and BA.2 subvariants in Qatar. Nat Commun. 2022;13(1):3082. Published 2022 Jun 2.
19 Tenforde MW, Patel MM, Gaglani M, et al. (2022). Effectiveness of a Third Dose of Pfizer-BioNTech and Moderna Vaccines in Preventing COVID-19 Hospitalization Among Immunocompetent and Immunocompromised Adults — United States, August–December 2021. MMWR Morb Mortal Wkly Rep.
20 Arbel R, Sergienko R, Friger M, et al. (2021). BNT162b2 vaccine booster and mortality due to COVID 19. N Engl J Med.
21 Bar-On YM, Goldberg Y, Mandel M, et al. (2022). Protection by a Fourth Dose of BNT162b2 against Omicron in Israel. N Engl J Med.
22 Gazit S, Saciuk Y, Perez G, et al. Relative Effectiveness of Four Doses Compared to Three Dose of the BNT162b2 Vaccine in Israel. medRxiv.
23 Andeweg SP, de Gier B, Eggink D, van den Ende C, van Maarseveen N, Ali L, et al. (2022). Protection of COVID-19 vaccination and previous infection against Omicron BA.1, BA.2 and Delta SARS-CoV-2 infections. Nat Commun.
24 Flury BB, Güsewell S, Egger T, Leal O, Brucher A, Lemmenmeier E, et al. (2022). Risk and symptoms of COVID-19 in health professionals according to baseline immune status and booster vaccination during the Delta and Omicron waves in Switzerland-A multicentre cohort study. PLoS Med.
25 Bates TA, McBride SK, Leier HC, Guzman G, Lyski ZL, Schoen D, et al. (2022). Vaccination before or after SARS-CoV-2 infection leads to robust humoral response and antibodies that effectively neutralize variants. Sci Immunol.
26 Chin ET, Leidner D, Lamson L, Lucas K, Studdert DM, Goldhaber-Fiebert JD, et al. (2022). Protection against Omicron from Vaccination and Previous Infection in a Prison System. N Engl J Med.
27 Hansen CH, Friis NU, Bager P, Stegger M, Fonager J, Fomsgaard A, et al. (2023). Risk of reinfection, vaccine protection, and severity of infection with the BA.5 omicron subvariant: a nation-wide population-based study in Denmark. Lancet Infect Dis.
28 Powell AA, Kirsebom F, Stowe J, Ramsay ME, Lopez-Bernal J, Andrews N, et al. (2022). Protection against symptomatic infection with delta (B.1.617.2) and omicron (B.1.1.529) BA.1 and BA.2 SARS-CoV-2 variants after previous infection and vaccination in adolescents in England, August, 2021-March, 2022: a national, observational, test-negative, case-control study. Lancet Infect Dis.
29 Scheaffer S. M., Lee D., Whitener B., Ying B., et al. (2023). Bivalent SARS-CoV-2 mRNA vaccines increase breadth of neutralization and protect against the BA.5 Omicron variant in mice. Nature medicine.
30 Carazo S., Skowronski D. M., Brisson M., et al. (2023). Protection against omicron (B.1.1.529) BA.2 reinfection conferred by primary omicron BA.1 or pre-omicron SARS-CoV-2 infection among health-care workers with and without mRNA vaccination: a test-negative case-control study. The Lancet. Infectious diseases.
31 Carazo S., Skowronski D. M., Brisson M., et al. (2022). Estimated Protection of Prior SARS-CoV-2 Infection Against Reinfection With the Omicron Variant Among Messenger RNA-Vaccinated and Nonvaccinated Individuals in Quebec, Canada. JAMA network open.
32 Centers for Disease Control and Prevention. COVID Data Tracker. Atlanta, GA: US Department of Health and Human Services, CDC; 2023, March 31. https://covid.cdc.gov/covid-data-tracker
33 Lauring AS, Tenforde MW, Chappell JD, Gaglani M, Ginde AA, McNeal T, Ghamande S, Douin DJ, Talbot HK, Casey JD, Mohr NM. (2022). Clinical severity and mRNA vaccine effectiveness for omicron, delta, and alpha SARS-CoV-2 variants in the United States: a prospective observational study. MedRxiv.
34 Dorabawila V, Hoefer D, Bauer UE, Bassett M, Lutterloh E, Rosenberg E. (2022). Effectiveness of the BNT162b2 vaccine among children 5-11 and 12-17 years in New York after the Emergence of the Omicron Variant. medRxiv.
35 Kislaya I, Casaca P, Borges V, Sousa C, Ferreira B, Fernandes E, Dias CM, Duarte S, Almeida JP, Coelho L, Grenho I. (2022). SARS-CoV-2 BA. 5 vaccine breakthrough risk and severity compared with BA. 2: a case-case and cohort study using Electronic Health Records in Portugal. medRxiv.
36 Atmar RL, Lyke KE, Deming ME, et al. (2022). Homologous and Heterologous Covid-19 Booster Vaccinations. N Engl J Med.

## Pfizer Decision Memorandum - December 2020 - References

1 Zhu N, Zhang D, Wang W, et al. (2020). A Novel Coronavirus from Patients with Pneumonia in China, 2019. The New England journal of medicine.
2 Coronaviridae Study Group of the International Committee on Taxonomy of V. The species Severe acute respiratory syndrome-related coronavirus: classifying 2019-nCoV and naming it SARS-CoV-2.
3 Lu R, Zhao X, Li J, et al. (2020). Genomic characterisation and epidemiology of 2019 novel coronavirus: implications for virus origins and receptor binding. Lancet (London, England).
4 Hoffmann M, Kleine-Weber H, Schroeder S, et al. (2020). SARS-CoV-2 Cell Entry Depends on ACE2 and TMPRSS2 and Is Blocked by a Clinically Proven Protease Inhibitor. Cell.
5 Federal Food, Drug and Cosmetic Act, 21 U.S.C. § 360bbb–3 and 360bbb-3b. (2011).
6 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID19. June 2020. https://www.fda.gov/regulatory-information/search-fda-guidancedocuments/development-and-licensure-vaccines-prevent-covid-19.
7 National Vaccine Injury Compensation Program. Vaccine Injury Table, Revised and Effective March 21, 2017. https://www.hrsa.gov/sites/default/files/hrsa/vaccinecompensation/vaccine-injury-table.pdf.
8 International Coalition of Medicines Regulatory Authorities. Statement on continuation of vaccine trials. http://www.icmra.info/drupal/en/covid19/statement on continuation of vaccine trials. 2020.
9 Krause PR, Fleming TR, Longini IM, et al. (2020). Placebo-Controlled Trials of Covid-19 Vaccines - Why We Still Need Them. The New England journal of medicine.
10 Wendler D, Ochoa J, Millum J, Grady C, Taylor HA. (2020). COVID-19 vaccine trial ethics once we have efficacious vaccines. Science.
11 Roush SW, Murphy TV, Vaccine-Preventable Disease Table Working Group, the. (2018). Historical Comparisons of Morbidity and Mortality for Vaccine-Preventable Diseases in the United States. JAMA. 2007;298(18):2155-2163. 12. Verhees RAF, Dondorp W, Thijs C, Dinant GJ, Knottnerus JA. Influenza vaccination in the elderly: Is a trial on mortality ethically acceptable?. Vaccine.
13 Flannery B, Reynolds SB, Blanton L, et al. Influenza Vaccine Effectiveness Against Pediatric Deaths: 2010–2014. 2017;139(5):e20164244.
14 Rolfes MA, Flannery B, Chung JR, et al. (2019). Effects of Influenza Vaccination in the United States During the 2017-2018 Influenza Season. Clinical infectious diseases : an official publication of the Infectious Diseases Society of America.

## Pfizer Decision Memorandum - May 2021 - References

1 FDA. Emergency Use Authorization Review Memorandum for the Pfizer-BioNTech COVID-19 Vaccine/ BNT162b2. December 11, 2020. https://www.fda.gov/media/144416/download
2 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trends dailytrendscases and CDC communication
3 Poline J, Gaschignard J, Leblanc C, et al. (2020). Systematic SARS-CoV-2 screening at hospital admission in children: a French prospective multicenter study. Clin Infect Dis.
4 Thompson MG, Burgess JL, Naleway AL, et al. (2021). Interim Estimates of Vaccine Effectiveness of BNT162b2 and mRNA-1273 COVID-19 Vaccines in Preventing SARS-CoV-2 Infection Among Health Care Personnel, First Responders, and Other Essential and Frontline Workers - Eight U.S. Locations, December 2020-March 2021. MMWR.
5 Viner RM, Mytton OT, Bonell C, et al. (2021). Susceptibility to SARS-CoV-2 Infection Among Children and Adolescents Compared With Adults: A Systematic Review and Meta-analysis. JAMA Pediatr.
6 Leidman E, Duca LM, Omura JD, et al. (2021). COVID-19 Trends Among Persons Aged 0-24 Years - United States, March 1-December 12, 2020. MMWR.
7 Sargent TH, Muller WJ, Zheng X, et al. (2020). Age-Related Differences in Nasopharyngeal Severe Acute Respiratory Syndrome Coronavirus 2 (SARS-CoV-2) Levels in Patients With Mild to Moderate Coronavirus Disease 2019 (COVID-19). JAMA Pediatrics.
8 Yonker LM, Neilan AM, Bartsch Y, et al. (2020). Pediatric Severe Acute Respiratory Syndrome Coronavirus 2 (SARS-CoV-2): Clinical Presentation, Infectivity, and Immune Responses. J Pediatr.
9 Centers for Disease Control and Prevention. Science Brief: Transmission of SARS-CoV-2 in K-12 schools. Updated March 19, 2021. https://www.cdc.gov/coronavirus/2019-ncov/science/science-briefs/transmission k 12 schools.html#sars-cov-2
10 Goldstein E, Lipsitch M, Cevik M. (2021). On the Effect of Age on the Transmission of SARS-CoV-2 in Households, Schools, and the Community. J Infect Dis.
11 Larosa E, Djuric O, Cassinadri M, et al. (2020). Secondary transmission of COVID-19 in preschool and school settings in northern Italy after their reopening in September 2020: a population-based study. Euro Surveill.
12 Kim L, Whitaker M, O’Halloran A, et al. (2020). Hospitalization Rates and Characteristics of Children Aged <18 Years Hospitalized with Laboratory-Confirmed COVID-19 – COVID-NET, 14 States, March 1-July 25, 2020. MMWR.
13 Centers For Disease Control and Prevention. Information for Healthcare Providers about Multisystem Inflammatory Syndrome in Children (MIS-C). February 17, 2021. https://www.cdc.gov/mis-c/hcp/
14 Centers for Disease Control and Prevention. Health Department-Reported Cases of Multisystem Inflammatory Syndrome in Children (MIS-C) in the United States. April 1, 2021. https://www.cdc.gov/mis-c/cases/index.html
15 Racine N, Cooke JE, Eirich R, Korczak DJ, McArthur B, Madigan S. (2020). Child and adolescent mental illness during COVID-19: A rapid review. Psychiatry Res.
16 Magson NR, Freeman JYA, Rapee RM, Richardson CE, Oar EL, Fardouly J. (2021). Risk and Protective Factors for Prospective Changes in Adolescent Mental Health during the COVID-19 Pandemic. J Youth Adolesc.
17 Hill RM, Rufino K, Kurian S, et al. (2021). Suicide Ideation and Attempts in a Pediatric Emergency Department Before and During COVID-19. Pediatrics.
18 Thompson MG, Burgess JL, Naleway AL, et al. (2021). Interim Estimates of Vaccine Effectiveness of BNT162b2 and mRNA-1273 COVID-19 Vaccines in Preventing SARS-CoV-2 Infection Among Health Care Personnel, First Responders, and Other Essential and Frontline Workers - Eight U.S. Locations, December 2020-March 2021. MMWR.
19 Dagan N, Barda N, Kepten E, et al. (2021). BNT162b2 mRNA Covid-19 Vaccine in a Nationwide Mass Vaccination Setting. N Engl J Med.
20 FDA. Emergency Use Authorization 091 casirivimab and imdevimab. February 25, 2021. https://www.fda.gov/media/145610/download
21 FDA. Emergency Use Authorization 094 bamlanivimab and etesevimab. February 25, 2021. https://www.fda.gov/media/145801/download
22 Centers for Disease Control and Prevention, 2021, COVID-19 Breakthrough Case Investigations and Reporting. accessed May 4,2021. https://www.cdc.gov/vaccines/covid-19/health-departments/breakthrough-cases.html
23 Federal Food, Drug and Cosmetic Act, 21 U.S.C. § 360bbb–3 and 360bbb-3b. (2011)
24 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. February 2021. https://www.fda.gov/media/142749/download
25 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/regulatory-in

## Pfizer Decision Memorandum - September 24, 2021 - References

1 FDA. Vaccine approval package: COMIRNATY (COVID-19 Vaccine, mRNA) (Application No 125742). August 23, 2021. https://www.fda.gov/media/151733/download
2 FDA. Vaccines and Related Biological Products Advisory Committee September 17, 2021 Meeting. Event materials available at https://www.fda.gov/advisory-committees/advisory-committeecalendar/vaccines-and-related-biological-products-advisory-committee-september-17-2021-meetingannouncement#event-materials
3 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/media/139638/download
4 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. February 2021. https://www.fda.gov/media/142749/download

## Pfizer Decision Memorandum - October 29, 2021 - References

1 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Arch Dis Child.
2 Liguoro I., Pilotto C., Bonanni M., et al. (2020). SARS-COV-2 infection in children and newborns: a systematic review. Eur J Pediatr.
3 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Arch Dis Child.
4 Assaker R, Colas A-E, Julien-Marsollier F, et al. (2020). Presenting Symptoms of COVID-19 in Children: A Meta-Analysis of Published Studies. Br J Anaesth.
5 Poline J, Gaschignard J, Leblanc C, et al. (2020). Systematic Severe Acute Respiratory Syndrome Coronavirus 2 Screening at Hospital Admission in Children: A French Prospective Multicenter Study. Clin Infect Dis.
6 Office of National Statistics. Updated estimates of the prevalence of ongoing symptoms following coronavirus (COVID-19) infection in the UK. https://www.ons.gov.uk/peoplepopulationandcommunity/healthandsocialcare/conditionsanddiseases/datasets/alldatarelatingtoprevalenceofongoingsymptomsfollowingcoronaviruscovid19infectionintheuk. Accessed October 9, 2021.
7 Johns Hopkins Coronavirus Resource Center (website) https://coronavirus.jhu.edu/, Accessed October 17, 2021.
8 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trends_dailytrendscases, Accessed October 17, 2021.
9 Link-Gelles, Ruth, COVID-19 Vaccine Effectiveness in the United States, the US CDC ACIP Meeting September 22, 2021. Retrieved from: https://www.cdc.gov/vaccines/acip/meetings/downloads/slides2021-09-22/04-COVID-Link-Gelles-508.pdf retrieved on October 15, 2021.Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-datatracker/#demographics. Accessed October 17, 2021.
10 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics. Accessed October 17, 2021.
11 Centers for Disease Control and Prevention. COVID Data Tracker (website) https://covid.cdc.gov/coviddata-tracker/#variant-proportions. Accessed September 26, 2021.
12 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#nowcasting. Accessed October 9, 2021.
13 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trends_dailytrendscases and CDC communication
14 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics. Accessed October 17. 2021.
15 Centers for Disease Control and Prevention. COVID Data Tracker (website).Counts of Hospitalizations by Age from the COVID-NET Network (data downloaded on October 17, 2021. https://covid.cdc.gov/covid-data-tracker/#covidnet-hospitalization-network. Accessed October 9, 2021.
16 Centers for Disease Control and Prevention. COVID Data Tracker (website) https://covid.cdc.gov/coviddata-tracker/#demographics. Accessed October 17, 2021. 17Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#pediatric-data. Accessed October 9, 2021.
18 Kim L, et al. (2020). Hospitalization Rates and Characteristics of Children Aged<18 Years Hospitalized with Laboratory-Confirmed COVID-19 - COVID-NET, 14 States, March 1-July 25, 2020. MMWR.
19 McCormick DW, Richardson LC, Young PR, et al. Deaths in children and adolescents associated with COVID-19 and MIS-C in the United States. Pediatrics. 2021; (preprint) doi: 10.1542/peds.2021-052273
20 (2021). Diagnosis-wide analysis of COVID-19 complications: an exposure-crossover study William Murk, Monica Gierada, Michael Fralick, Andrew Weckstein, Reyna Klesh, Jeremy A. Rassen CMAJ.
21 Daugherty S E, Guo Y, Heath K, Dasmari Ã. (2021). Risk of clinical sequelae after the acute phase of SARS-CoV-2 infection: retrospective cohort study. BMJ.
22 Boehmer, TK et al. Association Between COVID-19 and Myocarditis Using Hospital-Based Administrative Data — United States, March 2020–January 2021 MMWR September 3, 2021.70(35);1228–1232
23 Dufort EM, et al. (2020). COVID-19: Multisystem inflammatory syndrome in children (MIS-C) clinical features, evaluation, and diagnosis. N Engl J Med.
24 Centers for Disease Control and Prevention. Information for Healthcare Providers about Multisystem Inflammatory Syndrome in Children (MIS-C). May 20, 2021. https://www.cdc.gov/mis-c/hcp/
25 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website). https://covid.cdc.gov/covid-data-tracker/#mis-national-surveillance Graph - Daily MIS-C Cases and COVID-19 Cases Reported to CDC. Accessed October 17, 2021.
26 Dufort EM, et al. (2020). Multisystem Inflammatory Syndrome in Children in New York State. N Engl J Med.
27 Centers for Disease Control and Prevention. Health Department-Reported Cases of Multisystem Inflammatory Syndrome in Children (MIS-C) in the United States. October 17, 2021. https://covid.cdc.gov/covid-data-tracker/#mis-national-surveillance
28 Feldstein, et al. (2021). Characteristics and Outcomes of US Children and Adolescents with Mulitsystem Inflammatory Syndrome in Children (MIS-C) Compared with Severe Acute COVID-19. JAMA.
29 Farooqi, et al. (2021). Longitudinal Outcomes for Multisystem Inflammatory Syndrome in Children. Pediatrics.
30 Farooqi 2021.
31 Viner RM, Mytton OT, Bonell C, et al. (2021). Susceptibility to SARS-CoV-2 Infection Among Children and Adolescents Compared With Adults: A Systematic Review and Meta-analysis. JAMA Pediatr.
32 Leidman E, Duca LM, Omura JD, et al. (2021). COVID-19 Trends Among Persons Aged 0-24 Years - United States, March 1-December 12, 2020. MMWR.
33 Sargent TH, Muller WJ, Zheng X, et al. (2020). Age-Related Differences in Nasopharyngeal Severe Acute Respiratory Syndrome Coronavirus 2 (SARS-CoV-2) Levels in Patients With Mild to Moderate Coronavirus Disease 2019 (COVID-19). JAMA Pediatrics.
34 Yonker LM, Neilan AM, Bartsch Y, et al. (2020). Pediatric Severe Acute Respiratory Syndrome Coronavirus 2 (SARS-CoV-2): Clinical Presentation, Infectivity, and Immune Responses. J Pediatr.
35 Chu VT, Yousaf AR, Chang K, et al. Household Transmission of SARS-CoV-2 from Children and Adolescents. N Engl J Med. 2021;NEJMc2031915.
36 Centers for Disease control and prevention. Science Brief: Transmission of SARS-CoV-2 in K-12 schools. https://www.cdc.gov/coronavirus/2019-ncov/science/sciencebriefs/transmission_k_12_schools.html. Accessed October 17, 2021.
37 Ismail SA, Saliba V, Lopez Bernal J, et al. (2021). SARS-CoV-2 infection and transmission in educational settings: a prospective, cross-sectional analysis of infection clusters and outbreaks in England. Lancet Infect Dis.
38 Goldstein E, Lipsitch M, Cevik M. (2021). On the Effect of Age on the Transmission of SARS-CoV-2 in Households, Schools, and the Community. J Infect Dis.
39 Larosa E, Djuric O, Cassinadri M, et al. (2020). Secondary transmission of COVID-19 in preschool and school settings in northern Italy after their reopening in September 2020: a population-based study. Euro Surveill.
40 Tonzel JL, Sokol T. (2021). COVID-19 Outbreaks at Youth Summer Camps — Louisiana, June–July 2021. MMWR.
41 Szablewski CM, Chang KT, Brown MM, et al. (2020). SARS-CoV-2 transmission and infection among attendees of an overnight camp—Georgia, June 2020. MMWR.
42 Gee J, Marquez P, Su J, et al. (2021). First Month of COVID-19 Vaccine Safety Monitoring — United States, December 14, 2020–January 13, 2021. MMWR Morb Mortal Wkly Rep.
43 CDC. (2021). COVID-19 Response Team et al. Allergic Reactions Including Anaphylaxis After Receipt of the First Dose of Pfizer-BioNTech COVID-19 Vaccine — United States, December 14–23, 2020. MMWR Morb Mortal Wkly Rep.
44 FDA. Vaccine approval package: COMIRNATY (COVID-19 Vaccine, mRNA) (Application No 125742). August 23, 2021. https://www.fda.gov/media/151733/download
45 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. February 2021. https://www.fda.gov/media/142749/download
46 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/development-andlicensure-vaccines-prevent-covid-19
47 Kim L, Whitaker M, O'Halloran A, et al. (2020). Hospitalization Rates and Characteristics of Children Aged<18 Years Hospitalized with Laboratory-Confirmed COVID-19 - COVID-NET, 14 States, March 1-July 25, 2020. MMWR Morb Mortal Wkly Rep.
48 Link-Gelles, R. COVID-19 Vaccine Effectiveness in the United States, the US CDC ACIP Meeting September 22, 2021. https://www.cdc.gov/vaccines/acip/meetings/downloads/slides-2021-09-22/04- COVID-Link-Gelles-508.pdf Accessed October 15, 2021.
49 Klein, N. Rapid Cycle Analysis to Monitor the Safety of COVID-19 Vaccines in Near Real-Time within the Vaccine Safety Datalink: Myocarditis and Anaphylaxis, the US CDC ACIP Meeting August 30, 2021. https://www.cdc.gov/vaccines/acip/meetings/downloads/slides-2021-08-30/04-COVID-Klein-508.pdf Accessed October 20, 2021.

## Pfizer Decision Memorandum – May 17, 2022 - References

1 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Arch Dis Child.
2 Liguoro I, Pilotto C, Bonanni M, et al. (2020). SARS-COV-2 infection in children and newborns: a systematic review. Eur J Pediatr.
3 Irfan 2021.
4 Assaker R, Colas A-E, Julien-Marsollier F, et al. (2020). Presenting Symptoms of COVID-19 in Children: A Meta-Analysis of Published Studies. Br J Anaesth.
5 Poline J, Gaschignard J, Leblanc C, et al. (2021). Systematic Severe Acute Respiratory Syndrome Coronavirus 2 Screening at Hospital Admission in Children: A French Prospective Multicenter Study. Clin Infect Dis.
6 Office of National Statistics. Updated estimates of the prevalence of ongoing symptoms following coronavirus (COVID-19) infection in the UK. https://www.ons.gov.uk/peoplepopulationandcommunity/healthandsocialcare/conditionsanddiseases/d atasets/alldatarelatingtoprevalenceofongoingsymptomsfollowingcoronaviruscovid19infectionintheuk Accessed April 1, 2022.
7 Johns Hopkins Coronavirus Resource Center (website) https://coronavirus.jhu.edu/ Accessed April 1, 2022. 8 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trends dailytrendscases Accessed April 1, 2022.
9 Centers for Disease Control and Prevention. COVID-19 Vaccine Effectiveness in Children and Adults. Presented at the meeting of the Advisory Committee on Immunization Practices, September 22, 2021. https://www.cdc.gov/vaccines/acip/meetings/downloads/slides-2021-09-22/04-COVID-Link-Gelles508.pdf
10 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics Accessed April 1, 2022.
11 Centers for Disease Control and Prevention. COVID Data Tracker (website) https://covid.cdc.gov/coviddata-tracker/#variant-proportions Accessed April 1, 2022.
12 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#nowcasting Accessed April 1, 2022.
13 Centers for Disease Control and Prevention. COVID Data Tracker (website).Counts of Hospitalizations by Age from the COVID-NET Network (data downloaded on April 1, 2022. https://covid.cdc.gov/coviddata-tracker/#covidnet-hospitalization-network Accessed April 1, 2022.
14 Centers for Disease Control and Prevention. COVID Data Tracker (website) https://covid.cdc.gov/coviddata-tracker/#demographics Accessed April 1, 2022.
15 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#pediatric-data Accessed April 1, 2022.
16 Kim L, Whitaker M, O'Halloran A, et al. (2020). Hospitalization Rates and Characteristics of Children Aged<18 Years Hospitalized with Laboratory-Confirmed COVID-19 -COVID-NET, 14 States, March 1-July 25, 2020. MMWR Morb Mortal Wkly Rep.
17 McCormick DW, Richardson LC, Young PR, et al. (2021). Deaths in Children and Adolescents Associated With COVID-19 and MIS-C in the United States. Pediatrics.
18 Murk W, Gierada M, Fralick M, Weckstein A, Klesh R, Rassen JA. (2021). Diagnosis-wide analysis of COVID19 complications: an exposure-crossover study. CMAJ.
19 Daugherty SE, Guo Y, Heath K, et al. Risk of clinical sequelae after the acute phase of SARS-CoV-2 infection: retrospective cohort study. BMJ. 2021;373:n1098. Published 2021 May 19.
20 Dufort EM, et al. (2020). COVID-19: Multisystem inflammatory syndrome in children (MIS-C) clinical features, evaluation, and diagnosis. N Engl J Med.
21 Centers for Disease Control and Prevention. Health Department-Reported Cases of Multisystem Inflammatory Syndrome in Children (MIS-C) in the United States. October 17, 2021. https://covid.cdc.gov/covid-data-tracker/#mis-national-surveillance
22 Feldstein, et al. (2021). Characteristics and Outcomes of US Children and Adolescents with Mulitsystem Inflammatory Syndrome in Children (MIS-C) Compared with Severe Acute COVID-19. JAMA.
23 Farooqi KM, Chan A, Weller RJ, et al. (2021). Longitudinal Outcomes for Multisystem Inflammatory Syndrome in Children. Pediatrics.
24 Farooqi 2021.
25 FDA. Janssen COVID-19 Vaccine (webpage). https://www.fda.gov/emergency-preparedness-andresponse/coronavirus-disease-2019-covid-19/janssen-covid-19-vaccine Accessed May 10, 2022.
26 Shi DS, Whitaker M, Marks KJ, et al. (2022). Hospitalizations of Children Aged 5–11 Years with LaboratoryConfirmed COVID-19 — COVID-NET, 14 States, March 2020–February 2022. MMWR Morb Mortal Wkly Rep.
27 Klein NP, Stockwell MS, Demarco M, et al. (2022). Effectiveness of COVID-19 Pfizer-BioNTech BNT162b2 mRNA Vaccination in Preventing COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Nonimmunocompromised Children and Adolescents Aged 5– 17 Years — VISION Network, 10 States, April 2021–January 2022. MMWR Morb Mortal Wkly Rep.
28 Centers for Disease Control and Prevention. COVID-19 Vaccine Effectiveness in Children and Adults. Presented at a meeting of the Vaccines and Related Biological Products Advisory Committee, April 6, 2022. https://www.fda.gov/media/157475/download
29 Fleming-Dutra KE, Britton A, Shang N, et al. (2022). Association of Prior BNT162b2 COVID-19 Vaccination With Symptomatic SARS-CoV-2 Infection in Children and Adolescents During Omicron Predominance. JAMA.
30 FDA. Emergency Use Authorization Amendment Review Memorandum for the Pfizer-BioNTech COVID-19 Vaccine/ BNT162b2 in individuals 5 through 11 years of age. October 29, 2021. https://www.fda.gov/media/153947/download
31 Kim 2020.
32 FDA. Emergency Use Authorization Amendment Review Memorandum for the Pfizer-BioNTech COVID-19 Vaccine/ BNT162b2 in individuals 5 through 11 years of age. October 29, 2021. https://www.fda.gov/media/153947/download
33 Gee J, Marquez P, Su J, et al. (2021). First Month of COVID-19 Vaccine Safety Monitoring — United States, December 14, 2020–January 13, 2021. MMWR Morb Mortal Wkly Rep.
34 Allergic Reactions Including Anaphylaxis After Receipt of the First Dose of Pfizer-BioNTech COVID-19 Vaccine — United States. (2021). December 14–23, 2020. MMWR Morb Mortal Wkly Rep.
35 McNeil MM, Weintraub ES, Duffy J, et al. (2016). Risk of anaphylaxis after vaccination in children and adults. J Allergy Clin Immunol.
36 CDC Advisory Committee on Immunization Practices, Updates on safety of COVID-19 primary series in children and adolescents ages 5–11 and 12–15 years, and booster doses in adolescents ages 16–24 (slide presentation). January 5, 2022. https://www.cdc.gov/vaccines/acip/meetings/downloads/slides2022-01-05/02-COVID-Su-508.pdf Accessed May 10, 2022
37 CDC Advisory Committee on Immunization Practices, Updates on safety of COVID-19 booster dose (slide presentation). April 20, 2022. https://www.cdc.gov/vaccines/acip/meetings/downloads/slides2022-04-20/03-COVID-Klein-Shimabukuro-508.pdf Accessed May 10, 2022.
38 Thompson MG, Natarajan K, Irving SA, et al. (2022). Effectiveness of a Third Dose of mRNA Vaccines Against COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep.
39 Klein 2022.
40 Hause AM, Baggs J, Marquez P, et al. (2021). COVID-19 Vaccine Safety in Children Aged 5–11 Years — United States, November 3–December 19, 2021. MMWR Morb Mortal Wkly Rep.
41 Oster ME, Shay DK, Su JR, et al. (2022). Myocarditis Cases Reported After mRNA-Based COVID-19 Vaccination in the US From December 2020 to August 2021. JAMA.

## Pfizer Decision Memorandum – June 17, 2022 - References

1 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Arch Dis Child.
2 Liguoro I, Pilotto C, Bonanni M, et al. (2020). SARS-COV-2 infection in children and newborns: a systematic review. Eur J Pediatr.
3 Irfan 2021.
4 Assaker R, Colas A-E, Julien-Marsollier F, et al. (2020). Presenting Symptoms of COVID-19 in Children: A Meta-Analysis of Published Studies. Br J Anaesth.
5 Poline J, Gaschignard J, Leblanc C, et al. (2021). Systematic Severe Acute Respiratory Syndrome Coronavirus 2 Screening at Hospital Admission in Children: A French Prospective Multicenter Study. Clin Infect Dis.
6 Office of National Statistics. Updated estimates of the prevalence of ongoing symptoms following coronavirus (COVID-19) infection in the UK. https://www.ons.gov.uk/peoplepopulationandcommunity/healthandsocialcare/conditionsanddiseases/d atasets/alldatarelatingtoprevalenceofongoingsymptomsfollowingcoronaviruscovid19infectionintheuk Accessed April 1, 2022.
7 Johns Hopkins Coronavirus Resource Center (website) https://coronavirus.jhu.edu/ Accessed June 8, 2022.
8 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trends dailytrendscases Accessed June 8, 2022.
9 Centers for Disease Control and Prevention. COVID-19 Vaccine Effectiveness in Children and Adults. Presented at the meeting of the Advisory Committee on Immunization Practices, September 22, 2021. https://www.cdc.gov/vaccines/acip/meetings/downloads/slides-2021-09-22/04-COVID-Link-Gelles508.pdf
10 Centers for Disease Control and Prevention. COVID Data Tracker (website) https://covid.cdc.gov/coviddata-tracker/#variant-proportions Accessed June 8, 2022.
11 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics Accessed June 8, 2022.
12 National Center for Health Statistics. Provisional COVID-19 Death Counts by Age in Years (website). https://data.cdc.gov/NCHS/Provisional-COVID-19-Deaths-Counts-by-Age-in-Years/3apk-4u4f/data Accessed May 14, 2022.
13 Centers for Disease Control and Prevention. COVID Data Tracker (website).Counts of Hospitalizations by Age from the COVID-NET Network (data downloaded on June 8, 2022. https://covid.cdc.gov/coviddata-tracker/#covidnet-hospitalization-network Accessed June 8, 2022.
14 Centers for Disease Control and Prevention. COVID Data Tracker (website).Counts of Hospitalizations by Age from the COVID-NET Network (data downloaded on June 8, 2022. https://covid.cdc.gov/coviddata-tracker/#covidnet-hospitalization-network Accessed June 8, 2022.
15 Centers for Disease Control and Prevention. COVID Data Tracker (website).Counts of Hospitalizations by Age from the COVID-NET Network (data downloaded on June 8, 2022. https://covid.cdc.gov/coviddata-tracker/#covidnet-hospitalization-network Accessed June 8, 2022.
16 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#pediatric-data Accessed June 8, 2022.
17 Kim L, Whitaker M, O'Halloran A, et al. (2020). Hospitalization Rates and Characteristics of Children Aged< 18 Years Hospitalized with Laboratory-Confirmed COVID-19 -COVID-NET, 14 States, March 1-July 25, 2020. MMWR Morb Mortal Wkly Rep.
18 McCormick DW, Richardson LC, Young PR, et al. (2021). Deaths in Children and Adolescents Associated With COVID-19 and MIS-C in the United States. Pediatrics.
19 Office for National Statistics United Kingdom. Prevalence of ongoing symptoms following coronavirus (COVID-19) infection in the UK: 1 April 2021. Accessed September 17, 2021. https://www.ons.gov.uk/peoplepopulationandcommunity/healthandsocialcare/conditionsanddiseases/b ulletins/prevalenceofongoingsymptomsfollowingcoronaviruscovid19infectionintheuk/1april2021
20 Murk W, Gierada M, Fralick M, Weckstein A, Klesh R, Rassen JA. (2021). Diagnosis-wide analysis of COVID19 complications: an exposure-crossover study. CMAJ.
21 Daugherty SE, Guo Y, Heath K, et al. Risk of clinical sequelae after the acute phase of SARS-CoV-2 infection: retrospective cohort study. BMJ. 2021;373:n1098. Published 2021 May 19.
22 Dufort EM, et al. (2020). COVID-19: Multisystem inflammatory syndrome in children (MIS-C) clinical features, evaluation, and diagnosis. N Engl J Med.
23 Feldstein LR, Tenforde MW, Friedman KG, et al. (2021). Characteristics and Outcomes of US Children and Adolescents With Multisystem Inflammatory Syndrome in Children (MIS-C) Compared With Severe Acute COVID-19. JAMA.
24 Belay ED, Abrams J, Oster ME, et al. (2021). Trends in Geographic and Temporal Distribution of US Children With Multisystem Inflammatory Syndrome During the COVID-19 Pandemic. JAMA Pediatr.
25 Miller AD, Zambrano LD, Yousaf AR, et al. Multisystem Inflammatory Syndrome in Children-United States, February 2020-July 2021 [published online ahead of print, 2021 Dec 5] [published correction appears in Clin Infect Dis. 2022 Apr 27;:]. Clin Infect Dis. 2021;ciab1007. 26 Centers for Disease Control and Prevention. Health Department-Reported Cases of Multisystem Inflammatory Syndrome in Children (MIS-C) in the United States. October 17, 2021. https://covid.cdc.gov/covid-data-tracker/#mis-national-surveillance
27 Feldstein, et al. (2021). Characteristics and Outcomes of US Children and Adolescents with Mulitsystem Inflammatory Syndrome in Children (MIS-C) Compared with Severe Acute COVID-19. JAMA.
28 Farooqi KM, Chan A, Weller RJ, et al. (2021). Longitudinal Outcomes for Multisystem Inflammatory Syndrome in Children. Pediatrics.
29 Farooqi 2021.
30 Shi DS, Whitaker M, Marks KJ, et al. (2022). Hospitalizations of Children Aged 5–11 Years with LaboratoryConfirmed COVID-19 — COVID-NET, 14 States, March 2020–February 2022. MMWR Morb Mortal Wkly Rep.
31 Klein NP, Stockwell MS, Demarco M, et al. (2022). Effectiveness of COVID-19 Pfizer-BioNTech BNT162b2 mRNA Vaccination in Preventing COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Nonimmunocompromised Children and Adolescents Aged 5– 17 Years — VISION Network, 10 States, April 2021–January 2022. MMWR Morb Mortal Wkly Rep.
32 Andrews N, Stowe J, Kirsebom F, et al. (2022). Covid-19 Vaccine Effectiveness against the Omicron (B.1.1.529) Variant. N Engl J Med.
33 Lauring AS, Tenforde MW, Chappell JD, et al. Clinical severity of, and effectiveness of mRNA vaccines against, covid-19 from omicron, delta, and alpha SARS-CoV-2 variants in the United States: prospective observational study. BMJ. 2022;376:e069761. Published 2022 Mar 9.
34 Fleming-Dutra KE, Britton A, Shang N, et al. (2022). Association of Prior BNT162b2 COVID-19 Vaccination With Symptomatic SARS-CoV-2 Infection in Children and Adolescents During Omicron Predominance. JAMA.
35 Lauring AS 2022.
36 Thompson MG, et al. Effectiveness of a third dose of mRNA vaccines against COVID-19–associated emergency department and urgent care encounters and hospitalizations among adults during periods of Delta and Omicron variant predominance—VISION Network, 10 States, August 2021–January 2022. 2022.
37 Price AM, et al. (2022). BNT162b2 protection against the omicron variant in children and adolescents. New England Journal of Medicine.
38 Thompson MG 2021.
39 Tartof SY, et al. (2022). Durability of BNT162b2 vaccine against hospital and emergency department admissions due to the omicron and delta variants in a large health system in the USA: a test-negative case–control study. The Lancet Respiratory Medicine.
40 Fleming-Dutra KE 2022.
41 Center for Disease Control and Prevention. COVID Data Tracker (website). https://covid.cdc.gov/coviddata-tracker/#vaccinations vacc-total-admin-rate-total Accessed on May 19, 2022
42 Gee J, Marquez P, Su J, et al. (2021). First Month of COVID-19 Vaccine Safety Monitoring — United States, December 14, 2020–January 13, 2021. MMWR Morb Mortal Wkly Rep.
43 Allergic Reactions Including Anaphylaxis After Receipt of the First Dose of Pfizer-BioNTech COVID-19 Vaccine — United States. (2021). December 14–23, 2020. MMWR Morb Mortal Wkly Rep.
44 McNeil MM, Weintraub ES, Duffy J, et al. (2016). Risk of anaphylaxis after vaccination in children and adults. J Allergy Clin Immunol.
45 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. March 2022. https://www.fda.gov/media/142749/download
46 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/development-andlicensure-vaccines-prevent-covid-19
47 Kim L, Whitaker M, O'Halloran A, et al. Hospitalization Rates and Characteristics of Children Aged
48 Centers for Disease Control and Prevention. BMI Percentile Calculator for Child and Teen. https://www.cdc.gov/healthyweight/bmi/calculator.html Accessed February 2, 2022.
49 FDA. Emergency Use Authorization Amendment Review Memorandum for the Pfizer-BioNTech COVID-19 Vaccine/ BNT162b2 in individuals 5 through 11 years of age. October 29, 2021. https://www.fda.gov/media/153947/download
50 FDA. Emergency Use Authorization Amendment Review Memorandum for the Pfizer-BioNTech COVID-19 Vaccine/ BNT162b2 in individuals 5 through 11 years of age. October 29, 2021. https://www.fda.gov/media/153947/download
51 UK Health Security Agency. COVID-19 vaccine surveillance report – Week 19, 12 May 2022. Available at: https://assets.publishing.service.gov.uk/government/uploads/system/uploads/attachment data/file/107 5115/COVID-19 vaccine surveillance report 12 May 2022 week 19.pdf. Accessed June 7, 2022.
52 Fleming-Dutra KE, et al. (2022). Association of Prior BNT162b2 COVID-19 Vaccination With Symptomatic SARS-CoV-2 Infection in Children and Adolescents During Omicron Predominance. JAMA.
53 Centers for Disease Control and Prevention. COVID Data Tracker. 2022, June 13. https://covid.cdc.gov/covid-data-tracker. Accessed June 13, 2022.
54 Carazo S, et al. (2022). Protection against Omicron re-infection conferred by prior heterologous SARSCoV-2 infection, with and without mRNA vaccination. medRxiv.
55 Smid M, et al. (2022). Protection by vaccines and previous infection against the Omicron variant of SARS-CoV2. medRxiv.
56 Vasudeva Rhythm, et al. (2021). Trends in acute myocarditis related pediatric hospitalizations in the United States, 2007–2016. The American Journal of Cardiology.
57 FDA. BLA Clinical Review Memorandum (approval memo) of Comirnaty for use in individuals 16 years of age and older. August 23, 2021. https://www.fda.gov/media/152256/download
58 Centers for Disease Control and Prevention. COVID Data Tracker (website). https://covid.cdc.gov/covid-data-tracker/#rates-by-vaccine-status
59 Plumb ID, Feldstein LR, Barkley E, et al. (2022). Effectiveness of COVID-19 mRNA Vaccination in Preventing COVID-19–Associated Hospitalization Among Adults with Previous SARS-CoV-2 Infection — United States, June 2021–February 2022. Morb Mortal Wkly Rep.

## Pfizer Decision Memorandum – August 31, 2022 - References

1 Johns Hopkins Coronavirus Resource Center (website) https://coronavirus.jhu.edu/ Accessed August 26, 2022
2 Centers for Disease Control and Prevention, 2022. Underlying Medical Conditions Associated with Higher Risk for Severe COVID-19: Information for Healthcare Professionals. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/underlyingconditions.html Accessed August 26, 2022.
3 Centers for Disease Control and Prevention, 2021. Post-COVID Conditions: Overview for Healthcare Providers. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/post-covidconditions.html Accessed August 26, 2022.
4 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2020). Eur J Pediatr.
6 Assaker R, Colas AE, Julien-Marsollier F, et al. (2020). Presenting symptoms of COVID-19 in children: a metaanalysis of published studies. Br J Anaesth.
7 Poline J, Gaschignard J, Leblanc C, et al. (2021). Systematic Severe Acute Respiratory Syndrome Coronavirus 2 Screening at Hospital Admission in Children: A French Prospective Multicenter Study. Clin Infect Dis.
8 Johns Hopkins Coronavirus Resource Center (website) https://coronavirus.jhu.edu/ Accessed August 26, 2022
9 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trends dailytrendscases Accessed August 26, 2022.
10 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics Accessed August 26, 2022.
11 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#nowcast-heading Accessed August 26, 2022.
12 Pulliam JRC, van Schalkwyk C, Govender N, et al. (2022). Increased risk of SARS-CoV-2 reinfection associated with emergence of Omicron in South Africa. Science.
13 Tseng HF, Ackerson BK, Luo Y, et al. (2022). Effectiveness of mRNA-1273 against SARS-CoV-2 Omicron and Delta variants. Nat Med.
14 Andrews N, Stowe J, Kirsebom F, et al. (2022). Covid-19 Vaccine Effectiveness against the Omicron (B.1.1.529) Variant. N Engl J Med.
15 Taylor CA, Whitaker M, Anglin O, et al. (2022). COVID-19–Associated Hospitalizations Among Adults During SARS-CoV-2 Delta and Omicron Variant Predominance, by Race/Ethnicity and Vaccination Status — COVID-NET, 14 States, July 2021–January 2022. MMWR Morb Mortal Wkly Rep.
16 Korves C, Izurieta HS, Smith J, et al. (2022). Relative effectiveness of booster vs. 2-dose mRNA Covid-19 vaccination in the Veterans Health Administration: Self-controlled risk interval analysis. Vaccine.
17 Stowe J, Andrews N, Kirsebom F, Ramsay M, Bernal JL. (2022). Effectiveness of COVID-19 vaccines against Omicron and Delta hospitalisation: test negative case-control study. medRxiv.
18 Ferdinands JM, Rao S, Dixon BE, et al. (2022). Waning 2-Dose and 3-Dose Effectiveness of mRNA Vaccines Against COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep.
19 Chemaitelly H, Ayoub HH, AlMukdad S, et al. Duration of mRNA vaccine protection against SARSCoV-2 Omicron BA.1 and BA.2 subvariants in Qatar. Nat Commun. 2022;13(1):3082. Published 2022 Jun 2.
20 Tenforde MW, Patel MM, Gaglani M, et al. (2022). Effectiveness of a Third Dose of Pfizer-BioNTech and Moderna Vaccines in Preventing COVID-19 Hospitalization Among Immunocompetent and Immunocompromised Adults — United States, August–December 2021. MMWR Morb Mortal Wkly Rep.
21 Arbel R, Sergienko R, Friger M, et al. (2021). BNT162b2 vaccine booster and mortality due to COVID 19. N Engl J Med.
22 Bar-On YM, Goldberg Y, Mandel M, et al. (2022). Protection by a Fourth Dose of BNT162b2 against Omicron in Israel. N Engl J Med.
23 Gazit S, Saciuk Y, Perez G, et al. Relative Effectiveness of Four Doses Compared to Three Dose of the BNT162b2 Vaccine in Israel. medRxiv.
24 Atmar RL, Lyke KE, Deming ME, et al. (2022). Homologous and Heterologous Covid-19 Booster Vaccinations. N Engl J Med.
25 World Health Organization. Interim recommendations for heterologous COVID-19 vaccine schedules. December 16, 2021. https://www.who.int/publications/i/item/WHO-2019-nCoV-vaccines-SAGErecommendation-heterologous-schedules
26 Gee J, Marquez P, Su J, et al. (2021). First Month of COVID-19 Vaccine Safety Monitoring — United States, December 14, 2020–January 13, 2021. MMWR Morb Mortal Wkly Rep.
27 Allergic Reactions Including Anaphylaxis After Receipt of the First Dose of Pfizer-BioNTech COVID-19 Vaccine — United States. (2021). December 14–23, 2020. MMWR Morb Mortal Wkly Rep.
28 McNeil MM, Weintraub ES, Duffy J, et al. (2016). Risk of anaphylaxis after vaccination in children and adults. J Allergy Clin Immunol.
29 Shimabukuro, T. Myocarditis following mRNA COVID-19 vaccination; presented to the Advisory Committee on Immunization Practices on July 19, 2022. Available at: ACIP July 19, 2022 Presentation Slides | Immunization Practices | CDC; Accessed on August 23, 2022.
30 Lauring AS, Tenforde MW, Chappell JD, Gaglani M, Ginde AA, McNeal T, Ghamande S, Douin DJ, Talbot HK, Casey JD, Mohr NM. (2022). Clinical severity and mRNA vaccine effectiveness for omicron, delta, and alpha SARS-CoV-2 variants in the United States: a prospective observational study. MedRxiv.
31 Dorabawila V, Hoefer D, Bauer UE, Bassett M, Lutterloh E, Rosenberg E. (2022). Effectiveness of the BNT162b2 vaccine among children 5-11 and 12-17 years in New York after the Emergence of the Omicron Variant. medRxiv.
32 Kislaya I, Casaca P, Borges V, Sousa C, Ferreira B, Fernandes E, Dias CM, Duarte S, Almeida JP, Coelho L, Grenho I. (2022). SARS-CoV-2 BA. 5 vaccine breakthrough risk and severity compared with BA. 2: a case-case and cohort study using Electronic Health Records in Portugal. medRxiv.
33 Wong HL, Hu M, Zhou CK, et al. (2022). Risk of myocarditis and pericarditis after the COVID-19 mRNA vaccination in the USA: a cohort study in claims databases. Lancet.

## Pfizer Decision Memorandum - October 2022 – References

1 Johns Hopkins Coronavirus Resource Center (website) https://coronavirus.jhu.edu/ Accessed October 4, 2022
2 Centers for Disease Control and Prevention, 2022. Underlying Medical Conditions Associated with Higher Risk for Severe COVID-19: Information for Healthcare Professionals. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/underlyingconditions.html Accessed August 26, 2022.
3 Centers for Disease Control and Prevention, 2021. Post-COVID Conditions: Overview for Healthcare Providers. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/post-covid-conditions.html Accessed August 26, 2022.
4 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Arch Dis Child.
5 Liguoro I, Pilotto C, Bonanni M, et al. (2020). SARS-COV-2 infection in children and newborns: a systematic review. Eur J Pediatr.
6 Assaker R, Colas AE, Julien-Marsollier F, et al. (2020). Presenting symptoms of COVID-19 in children: a meta-analysis of published studies. Br J Anaesth.
7 Poline J, Gaschignard J, Leblanc C, et al. (2021). Systematic Severe Acute Respiratory Syndrome Coronavirus 2 Screening at Hospital Admission in Children: A French Prospective Multicenter Study. Clin Infect Dis.
8 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) CDC COVID Data Tracker: Daily and Total Trends (https://covid.cdc.gov/covid-data-tracker/#trends_weeklycases_select_00) Accessed October 4, 2022.
9 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics Accessed October 4, 2022.
10 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#nowcast-heading Accessed October 4, 2022. 11 Pulliam JRC, van Schalkwyk C, Govender N, et al. Increased risk of SARS-CoV-2 reinfection associated with emergence of Omicron in South Africa. Science. 2022;376(6593):eabn4947.
12 Tseng HF, Ackerson BK, Luo Y, et al. (2022). Effectiveness of mRNA-1273 against SARS-CoV-2 Omicron and Delta variants. Nat Med.
13 Andrews N, Stowe J, Kirsebom F, et al. (2022). Covid-19 Vaccine Effectiveness against the Omicron (B.1.1.529) Variant. N Engl J Med.
14 Taylor CA, Whitaker M, Anglin O, et al. (2022). COVID-19–Associated Hospitalizations Among Adults During SARS-CoV-2 Delta and Omicron Variant Predominance, by Race/Ethnicity and Vaccination Status — COVID-NET, 14 States, July 2021–January 2022. MMWR Morb Mortal Wkly Rep.
15 Korves C, Izurieta HS, Smith J, et al. (2022). Relative effectiveness of booster vs. 2-dose mRNA Covid-19 vaccination in the Veterans Health Administration: Self-controlled risk interval analysis. Vaccine.
16 Stowe J, Andrews N, Kirsebom F, Ramsay M, Bernal JL. (2022). Effectiveness of COVID-19 vaccines against Omicron and Delta hospitalisation: test negative case-control study. medRxiv.
17 Ferdinands JM, Rao S, Dixon BE, et al. (2022). Waning 2-Dose and 3-Dose Effectiveness of mRNA Vaccines Against COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep.
18 Chemaitelly H, Ayoub HH, AlMukdad S, et al. Duration of mRNA vaccine protection against SARS CoV-2 Omicron BA.1 and BA.2 subvariants in Qatar. Nat Commun. 2022;13(1):3082. Published 2022 Jun 2.
19 Tenforde MW, Patel MM, Gaglani M, et al. (2022). Effectiveness of a Third Dose of Pfizer-BioNTech and Moderna Vaccines in Preventing COVID-19 Hospitalization Among Immunocompetent and Immunocompromised Adults — United States, August–December 2021. MMWR Morb Mortal Wkly Rep.
20 Arbel R, Sergienko R, Friger M, et al. (2021). BNT162b2 vaccine booster and mortality due to COVID 19. N Engl J Med.
21 Bar-On YM, Goldberg Y, Mandel M, et al. (2022). Protection by a Fourth Dose of BNT162b2 against Omicron in Israel. N Engl J Med.
22 Gazit S, Saciuk Y, Perez G, et al. Relative Effectiveness of Four Doses Compared to Three Dose of the BNT162b2 Vaccine in Israel. medRxiv.
23 Atmar RL, Lyke KE, Deming ME, et al. (2022). Homologous and Heterologous Covid-19 Booster Vaccinations. N Engl J Med.
24 Gee J, Marquez P, Su J, et al. (2021). First Month of COVID-19 Vaccine Safety Monitoring — United States, December 14, 2020–January 13, 2021. MMWR Morb Mortal Wkly Rep.
25 Allergic Reactions Including Anaphylaxis After Receipt of the First Dose of Pfizer-BioNTech COVID-19 Vaccine — United States. (2021). December 14–23, 2020. MMWR Morb Mortal Wkly Rep.
26 McNeil MM, Weintraub ES, Duffy J, et al. (2016). Risk of anaphylaxis after vaccination in children and adults. J Allergy Clin Immunol.
27 Shimabukuro, T. Updates on vaccine-associated myocarditis; presented to the Advisory Committee on Immunization Practices on July 19, 2022. Available at: ACIP July 19, 2022 Presentation Slides | Immunization Practices | CDC; Accessed on August 23, 2022.
28 Lauring AS, Tenforde MW, Chappell JD, Gaglani M, Ginde AA, McNeal T, Ghamande S, Douin DJ, Talbot HK, Casey JD, Mohr NM. (2022). Clinical severity and mRNA vaccine effectiveness for omicron, delta, and alpha SARS-CoV-2 variants in the United States: a prospective observational study. MedRxiv.
29 Dorabawila V, Hoefer D, Bauer UE, Bassett M, Lutterloh E, Rosenberg E. (2022). Effectiveness of the BNT162b2 vaccine among children 5-11 and 12-17 years in New York after the Emergence of the Omicron Variant. medRxiv.
30 Kislaya I, Casaca P, Borges V, Sousa C, Ferreira B, Fernandes E, Dias CM, Duarte S, Almeida JP, Coelho L, Grenho I. (2022). SARS-CoV-2 BA. 5 vaccine breakthrough risk and severity compared with BA. 2: a case-case and cohort study using Electronic Health Records in Portugal. medRxiv.

## Pfizer Decision Memorandum - December 2022 – References

1 Johns Hopkins Coronavirus Resource Center (website) https://coronavirus.jhu.edu/ Accessed October 4, 2022
2 Link-Gelles R, Ciesla AA, Fleming-Dutra KE, et al. (2022). Effectiveness of Bivalent mRNA Vaccines in Preventing Symptomatic SARS-CoV-2 Infection — Increasing Community Access to Testing Program, United States, September–November 2022. MMWR Morb Mortal Wkly Rep.
3 Centers for Disease Control and Prevention, 2022. Underlying Medical Conditions Associated with Higher Risk for Severe COVID-19: Information for Healthcare Professionals. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/underlyingconditions.html Accessed August 26, 2022.
4 Centers for Disease Control and Prevention, 2021. Post-COVID Conditions: Overview for Healthcare Providers. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/post-covid-conditions.html Accessed August 26, 2022.
5 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Arch Dis Child.
6 Liguoro I, Pilotto C, Bonanni M, et al. (2020). SARS-COV-2 infection in children and newborns: a systematic review. Eur J Pediatr.
7 Assaker R, Colas AE, Julien-Marsollier F, et al. (2020). Presenting symptoms of COVID-19 in children: a metaanalysis of published studies. Br J Anaesth.
8 Poline J, Gaschignard J, Leblanc C, et al. (2021). Systematic Severe Acute Respiratory Syndrome Coronavirus 2 Screening at Hospital Admission in Children: A French Prospective Multicenter Study. Clin Infect Dis.
9 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) CDC COVID Data Tracker: Daily and Total Trends (https://covid.cdc.gov/covid-data-tracker/#trends_dailytrendscases_select_00) AccessedOctober4, 2022.
10 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics AccessedOctober4, 2022.
11 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#nowcast-heading AccessedOctober4, 2022.
12 Qu P, Evans JP, Faraone J, et al. Distinct Neutralizing Antibody Escape of SARS-CoV-2 Omicron Subvariants BQ.1, BQ.1.1, BA.4.6, BF.7 and BA.2.75.2. bioRxiv.
13 Pulliam JRC, van Schalkwyk C, Govender N, et al. (2022). Increased risk of SARS-CoV-2 reinfection associated with emergence of Omicron in South Africa. Science.
14 Tseng HF, Ackerson BK, Luo Y, et al. (2022). Effectiveness of mRNA-1273 against SARS-CoV-2 Omicron and Delta variants. Nat Med.
15 Andrews N, Stowe J, Kirsebom F, et al. (2022). Covid-19 Vaccine Effectiveness against the Omicron (B.1.1.529) Variant. N Engl J Med.
16 Taylor CA, Whitaker M, Anglin O, et al. (2022). COVID-19–Associated Hospitalizations Among Adults During SARS-CoV-2 DeltaandOmicron Variant Predominance,byRace/Ethnicityand Vaccination Status - COVID-NET, 14 States, July 2021–January 2022. MMWR Morb Mortal Wkly Rep.
17 Korves C, Izurieta HS, Smith J, et al. (2022). Relative effectiveness of booster vs. 2-dose mRNA Covid-19 vaccination inthe Veterans Health Administration: Self-controlled risk interval analysis. Vaccine.
18 Stowe J., Andrews N., Kirsebom F., et al. (2022). Effectiveness of COVID-19 vaccines against Omicron and Delta hospitalisation, a test negative case-control study. Nat Commun.
19 Ferdinands JM, Rao S, Dixon BE, et al. (2022). Waning 2-Dose and 3-Dose Effectiveness of mRNA Vaccines Against COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep.
20 Chemaitelly H, Ayoub HH, AlMukdad S, et al. Duration of mRNA vaccine protection against SARSCoV-2 Omicron BA.1 and BA.2 subvariants in Qatar. Nat Commun. 2022;13(1):3082. Published 2022 Jun 2.
21 Tenforde MW, Patel MM, Gaglani M, et al. (2022). Effectiveness of a Third Dose of Pfizer-BioNTech and Moderna Vaccines in Preventing COVID-19 Hospitalization Among Immunocompetent and Immunocompromised Adults — United States, August–December 2021. MMWR Morb Mortal Wkly Rep.
22 Arbel R, Sergienko R, Friger M, et al. (2021). BNT162b2 vaccine booster and mortality due to COVID 19. N Engl J Med.
23 Bar-On YM, Goldberg Y, Mandel M, et al. (2022). Protection by a Fourth Dose of BNT162b2 against Omicron in Israel. N Engl J Med.
24 Gazit S, Saciuk Y, Perez G, Peretz A, Pitzer V E, Patalon T, et al. (2022). Short term, relative effectiveness of four doses versus three doses of BNT162b2 vaccine in people aged 60 years and older in Israel: retrospective, test negative, case-control study. BMJ.
25 Atmar RL, Lyke KE, Deming ME, et al. (2022). Homologous and Heterologous Covid-19 Booster Vaccinations. N Engl J Med.
26 Gee J, Marquez P, Su J, et al. (2021). First Month of COVID-19 Vaccine Safety Monitoring — United States, December 14, 2020–January 13, 2021. MMWR Morb Mortal Wkly Rep.
27 Allergic Reactions Including Anaphylaxis After Receipt of the First Dose of Pfizer-BioNTech COVID-19 Vaccine — United States. (2021). December 14–23, 2020. MMWR Morb Mortal Wkly Rep.
28 McNeil MM, Weintraub ES, Duffy J, et al. (2016). Risk of anaphylaxis after vaccination in children and adults. J Allergy Clin Immunol.
29 Shimabukuro, T. Updates on vaccine-associated myocarditis; presented to the Advisory Committee on Immunization Practices on July 19, 2022. Available at: ACIP July 19, 2022 Presentation Slides | Immunization Practices | CDC; Accessed on August 23, 2022.
30 Lauring A S, Tenforde M W, Chappell J D, Gaglani M, Ginde A A, McNeal T, et al. (2022). Clinical severity of, and effectiveness of mRNA vaccines against, covid-19 from omicron, delta, and alpha SARS-CoV-2 variants in the United States: prospective observational study. BMJ.
31 Dorabawila V, Hoefer D, Bauer UE, Bassett M, Lutterloh E, Rosenberg E. (2022). Effectiveness of the BNT162b2 vaccineamong children 5-11 and 12-17 years in New York after the Emergence of the Omicron Variant. medRxiv.
32 Kislaya I, Casaca P, Borges V, Sousa C, Ferreira B, Fernandes E, Dias CM, Duarte S, Almeida JP, Coelho L, Grenho I. (2022). SARS-CoV-2 BA. 5 vaccine breakthrough risk and severity compared with BA. 2: a case-case and cohort study using Electronic Health Records in Portugal. medRxiv.

## Pfizer Decision Memorandum – March 2023 – References

1 Johns Hopkins Coronavirus Resource Center https://coronavirus.jhu.edu/ Accessed March 12, 2023
2 Centers for Disease Control and Prevention, 2022. COVID Data Tracker. COVID-19 Vaccinations in the United States. Accessed March 2, 2023.
3 Centers for Disease Control and Prevention. Underlying Medical Conditions Associated with Higher Risk for Severe COVID-19: Information for Healthcare Professionals. Underlying Medical Conditions Associated with Higher Risk for Severe COVID-19: Information for Healthcare Professionals | CDC (https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/underlyingconditions.html) Accessed August 26, 2022.
4 Centers for Disease Control and Prevention. Post-COVID Conditions: Overview for Healthcare Providers. https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/post-covid-conditions.html Accessed August 26, 2022.
5 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Arch Dis Child.
6 Liguoro I, Pilotto C, Bonanni M, et al. (2020). SARS-COV-2 infection in children and newborns: a systematic review. Eur J Pediatr.
7 Assaker R, Colas AE, Julien-Marsollier F, et al. (2020). Presenting symptoms of COVID-19 in children: a meta-analysis of published studies. Br J Anaesth.
8 Poline J, Gaschignard J, Leblanc C, et al. (2021). Systematic Severe Acute Respiratory Syndrome Coronavirus 2 Screening at Hospital Admission in Children: A French Prospective Multicenter Study. Clin Infect Dis.
9 Centers for Disease Control and Prevention. Update on Current Epidemiology of the COVID-19 Pandemic and SARS-CoV-2 Variants. Slides presented at the meeting of the Vaccines and Related Biological Products Advisory Committee, January 26, 2023. https://www.fda.gov/media/164814/download
10 Centers for Disease Control and Prevention. COVID Data Tracker. CDC COVID Data Tracker: Daily and Total Trends (https://covid.cdc.gov/covid-data-tracker/#trends_dailytrendscases_select_00) Accessed March 1, 2023.
11 Centers for Disease Control and Prevention, 2023. COVID Data Tracker. https://covid.cdc.gov/covid-data-tracker/#demographics Accessed March 2, 2023.
12 Zou J, Kurhade C, Patel S, et al. (2023). Neutralization of BA.4-BA.5, BA.4.6, BA.2.75.2, BQ.1.1, and XBB.1 with Bivalent Vaccine. N Engl J Med.
13 Link-Gelles R, Ciesla AA, Roper LE, et al. (2023). Early Estimates of Bivalent mRNA Booster Dose Vaccine Effectiveness in Preventing Symptomatic SARS-CoV-2 Infection Attributable to Omicron BA.5– and XBB/XBB.1.5–Related Sublineages Among Immunocompetent Adults — Increasing Community Access to Testing Program, United States, December 2022–January 2023. MMWR Morb Mortal Wkly Rep.
14 Tseng HF, Ackerson BK, Luo Y, et al. (2022). Effectiveness of mRNA-1273 against SARS-CoV-2 Omicron and Delta variants. Nat Med.
15 Andrews N, Stowe J, Kirsebom F, et al. (2022). Covid-19 Vaccine Effectiveness against the Omicron (B.1.1.529) Variant. N Engl J Med.
16 Taylor CA, Whitaker M, Anglin O, et al. (2022). COVID-19–Associated Hospitalizations Among Adults During SARS-CoV-2 Delta and Omicron Variant Predominance, by Race/Ethnicity and Vaccination Status - COVID-NET, 14 States, July 2021–January 2022. MMWR Morb Mortal Wkly Rep.
17 Korves C, Izurieta HS, Smith J, et al. (2022). Relative effectiveness of booster vs. 2-dose mRNA Covid-19 vaccination in the Veterans Health Administration: Self-controlled risk interval analysis. Vaccine.
18 Stowe J., Andrews N., Kirsebom F., et al. (2022). Effectiveness of COVID-19 vaccines against Omicron and Delta hospitalisation, a test negative case-control study. Nat Commun.
19 Ferdinands JM, Rao S, Dixon BE, et al. (2022). Waning 2-Dose and 3-Dose Effectiveness of mRNA Vaccines Against COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep.
20 Chemaitelly H, Ayoub HH, AlMukdad S, et al. Duration of mRNA vaccine protection against SARSCoV-2 Omicron BA.1 and BA.2 subvariants in Qatar. Nat Commun. 2022;13(1):3082. Published 2022 Jun 2.
21 Tenforde MW, Patel MM, Gaglani M, et al. (2022). Effectiveness of a Third Dose of Pfizer-BioNTech and Moderna Vaccines in Preventing COVID-19 Hospitalization Among Immunocompetent and Immunocompromised Adults — United States, August–December 2021. MMWR Morb Mortal Wkly Rep.
22 Arbel R, Sergienko R, Friger M, et al. (2021). BNT162b2 vaccine booster and mortality due to COVID 19. N Engl J Med.
23 Bar-On YM, Goldberg Y, Mandel M, et al. (2022). Protection by a Fourth Dose of BNT162b2 against Omicron in Israel. N Engl J Med.
24 Gazit S, Saciuk Y, Perez G, Peretz A, Pitzer V E, Patalon T, et al. (2022). Short term, relative effectiveness of four doses versus three doses of BNT162b2 vaccine in people aged 60 years and older in Israel: retrospective, test negative, case-control study. BMJ.
25 Link-Gelles R, Ciesla AA, Fleming-Dutra KE, et al. (2022). Effectiveness of Bivalent mRNA Vaccines in Preventing Symptomatic SARS-CoV-2 Infection — Increasing Community Access to Testing Program, United States, September–November 2022. MMWR Morb Mortal Wkly Rep.
26 Centers for Disease Control and Prevention, 2022. COVID Data Tracker. COVID-19 Vaccinations in the United States. Accessed March 2, 2023.
27 Allergic Reactions Including Anaphylaxis After Receipt of the First Dose of Pfizer-BioNTech COVID-19 Vaccine — United States. (2021). December 14–23, 2020. MMWR Morb Mortal Wkly Rep.
28 McNeil MM, Weintraub ES, Duffy J, et al. (2016). Risk of anaphylaxis after vaccination in children and adults. J Allergy Clin Immunol.
29 Lauring A S, Tenforde M W, Chappell J D, Gaglani M, Ginde A A, McNeal T, et al. (2022). Clinical severity of, and effectiveness of mRNA vaccines against, covid-19 from omicron, delta, and alpha SARS-CoV-2 variants in the United States: prospective observational study. BMJ.
30 Dorabawila V, Hoefer D, Bauer UE, Bassett M, Lutterloh E, Rosenberg E. (2022). Effectiveness of the BNT162b2 vaccine among children 5-11 and 12-17 years in New York after the Emergence of the Omicron Variant. medRxiv.
31 Kislaya I, Casaca P, Borges V, Sousa C, Ferreira B, Fernandes E, Dias CM, Duarte S, Almeida JP, Coelho L, Grenho I. (2022). SARS-CoV-2 BA. 5 vaccine breakthrough risk and severity compared with BA. 2: a case-case and cohort study using Electronic Health Records in Portugal. medRxiv.
32 Fleming-Dutra KE, Britton A, Shang N, et al. (2022). Association of Prior BNT162b2 COVID-19 Vaccination With Symptomatic SARS-CoV-2 Infection in Children and Adolescents During Omicron Predominance. JAMA.
33 FDA. Emergency Use Authorization Review Memorandum for Pfizer-BioNTech COVID-19 Vaccine, Bivalent (Original and Omicron BA.4/BA.5) for individuals 12 years of age and older VID-19 Vaccine, Bivalent (Original and Omicron BA.4/BA.5) for individuals 12 years of age and older (EUA 27034, Amendment 617). August 22, 2022. https://www.fda.gov/media/161595/download)

## Pfizer Decision Memorandum – April 18, 2023 – References

1 WHO Coronavirus (COVID-19) Dashboard (website) https://covid19.who.int/?adgroupsurvey=%7Badgroupsurvey%7D&gclid=Cj0KCQiAw8OeBhCeARIsAGxWtUxR9wuVfKmK8awaDLSRrSm65bKiEJOcvWX34XpP2LX4eD_sR9ZfUqAaArNPEALw_wcB Accessed April 14, 2023.
2 Centers for Disease Control and Prevention, 2023. Underlying Medical Conditions Associated with Higher Risk for Severe COVID-19: Information for Healthcare Professionals. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/underlyingconditions.html. Updated February 9, 2023. Accessed April 14, 2023.
3 Centers for Disease Control and Prevention, 2021. Post-COVID Conditions: Overview for Healthcare Providers. (website) https://www.cdc.gov/coronavirus/2019-ncov/hcp/clinical-care/post-covid-conditions.html. Updated December 16, 2022. Accessed April 14, 2023.
4 Irfan O, Muttalib F, Tang K, Jiang L, Lassi ZS, Bhutta Z. (2021). Clinical characteristics, treatment and outcomes of paediatric COVID-19: a systematic review and meta-analysis. Arch Dis Child.
5 Liguoro I, Pilotto C, Bonanni M, et al. (2020). SARS-COV-2 infection in children and newborns: a systematic review. Eur J Pediatr.
6 Assaker R, Colas AE, Julien-Marsollier F, et al. (2020). Presenting symptoms of COVID-19 in children: a meta- analysis of published studies. Br J Anaesth.
7 Poline J, Gaschignard J, Leblanc C, et al. (2021). Systematic Severe Acute Respiratory Syndrome Coronavirus 2 Screening at Hospital Admission in Children: A French Prospective Multicenter Study. Clin Infect Dis.
8 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trends_dailytrendscases Accessed April 14, 2023.
9 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#demographics Accessed April 14, 2023.
10 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#nowcast-heading Accessed April 14, 2023.
11 Pulliam JRC, van Schalkwyk C, Govender N, et al. (2022). Increased risk of SARS-CoV-2 reinfection associated with emergence of Omicron in South Africa. Science.
12 Tseng HF, Ackerson BK, Luo Y, et al. (2022). Effectiveness of mRNA-1273 against SARS-CoV-2 Omicron and Delta variants. Nat Med.
13 Andrews N, Stowe J, Kirsebom F, et al. (2022). Covid-19 Vaccine Effectiveness against the Omicron (B.1.1.529) Variant. N Engl J Med.
14 Taylor CA, Whitaker M, Anglin O, et al. (2022). COVID-19–Associated Hospitalizations Among Adults During SARS-CoV-2 Delta and Omicron Variant Predominance, by Race/Ethnicity and Vaccination Status— COVID-NET, 14 States, July 2021–January 2022. MMWR Morb Mortal Wkly Rep.
15 Korves C, Izurieta HS, Smith J, et al. (2022). Relative effectiveness of booster vs. 2-dose mRNA Covid-19 vaccination in the Veterans Health Administration: Self-controlled risk interval analysis. Vaccine.
16 Stowe J, Andrews N, Kirsebom F, Ramsay M, Bernal JL. (2022). Effectiveness of COVID-19 vaccines against Omicron and Delta hospitalisation: test negative case-control study. medRxiv.
17 Ferdinands JM, Rao S, Dixon BE, et al. (2022). Waning 2-Dose and 3-Dose Effectiveness of mRNA Vaccines Against COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep.
18 Chemaitelly H, Ayoub HH, AlMukdad S, et al. Duration of mRNA vaccine protection against SARS- CoV-2 Omicron BA.1 and BA.2 subvariants in Qatar. Nat Commun. 2022;13(1):3082. Published 2022 Jun 2.
19 Tenforde MW, Patel MM, Gaglani M, et al. (2022). Effectiveness of a Third Dose of Pfizer-BioNTech and Moderna Vaccines in Preventing COVID-19 Hospitalization Among Immunocompetent and Immunocompromised Adults — United States, August–December 2021. MMWR Morb Mortal Wkly Rep.
20 Arbel R, Sergienko R, Friger M, et al. (2021). BNT162b2 vaccine booster and mortality due to COVID 19. N Engl J Med.
21 Bar-On YM, Goldberg Y, Mandel M, et al. (2022). Protection by a Fourth Dose of BNT162b2 against Omicron in Israel. N Engl J Med.
22 Gazit S, Saciuk Y, Perez G, et al. Relative Effectiveness of Four Doses Compared to Three Dose of the BNT162b2 Vaccine in Israel. medRxiv.
23 Andeweg SP, de Gier B, Eggink D, van den Ende C, van Maarseveen N, Ali L, et al. (2022). Protection of COVID-19 vaccination and previous infection against Omicron BA.1, BA.2 and Delta SARS-CoV-2 infections. Nat Commun.
24 Babouee Flury B, Güsewell S, Egger T, Leal O, Brucher A, Lemmenmeier E, et al. (2022). Risk and symptoms of COVID-19 in health professionals according to baseline immune status and booster vaccination during the Delta and Omicron waves in Switzerland-A multicentre cohort study. PLoS Med.
25 Bates TA, McBride SK, Leier HC, Guzman G, Lyski ZL, Schoen D, et al. (2022). Vaccination before or after SARS-CoV-2 infection leads to robust humoral response and antibodies that effectively neutralize variants. Sci Immunol.
26 Chin ET, Leidner D, Lamson L, Lucas K, Studdert DM, Goldhaber-Fiebert JD, et al. (2022). Protection against Omicron from Vaccination and Previous Infection in a Prison System. N Engl J Med.
27 Hansen CH, Friis NU, Bager P, Stegger M, Fonager J, Fomsgaard A, et al. (2023). Risk of reinfection, vaccine protection, and severity of infection with the BA.5 omicron subvariant: a nation-wide population-based study in Denmark. Lancet Infect Dis.
28 Powell AA, Kirsebom F, Stowe J, Ramsay ME, Lopez-Bernal J, Andrews N, et al. (2022). Protection against symptomatic infection with delta (B.1.617.2) and omicron (B.1.1.529) BA.1 and BA.2 SARS-CoV-2 variants after previous infection and vaccination in adolescents in England, August, 2021-March, 2022: a national, observational, test-negative, case-control study. Lancet Infect Dis.
29 Scheaffer S. M., Lee D., Whitener B., Ying B., et al. (2023). Bivalent SARS-CoV-2 mRNA vaccines increase breadth of neutralization and protect against the BA.5 Omicron variant in mice. Nature medicine.
30 Carazo S., Skowronski D. M., Brisson M., et al. (2023). Protection against omicron (B.1.1.529) BA.2 reinfection conferred by primary omicron BA.1 or pre-omicron SARS-CoV-2 infection among health-care workers with and without mRNA vaccination: a test-negative case-control study. The Lancet. Infectious diseases.
31 Carazo S., Skowronski D. M., Brisson M., et al. (2022). Estimated Protection of Prior SARS-CoV-2 Infection Against Reinfection With the Omicron Variant Among Messenger RNA-Vaccinated and Nonvaccinated Individuals in Quebec, Canada. JAMA network open.
32 Centers for Disease Control and Prevention. COVID Data Tracker. Atlanta, GA: US Department of Health and Human Services, CDC; 2023, March 31. https://covid.cdc.gov/covid-data-tracker
33 Thompson MG, Natarajan K, Irving SA, et al. (2022). Effectiveness of a Third Dose of mRNA Vaccines Against COVID-19–Associated Emergency Department and Urgent Care Encounters and Hospitalizations Among Adults During Periods of Delta and Omicron Variant Predominance — VISION Network, 10 States, August 2021–January 2022. MMWR Morb Mortal Wkly Rep.

## Emergency Use Authorization (EUA) Amendment for an Unapproved Product Review Memorandum References

1 FDA. Emergency Use Authorization Review Memorandum for the Pfizer-BioNTech COVID-19 Vaccine/ BNT162b2. December 11, 2020. https://www.fda.gov/media/144416/download
2 Centers for Disease Control and Prevention, 2021. COVID Data Tracker (website) https://covid.cdc.gov/covid-data-tracker/#trends dailytrendscases and CDC communication
3 Poline J, Gaschignard J, Leblanc C, et al. (2020). Systematic SARS-CoV-2 screening at hospital admission in children: a French prospective multicenter study. Clin Infect Dis.
4 Thompson MG, Burgess JL, Naleway AL, et al. (2021). Interim Estimates of Vaccine Effectiveness of BNT162b2 and mRNA-1273 COVID-19 Vaccines in Preventing SARS-CoV-2 Infection Among Health Care Personnel, First Responders, and Other Essential and Frontline Workers - Eight U.S. Locations, December 2020-March 2021. MMWR.
5 Viner RM, Mytton OT, Bonell C, et al. (2021). Susceptibility to SARS-CoV-2 Infection Among Children and Adolescents Compared With Adults: A Systematic Review and Meta-analysis. JAMA Pediatr.
6 Leidman E, Duca LM, Omura JD, et al. (2021). COVID-19 Trends Among Persons Aged 0-24 Years - United States, March 1-December 12, 2020. MMWR.
7 Sargent TH, Muller WJ, Zheng X, et al. (2020). Age-Related Differences in Nasopharyngeal Severe Acute Respiratory Syndrome Coronavirus 2 (SARS-CoV-2) Levels in Patients With Mild to Moderate Coronavirus Disease 2019 (COVID-19). JAMA Pediatrics.
8 Yonker LM, Neilan AM, Bartsch Y, et al. (2020). Pediatric Severe Acute Respiratory Syndrome Coronavirus 2 (SARS-CoV-2): Clinical Presentation, Infectivity, and Immune Responses. J Pediatr.
9 Centers for Disease Control and Prevention. Science Brief: Transmission of SARS-CoV-2 in K-12 schools. Updated March 19, 2021. https://www.cdc.gov/coronavirus/2019-ncov/science/sciencebriefs/transmission k 12 schools.html#sars-cov-2
10 Goldstein E, Lipsitch M, Cevik M. (2021). On the Effect of Age on the Transmission of SARS-CoV-2 in Households, Schools, and the Community. J Infect Dis.
11 Larosa E, Djuric O, Cassinadri M, et al. (2020). Secondary transmission of COVID-19 in preschool and school settings in northern Italy after their reopening in September 2020: a population-based study. Euro Surveill.
12 Kim L, Whitaker M, O’Halloran A, et al. Hospitalization Rates and Characteristics of Children Aged <18
Years Hospitalized with Laboratory-Confirmed COVID-19 – COVID-NET, 14 States, March 1-July 25,
2020 (2020). MMWR.
13 Centers For Disease Control and Prevention. Information for Healthcare Providers about Multisystem
Inflammatory Syndrome in Children (MIS-C). February 17, 2021. https://www.cdc.gov/mis-c/hcp/
14 Centers for Disease Control and Prevention. Health Department-Reported Cases of Multisystem
Inflammatory Syndrome in Children (MIS-C) in the United States. April 1, 2021. https://www.cdc.gov/misc/cases/index.html
15 Racine N, Cooke JE, Eirich R, Korczak DJ, McArthur B, Madigan S. Child and adolescent mental
(2020). illness during COVID-19: A rapid review. Psychiatry Res.
16 Magson NR Freeman JYA Rapee RM Richardson CE Oar EL Fardouly J. Risk and Protective
Factors for Prospective Changes in Adolescent Mental Health during the COVID-19 Pandemic. J Youth
(2021). Adolesc.
17 Hill RM, Rufino K, Kurian S, et al. Suicide Ideation and Attempts in a Pediatric Emergency Department
Before and During COVID-19. (2021). Pediatrics.
18 Thompson MG, Burgess JL, Naleway AL, et al. Interim Estimates of Vaccine Effectiveness of
BNT162b2 and mRNA-1273 COVID-19 Vaccines in Preventing SARS-CoV-2 Infection Among Health
Care Personnel, First Responders, and Other Essential and Frontline Workers - Eight U.S. Locations,
(2021). December 2020-March 2021. MMWR.
19 Dagan N, Barda N, Kepten E, et al. (2021). BNT162b2 mRNA Covid-19 Vaccine in a Nationwide Mass Vaccination Setting. N Engl J Med.
20 FDA. Emergency Use Authorization 091 casirivimab and imdevimab. February 25, 2021. https://www.fda.gov/media/145610/download
21 FDA. Emergency Use Authorization 094 bamlanivimab and etesevimab. February 25, 2021. https://www.fda.gov/media/145801/download
22 Centers for Disease Control and Prevention, 2021, COVID-19 Breakthrough Case Investigations and Reporting. accessed May 4,2021. https://www.cdc.gov/vaccines/covid-19/healthdepartments/breakthrough-cases.html
23 Federal Food, Drug and Cosmetic Act, 21 U.S.C. § 360bbb–3 and 360bbb-3b. (2011)
24 FDA. Guidance for Industry: Emergency Use Authorization for Vaccines to Prevent COVID-19. February 2021. https://www.fda.gov/media/142749/download
25 FDA. Guidance for Industry: Development and Licensure of Vaccines to Prevent COVID-19. June 2020. https://www.fda.gov/regulatory-information/search-fda-guidance-documents/development-andlicensure-vaccines-prevent-covid-19