# Medical Devices

## Blood Purification Devices EUAs

November 8, 2023 - The COVID-19 public health emergency (PHE) declared under section 319 of the Public Health Service (PHS) Act expired (https://www.hhs.gov/about/news/2023/02/09/fact-sheet-covid-19-public-health-emergency-transition-roadmap.html) on May 11, 2023. The COVID-19 enforcement policy guidances within scope of the Transition Plan for Medical Devices That Fall Within Enforcement Policies Issued During the Coronavirus Disease 2019 (COVID-19) Public Health Emergency (https://www.fda.gov/regulatory-information/search-fda-guidance-documents/transition-plan-medical-devices-fall-within-enforcement-policies-issued-during-coronavirus-disease) (see List 1) are no longer in effect.

Date EUA Issued | Letter of Authorization | Assigned Product Code | Fact Sheets | Other Documents
04/22/2020 | Baxter Healthcare Corporation Extracorporeal Blood Purification (EBP) Device | QLO | - Healthcare Providers; - Patients | - IFU
04/17/2020 | ExThera Medical Corporation Extracorporeal Blood Purification (EBP) Device | QLO | - Healthcare Providers; - Patients | - IFU
04/10/2020 | CytoSorbents, Inc. Extracorporeal Blood Purification (EBP) Device | QLO | - Healthcare Providers; - Patients | - IFU
04/09/2020 | Terumo BCT Inc. and Marker Therapeutics AG Extracorporeal Blood Purification (EBP) Devices | QLO | - Healthcare Providers; - Patients | - Operation Manual for Use of D2000 with the Spectra Optia Apheresis System; - Spectra Optia Apheresis System Operator's Manual; - D2000 Cartridge IFU

## Continuous Renal Replacement Therapy and Hemodialysis Devices EUAs

November 8, 2023 - The COVID-19 public health emergency (PHE) declared under section 319 of the Public Health Service (PHS) Act expired (https://www.hhs.gov/about/news/2023/02/09/fact-sheet-covid-19-public-health-emergency-transition-roadmap.html) on May 11, 2023. The COVID-19 enforcement policy guidances within scope of the Transition Plan for Medical Devices That Fall Within Enforcement Policies Issued During the Coronavirus Disease 2019 (COVID-19) Public Health Emergency (https://www.fda.gov/regulatory-information/search-fda-guidance-documents/transition-plan-medical-devices-fall-within-enforcement-policies-issued-during-coronavirus-disease) (see List 1) are no longer in effect.

Date EUA Issued | Letter of Authorization | Assigned Product Code | Fact Sheets | Other Documents
08/10/2020 | Baxter Healthcare Corporation, Prismaflex HF20 Set | QLP | - Healthcare Providers; - Patients | - Prismaflex HF20 Set - IFU; - Prismaflex HF20 Set - IFU Insert
05/20/2020 | Baxter Healthcare Corporation, Prismaflex ST Set | QLP | - Healthcare Providers; - Patients | - Prismaflex ST Set - IFU - Global; - Prismaflex ST Set - IFU - South Korea; - Prismaflex ST Set - IFU - China
04/30/2020 | Fresenius Medical, multiFiltrate PRO System and multiBic/multiPlus Solutions | QLP | - Healthcare Providers; - Patients | - Instructions for Use, Bloodline/Tubing; - Instructions for Use, UltraFlux; - Instructions for Use, multiFiltratePRO; - Summary of Product Characteristics (SmPC); - Instructions for Use, MultiPlus

## In Vitro Diagnostics EUAs

### Molecular Diagnostic Tests for SARS-CoV-2

Authorized Molecular Diagnostic Tests for SARS-CoV-2 are assigned the QJR product code. Authorized Home Collection Kits are assigned the QLW product code. Authorized EUAs for Multi-analyte Respiratory Panel Tests are assigned the QLT product code.

#### Individual EUAs for Molecular Diagnostic Tests for SARS-CoV-2

Tests with "single target" in the attribute column are:

- designed to detect only one viral target on the SARS-CoV-2 genome;
- more susceptible to changes in performance due to viral mutations, meaning they are more likely to fail to detect new variants.

Tests with "multiple targets" in the attribute column are:

- designed to detect two or more viral targets, or sections of the SARS-CoV-2 genome;
- more likely to continue to perform well when new variants emerge.

EUAs for standalone specimen collection devices, including home collection kits which do not include an assay in the EUA, will not have a target designation in the attribute column.

Authorized Molecular Diagnostic Tests for SARS-CoV-2 are assigned the QJR product code.

Authorized Home Collection Kits are assigned the QLW product code. Authorized EUAs for Multi-analyte Respiratory Panel Tests are assigned the QLT product code.

Date EUA Issued or Last Updated | Entity | Diagnostic (Most Recent Letter of Authorization) and Date EUA Original Issue | Attributes3 | Authorized Setting(s)1 | Authorization Documents2 | Other Documents | Other Brand Name(s)
10/31/2024 | DNA Genotek Inc. | ORAcollect∙RNA OR-100 and ORAcollect∙RNA ORE-100 saliva collection devices; 10/28/2020 | Saliva Collection Device | N/A | EUA Summary, IFU | None | None
10/03/2024 | Luminex Molecular Diagnostics, Inc. | NxTAG Respiratory Pathogen Panel + SARS-CoV-2; 03/03/2021 | RT-PCR, Multi-analyte, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (January 4, 2023); Letter Granting EUA Revision(s) (October 3, 2024) | None
09/17/2024 | Pfizer Inc. | Lucira by Pfizer COVID-19 & Flu Test 11/22/2022 | RT-LAMP, Multiple Targets, Multi-analyte | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (March 22, 2023); Letter Granting EUA Revision(s) (August 3, 2023); Letter Granting EUA Revision(s) (September 6, 2023) | None
08/20/2024 | Centers for Disease Control and Prevention (CDC) | Influenza SARS-CoV-2 (Flu SC2) Multiplex Assay; 07/02/2020 | Real-time RT-PCR, Multi-analyte, Single Target | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (November 20, 2020); Letter Granting EUA Revision(s) (January 8, 2021) | None
08/09/2024 | Roche Molecular Systems, Inc. | cobas liat SARS-CoV-2, Influenza A/B & RSV nucleic acid test 06/07/2024 | RT-PCR, Multiple Targets, Multi-analyte | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (August 09, 2024) | None
07/01/2024 | SalivaDirect, Inc. | SalivaDirect DTC Saliva Collection Kit 08/27/2021 | Direct to Consumer (DTC), Home Collection Kit, Saliva, Screening | N/A | Individual, EUA Summary | None | None
07/01/2024 | SalivaDirect, Inc. | SalivaDirect 08/15/2020 | Real-time RT-PCR, Saliva, Home Collection, Screening, Pooling, Single Target | H | HCP, Patients, EUA Summary | Letter Granting EUA Revision(s) (August 25, 2020); Letter Granting EUA Revision(s) (October 15, 2020); Letter Granting EUA Revision(s) (February 5, 2021); Letter Granting EUA Revision(s) (March 12, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (April 21, 2023) | None
07/01/2024 | SalivaDirect, Inc. | SalivaDirect for use with DTC Kits 08/27/2021 | Direct to Consumer (DTC), Real-time RT-PCR, Saliva, Home Collection, Screening, Pooling, Single Target | H | HCP, Individuals, EUA Summary | Letter Granting EUA Revision(s) (December 14, 2022); Letter Granting EUA Revision(s) (April 21, 2023) | None
07/01/2024 | SalivaDirect, Inc. | SalivaDirect At-Home Collection Kit 04/09/2021 | Home Collection Kit, Saliva, Screening | N/A | EUA Summary | [underlined: Letter Granting EUA Revision(s) (May 6, 2021)] | None
05/14/2024 | 3EO Health, Inc. | 3EO Health COVID-19 Test 09/19/2023 | RT, LAMP, Over the Counter (OTC) Home Testing, Multiple Targets | Home, H, M, W | HCP, Individuals, IFU, IFU Home | Letter Granting EUA Revision(s) (May 14, 2024) | None
04/12/2024 | Aptitude Medical Systems Inc. | Metrix COVID-19 Test; 10/18/2022 | RT, LAMP, Over the Counter (OTC) Home Testing, Saliva, Screening, Multiple Targets | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (February 10, 2023); Letter Granting EUA Revision(s) (July 18, 2023); Letter Granting EUA Revision(s) (April 12, 2024) | None
04/04/2024 | GenMark Diagnostics, Inc. | ePlex Respiratory Pathogen Panel 2; 10/07/2020 | RT-PCR and electrochemical detection, Multi-analyte, Multiple Targets | H, M | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
04/01/2024 | LMSI, LLC d/b/a Lighthouse Lab Services | SalivaNow SARS-CoV-2 Assay; 04/01/2024 | Real-time RT-PCR, Saliva, Single Target | H | HCP, Patients, IFU | None | None
03/19/2024 | Tetracore, Inc. | EZ-SARS-CoV-2 Real-Time RT-PCR; 03/19/2024 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | None | None
03/06/2024 | ADL Diagnostics, Inc., dba Anavasi Diagnostics | The AscencioDx COVID-19 Test and The AscencioDx Molecular Detector; 02/08/2023 | RT-LAMP, Multiple Targets | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (April 18, 2023); Letter Granting EUA Revision(s) (March 6, 2023) | None
01/31/2024 | Revvity, Inc. | New Coronavirus Nucleic Acid Detection Kit; 03/24/2020 | Real-time RT-PCR, Pooling, Saliva, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 1, 2020); Letter Granting EUA Revision(s) (April 1, 2021); Letter Granting EUA Revision(s) (December 10, 2021); Letter Granting EUA Revision(s) (February 2, 2022); Letter Granting EUA Revision(s) (September 12, 2022) | None
01/26/2024 | Revvity, Inc. | Respiratory SARS-CoV-2 RT-PCR Panel 1; 10/06/2021 | Real-time RT-PCR, Multi-analyte, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (December 14, 2021); Letter Granting EUA Revision(s) (January 21, 2022); Letter Granting EUA Revision(s) (July 21, 2022) | None
01/25/2024 | Uh-Oh Labs Inc. | UOL COVID-19 Test; 02/08/2022 | RT-LAMP, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (March 25, 2022); Letter Granting EUA Revision(s) (August 2, 2022); Letter Granting EUA Revision(s) (September 9, 2022); Letter Granting EUA Revision(s) (November 8, 2022); Letter Granting EUA Revision(s) (July 6, 2023); Letter Granting EUA Revision(s) (January 25, 2024) | None
12/14/2023 | Pfizer Inc. | Lucira by Pfizer COVID-19 & Flu Home Test; 02/24/2023 | RT, LAMP, Over the Counter (OTC) Home Testing, Multi-analyte, Multiple Targets | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (March 22, 2023); Letter Granting EUA Revision(s) (August 3, 2023); Letter Granting EUA Revision(s) (September 6, 2023) | None
12/08/2023 | RCA Laboratory Services LLC dba GENETWORx | Gx HTIQ SARS-CoV-2 Test12/08/2023 | Real-time RT-PCR, Single Target, Screening | H | HCP, Patients, EUA Summary | None | None
12/08/2023 | RCA Laboratory Services LLC dba GENETWORx | Gx HTKB SARS-CoV-2 Test 12/08/2023 | Real-time RT-PCR, Single Target, Screening | H | HCP, Patients, EUA Summary | None | None
11/16/2023 | Roche Molecular Systems | cobas SARS-CoV-2 & Influenza A/B v211/16/2023 | Real-time RT-PCR, Multiple Targets, Multi-analyte | H, M | HCP, Patients, IFU | None | None
10/13/2023 | MAWD Laboratories | MAWD Laboratories SARS-CoV-2 Dual Target by RT-PCR10/13/2023 | real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | None | None
09/06/2023 | Pfizer Inc. | Lucira by Pfizer COVID-19 & Flu Home Test; 02/24/2023 | RT, LAMP, Over the Counter (OTC) Home Testing, Multi-analyte, Multiple Targets | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (March 22, 2023); Letter Granting EUA Revision(s) (August 3, 2023); Letter Granting EUA Revision(s) (September 6, 2023) | None
08/30/2023 | Hologic, Inc. | Aptima SARS-CoV-2 assay; 05/14/2020 | TMA, chemiluminescent, Pooling, Screening, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (July 24, 2020); Letter Granting EUA Revision(s) (September 15, 2020); Letter Granting EUA Revision(s) (January 22, 2021); Letter Granting EUA Revision(s) (March 26, 2021) | None
08/16/2023 | Visby Medical, Inc. | Visby Medical Respiratory Health Test; 12/23/2022 | RT-PCR, Multi-analyte, Multiple Targets | H, M, W | HCP, Patients, IFU | None | None
08/09/2023 | DxLab Inc. | DxLab COVID-19 Test; 06/01/2022 | RT-LAMP, Serial Screening, Multiple Targets | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (November 23, 2022); Letter Granting EUA Revision(s) (April 28, 2023); Letter Granting EUA Revision(s) (August 9, 2023) | None
08/02/2023 | Roche Molecular Systems | cobas SARS-CoV-2 Nucleic acid test for use on the cobas Liat System (cobas SARS-CoV-2); 06/17/2021 | Real-time RT-PCR, Screening, Multiple Targets | H, M, W | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (August 11, 2022); Letter Granting EUA Revision(s) (October 26, 2022); Letter Granting EUA Revision(s) (February 16, 2023); Letter Granting EUA Revision(s) (May 18, 2023) | None
07/28/2023 | Becton, Dickinson and Company (BD) | BD Respiratory Viral Panel for BD MAX System; 02/03/2023 | Real-time RT-PCR, Multi-analyte, Multiple Targets | M, H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (July 28, 2023) | None
07/20/2023 | Alphadera Labs, LLC | ALPHADx SARS-COV-2 RT-PCR Test; 07/20/2023 | Real-time RT-PCR, Multiple Target(s) | H | HCP, Patients, EUA Summary | None | None
07/18/2023 | Aptitude Medical Systems Inc. | Metrix COVID-19 Test 10/18/2022 | RT, LAMP, Over the Counter (OTC) Home Testing, Saliva, Screening, Multiple Targets | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (February 10, 2023); Letter Granting EUA Revision(s) (July 18, 2023) | None
07/18/2023 | Cepheid | Xpert Xpress CoV-2/Flu/RSV plus 09/10/2021 | Real-time RT-PCR, Multi-analyte, Multiple Targets | H, M, W | HCP, Patients, IFU for Labs, IFU for Point-of-Care | Letter Granting EUA Revision(s) (October 20, 2021); Letter Granting EUA Revision(s) (July 18, 2023) | None
07/18/2023 | LumiraDx UK Ltd. | LumiraDx SARS-CoV-2 RNA STAR; 08/11/2020 | RT, non-isothermal nucleic acid amplification qSTAR, Single Target | H | HCP, Patient, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
07/10/2023 | LumiraDx UK Ltd. | LumiraDx SARS-CoV-2 RNA STAR Complete; 10/14/2020 | RT, qSTAR amplification, Home Collection, Screening, Pooling, Single Target | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (March 22, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (August 17, 2022); Letter Granting EUA Revision(s) (September 15, 2022); Letter Granting EUA Revision(s) (February 22, 2023) | None
07/06/2023 | GenMark Diagnostics, Inc. | ePlex Respiratory Pathogen Panel 2; 10/07/2020 | RT-PCR and electrochemical detection, Multi-analyte, Multiple Targets | H, M | HCP, Patients, IFU | None | None
07/06/2023 | Uh-Oh Labs Inc. | UOL COVID-19 Test; 02/08/2022 | RT-LAMP, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (March 25, 2022); Letter Granting EUA Revision(s) (August 2, 2022); Letter Granting EUA Revision(s) (September 9, 2022); Letter Granting EUA Revision(s) (November 8, 2022); Letter Granting EUA Revision(s) (July 6, 2023) | None
06/30/2023 | LumiraDx UK Ltd. | LumiraDx SARS-CoV-2 & Flu A/B RNA STAR Complete Assay; 02/03/2023 | RT, Non-isothermal Nucleic Acid Amplification qSTAR, Multi-analyte, Single Target | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (June 30, 2023) | None
06/30/2023 | Discover Labs | Discover Labs COVID-19 Assay; 06/30/2023 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | None | None
06/29/2023 | Pfizer Inc. | Lucira CHECK-IT COVID-19 Test Kit; 04/09/2021 | RT, LAMP, Over the Counter (OTC) Home Testing, Screening, Multiple Targets | Home, H, M, W | HCP, IFU, IFU (Home Test) | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (July 28, 2022) | None
06/16/2023 | Roche Molecular Systems, Inc. | cobas SARS-CoV-2 & Influenza A/B Nucleic Acid Test for use on the cobas Liat System; 09/14/2020 | Real-time RT-PCR, Multi-analyte, Multiple Targets | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (September 18, 2020); Letter Granting EUA Revision(s) (December 10, 2020); Letter Granting EUA Revision(s) (June 24, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (January 6, 2022); Letter Granting EUA Revision(s) (August 11, 2022); Letter Granting EUA Revision(s) (October 26, 2022); Letter Granting EUA Revision(s) (February 16, 2023) | None
06/14/2023 | Texas Department of State Health Services, Laboratory Services Section | Texas Department of State Health Services (DSHS) SARS-CoV-2 Assay; 08/21/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (June 14, 2023) | None
06/14/2023 | Pfizer Inc. | Lucira COVID-19 All-In-One Test Kit; 11/17/2020 | Prescription Home Testing, Multiple Targets | Home, H, M, W | HCP, IFU, IFU (Home Test) | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (July 28, 2022) | None
06/12/2023 | Vela Operations Singapore Pte. Ltd. | ViroKey SARS-CoV-2 RT-PCR Test v2.0; 09/22/2020 | Real-time RT-PCR, Multiple Targets, Pooled Serial Screening – Media | H | HCP, Patients, IFU | Pooling and Serial Testing Amendment for Certain Molecular Diagnostic Tests for SARS-CoV-2 – Amendment Letter; Letter Granting EUA Revision(s) (June 12, 2023) | None
06/08/2023 | Michigan State University laboratories, Department of Medicine Olin Student Health Center | In-Dx SARS-CoV-2 RT-LAMP Assay 06/08/2023 | RT-LAMP, Single Target | H | HCP, Patients, EUA Summary | None | None
06/05/2023 | Acutis Diagnostics | SARS-CoV-2 Acutis Multiplex Assay 06/05/2023 | real-time RT-PCR, Multiple Targets | H | HCP, Patient, EUA Summary | None | None
06/05/2023 | BioFire Diagnostics, LLC | BioFire Respiratory Panel 2.1-EZ (RP2.1-EZ); 10/02/2020 | RT, Nested multiplex PCR, Multi-analyte, Multiple Targets | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (December 22, 2020); Letter Granting EUA Revision(s) (April 27, 2021); Letter Granting EUA Revision(s) (April 26, 2022); Letter Granting EUA Revision(s) (June 5, 2023) | None
05/31/2023 | Thermo Fisher Scientific Inc. | TaqPath COVID-19 Pooling Kit; 05/25/2021 | Real-time RT-PCR, Pooling, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (May 31, 2023) | None
05/24/2023 | Abbott Diagnostics Scarborough, Inc. | ID NOW COVID-19 2.0; 05/06/2022 | RT, Isothermal amplification, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (May 24, 2023) | None
05/12/2023 | DTPM, Inc. | DTPM COVID-19 RT-PCR Test; 06/10/2020 | Real-time RT-PCR, Single Target | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
05/03/2023 | Access Medical Laboratories, Inc. | Global Direct RT-PCR Test; 05/03/2023 | real-time RT-PCR, Single Target | H | HCP, Patients, EUA Summary | None | None
04/28/2023 | Drexel University College of Medicine | SARS-CoV-2 DUCoM-PDL Modified Tetracore Assay 04/28/2023 | real-time RT-PCR, Multiple Targets | H | HCP, Patient, EUA Summary | None | None
04/26/2023 | University of Massachusetts | ICTC SARS-CoV-2 RT-PCR Assay 4/26/2023 | real-time RT-PCR, Multiple Targets | H | HCP, Patient, EUA Summary | None | None
04/19/2023 | MedArbor, LLC dba MedArbor Diagnostics | MedArbor Diagnostics SARS-CoV-2 Assay; 04/19/2023 | real-time RT-PCR, Single Target | H | HCP, Patients, EUA Summary | None | None
04/18/2023 | ADL Diagnostics, Inc., dba Anavasi Diagnostics | The AscencioDx COVID-19 Test and The AscencioDx Molecular Detector; 02/08/2023 | RT-LAMP, Multiple Targets | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (April 18, 2023) | None
04/17/2023 | Quidel Corporation | Lyra SARS-CoV-2 Assay; 03/17/2020 | Real-time RT-PCR, Single Target | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 8, 2020); Letter Granting EUA Revision(s) (April 21, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (September 16, 2022); Letter Granting EUA Revision(s) (April 17, 2023) | None
03/31/2023 | Bioeksen R&D Technologies Inc. | Bio-Speedy Direct RT-qPCR SARS-CoV-2; 09/02/2020 | Real-time RT-PCR, Single Target | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (December 9, 2020); Viral Mutation Revision Letter - September 23, 2021 | BioeXsen SARS-CoV-2 RT PCR
03/31/2023 | Thermo Fisher Scientific Inc. | TaqPath COVID-19 RNase P Combo Kit 2.0; 07/08/2021 | Real-time RT-PCR, Screening, Home Collection, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (March 1, 2022); Letter Granting EUA Revision(s) (September 21, 2022); Letter Granting EUA Revision(s) (March 31, 2023) | None
03/30/2023 | SD Biosensor, Inc. | STANDARD M nCoV Real-Time Detection Kit; 04/23/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (March 30, 2023) | None
03/27/2023 | Luminex Corporation | ARIES SARS-CoV-2 Assay; 04/03/2020 | RT-PCR, Multiple Targets | H, M | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (May 11, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
03/24/2023 | Biomeme, Inc. | Biomeme SARS-CoV-2 Real-Time RT-PCR Test; 08/11/2020 | Real-time RT-PCR, Pooled Serial Screening - Swab, Pooled Serial Screening - Media, Multiple Targets | H | HCP, Patient, IFU | Pooling and Serial Testing Amendment for Certain Molecular Diagnostic Tests for SARS-CoV-2 - Amendment Letter; Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) April, 5, 2022 | None
03/23/2023 | PerkinElmer, Inc. | PerkinElmer New Coronavirus Nucleic Acid Detection Kit; 03/24/2020 | Real-time RT-PCR, Pooling, Saliva, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 1, 2020); Letter Granting EUA Revision(s) (April 1, 2021); Letter Granting EUA Revision(s) (December 10, 2021); Letter Granting EUA Revision(s) (February 2, 2022); Letter Granting EUA Revision(s) (September 12, 2022) | None
03/20/2023 | Thermo Fisher Scientific | TaqPath COVID-19, FluA, FluB Combo Kit; 02/10/2021 | Real-time RT-PCR, Multi-analyte, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (March 4, 2022); Letter Granting EUA Revision(s) (March 20, 2023) | None
03/20/2023 | Life Technologies Corporation (a part of Thermo Fisher Scientific Inc.) | TaqPath COVID-19 Fast PCR Combo Kit 2.0; 07/30/2021 | Real-time RT-PCR, Saliva, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (October 22, 2021); Letter Granting EUA Revision(s) (March 20, 2023) | None
03/15/2023 | Mesa Biotech Inc. | Accula SARS-Cov-2 Test; 03/23/2020 | RT and amplification, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 30, 2020); Letter Granting EUA Revision(s) (August 24, 2020); Letter Granting EUA Revision(s) (February 3, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
03/15/2023 | Ipsum Diagnostics, LLC | COV-19 IDx assay; 04/01/2020 | Real-time RT-PCR, Single Target | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
03/14/2023 | Co-Diagnostics, Inc. | Logix Smart Coronavirus Disease 2019 (COVID-19) Kit; 04/03/2020 | RT-PCR, CoPrimer technology, Single Target | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (March 14, 2023) | None
03/10/2023 | Quest Diagnostics Nichols Institute | Quest SARS-CoV-2 rRT-PCR; 03/17/2020 | Real-time RT-PCR, Home Collection, Pooling, Multiple Targets, Screening (Anterior Nasal) | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (March 26, 2020); Letter Granting EUA Amendment(s) (July 28, 2020); Letter Granting EUA Revision(s) (November 13, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
03/10/2023 | Quest Diagnostics Nichols Institute | Quest Diagnostics PF SARS-CoV-2 Assay; 07/15/2020 | Real-time RT-PCR, Home Collection, Multiple Targets, Screening | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
03/10/2023 | Quest Diagnostics Nichols Institute | Quest Diagnostics RC SARS-CoV-2 Assay; 07/15/2020 | Real-time RT-PCR, Home Collection, Pooling, Multiple Targets, Screening | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
03/10/2023 | Quest Diagnostics Nichols Institute | Quest COVID-19 Nucleic Acid Test Collection Kit; 03/10/2023 | Home Collection Kit, Screening | N/A | EUA Summary, IFU | None | None
03/09/2023 | Maccura Biotechnology (USA) LLC | SARS-CoV-2 Fluorescent PCR Kit; 04/15/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (June 2, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
03/07/2023 | Centers for Disease Control and Prevention's (CDC) | CDC 2019-nCoV Real-Time RT-PCR Diagnostic Panel (CDC); 02/04/2020 | Real-time RT-PCR, Pooling, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (March 30, 2020); Letter Granting EUA Amendment(s) (June 12, 2020); Letter Granting EUA Amendment(s) (July 13, 2020); Letter Granting EUA Revision(s) (July 21, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
03/03/2023 | Genetron Health (Beijing) Co., Ltd. | Genetron SARS-CoV-2 RNA Test; 06/05/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
03/02/2023 | Everlywell, Inc. | Everlywell COVID-19 Test Home Collection Kit; 05/15/2020 | Home Collection Kit | N/A | IFU, EUA Summary | Letter Granting EUA Revision(s) (September 4, 2020) | None
03/02/2023 | Everlywell, Inc. | Everlywell COVID-19 Test Home Collection Kit DTC; 02/13/2021 | Home Collection Kit, Direct to Consumer (DTC), Screening | N/A | Individuals, EUA Summary, IFU (Home Collect) | None | None
03/01/2023 | LabGenomics Co., Ltd. | LabGun COVID-19 RT-PCR Kit; 04/29/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
02/27/2023 | Xiamen Zeesan Biotech Co., Ltd. | SARS-CoV-2 Test Kit (Real-time PCR); 07/31/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (November 10, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
02/24/2023 | OSANG Healthcare | GeneFinder COVID-19 Plus RealAmp Kit; 04/18/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (June 24, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
02/17/2023 | DxTerity Diagnostics, Inc. | DxTerity SARS-CoV-2 RT PCR CE Test; 08/28/2020 | RT-PCR, Home Collection, Saliva, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (March 29, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
02/16/2023 | Genetrack Biolabs, Inc. | Genetrack SARS-CoV-2 Molecular Assay; 09/25/2020 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (October 17, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
02/15/2023 | Fosun Pharma USA Inc. | Fosun COVID-19 RT-PCR Detection Kit; 04/17/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
02/14/2023 | Hologic, Inc. | Aptima SARS-CoV-2/Flu assay; 12/16/2020 | Real-time TMA, chemiluminescent, Multi-analyte, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (February 24, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (February 14, 2023) | None
02/13/2023 | Enzo Life Sciences, Inc. | AMPIPROBE SARS-CoV-2 Test System; 07/07/2020 | Real-time RT-PCR, Pooling, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (July 16, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
02/10/2023 | Roche Molecular Systems, Inc. | cobas SARS-CoV-2 & Influenza A/B; 09/03/2020 | Real-time RT-PCR, Multi-analyte, Multiple Targets | H, M | HCP, Patients, IFU | Letter Granting EUA Revision(s) (December 15, 2020); Letter Granting EUA Revision(s) (June 8, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA [VB,R3] Revision(s) (February 10, 2023) | None
02/08/2023 | Roche Molecular Systems, Inc. (RMS) | cobas SARS-CoV-2; 03/12/2020 | Real-time RT-PCR, Pooling, Screening, Multiple Targets | H, M, H-Pooling | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (March 31, 2020); Letter Granting EUA Amendment(s) (May 13, 2020); Letter Granting EUA Revision(s) (May 14, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (February 8, 2023) | None
02/08/2023 | The HFI Laboratory at Boston University (dba the BU Clinical Testing Laboratory) | BU SARS-CoV-2 Test; 02/08/2023 | real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | None | None
12/19/2022 | OnsiteGene, Inc. | Hi-Sense COVID-19 Molecular Testing Kit 1.0; 12/19/2022 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | None | None
12/13/2022 | Seegene, Inc. | Allplex 2019-nCoV Assay; 04/21/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (July 27, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
12/09/2022 | 1drop Inc. | 1copy COVID-19 qPCR Multi Kit; 05/11/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (December 9, 2022) | None
11/18/2022 | Premier Medical Laboratory Services | Diversified Medical Healthcare SARS-CoV-2 Assay; 11/18/2022 | Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | None | None
11/15/2022 | altona Diagnostics GmbH | RealStar SARS-CoV02 RT-PCR Kits U.S.; 04/22/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
11/08/2022 | Nanobiosym Precision Testing Services | The Nano Test for COVID-19 11/08/2022 | Real-time RT-PCR, Home Collection, Saliva, Multiple Targets | H | HCP, Patients, EUA Summary, IFU | None | None
11/07/2022 | Cepheid | Xpert Xpress CoV-2 plus; 05/10/2022 | Real-time RT-PCR, Screening, Multiple Targets | H, M, W | HCP, Patients, IFU for Labs, IFU for Point-of-Care | None | None
11/04/2022 | Thermo Fisher Scientific Inc. | Amplitude Solution with the TaqPath COVID-19 High-Throughput Combo Kit; 04/09/2021 | Real-time RT-PCR, Saliva, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (March 3, 2022); Letter Granting EUA Revision(s) (November 4, 2022) | None
11/01/2022 | OPTI Medical Systems, Inc. | OPTI SARS-CoV-2 RT PCR Test; 05/06/2020 | Real-time RT-PCR, Screening, Pooling, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (May 29, 2020); Letter Granting EUA Amendment(s) (July 29, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
11/01/2022 | Trax Management Services Inc. | PhoenixDx SARS-CoV-2 Multiplex; 07/13/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (August 8, 2020); Letter Granting EUA Revision(s) (November 20, 2020); Letter Granting EUA Revision(s) (April 7, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
11/01/2022 | Laboratory Corporation of America (LabCorp) | Pixel by LabCorp COVID-19 Test Home Collection Kit; 12/09/2020 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Pooling, Screening, Multiple Targets | H | HCP, Individuals, EUA Summary, IFU (Home Collect) | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (April 1, 2022); Letter Granting EUA Revision(s) (July 8, 2022); Letter Granting EUA Revision(s) (November 1, 2022) | None
11/01/2022 | BioGX, Inc. | BioGX Xfree COVID-19 Direct RT-PCR; 06/29/2021 | Real-time RT-PCR, Single Target | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (November 1, 2022) | None
10/25/2022 | Bio-Rad Laboratories, Inc. | Bio-Rad Reliance SARS-CoV-2 RT-PCR Assay Kit; 01/15/2021 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
10/19/2022 | Cleveland Clinic Robert J. Tomsich Pathology and Laboratory Medicine Institute | SelfCheck cobas SARS-CoV-2 Assay; 09/29/2021 | Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | None | None
10/19/2022 | Luminex Molecular Diagnostics, Inc. | NxTAG CoV Extended Panel Assay; 03/27/2020 | RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
10/12/2022 | GeneMatrix, Inc. | NeoPlex COVID-19 Detection Kit; 05/14/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (January 26, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
10/11/2022 | Cepheid | Xpert Xpress SARS-CoV-2 DoD; 12/23/2020 | Real-time RT-PCR, Pooling, Multiple Targets | H, M, W | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
10/06/2022 | Quest Diagnostics Nichols Institute | Quest COVID-19 PCR DTC; 03/21/2022 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Pooling, Multiple Targets, Screening | H | HCP, Individuals, EUA Summary | Letter Granting EUA Revision(s) (October 6, 2022) | None
10/04/2022 | Avellino Lab USA, Inc. | AvellinoCoV2 test; 03/25/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Letter Granting EUA Revision(s) (September 24, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
09/13/2022 | Predicine, Inc. | Predicine SARS-CoV-2 RT-PCR Test 07/19/2022 | Real-time RT-PCR, Home Collection, Multiple Targets, Screening, Pooling | H | HCP, Patients, EUA Summary, IFU (Home Collect) | None | None
09/13/2022 | Rheonix, Inc. | Rheonix COVID-19 MDx Assay; 04/29/2020 | RT-PCR, Home Collection, Saliva, Single Target | H, M | HCP, Patients, IFU, IFU (Home Collect) | Viral Mutation Revision Letter - September 23, 2021 | None
09/06/2022 | INNO Diagnostics Reference Laboratory, Ponce Medical School | PMSF-INNO SARS-CoV-2 RT-PCR Test (Authorized by HHS/OASH); 01/19/2021 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
08/31/2022 | Thermo Fisher Scientific, Inc. | TaqPath COVID-19 Combo Kit; 03/13/2020 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (March 24, 2020); Letter Granting EUA Amendment(s) (April 20, 2020); Letter Granting EUA Amendment(s) (May 9, 2020); Letter Granting EUA Amendment(s) (July 17, 2020); Letter Granting EUA Revision(s) (November 20, 2020); Letter Granting EUA Revision(s) (February 23, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (August 31, 2022) | None
08/31/2022 | University of Louisville Infectious Diseases Laboratory | SARS-CoV-2 real time RT-PCR test (Authorized by HHS/OASH); 01/19/2021 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
08/24/2022 | Applied BioCode, Inc. | BioCode CoV-2 Flu Plus Assay; 12/15/2021 | RT-PCR, Multi-analyte, Single Target | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (August 24, 2022) | None
08/24/2022 | MicroGEM U.S., Inc. | MicroGEM Sal6830 SARS-CoV-2 Saliva Test; 04/14/2022 | Real-time RT-PCR, Saliva, Multiple Targets | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (August 24, 2022) | None
08/17/2022 | Cleveland Clinic Robert J. Tomsich Pathology and Laboratory Medicine Institute | SelfCheck cobas SARS-CoV-2 + Flu Assay 04/11/2022 | Real-time RT-PCR, Home Collection, Multi-analyte, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (August 17, 2022) | None
08/12/2022 | RCA Laboratory Services LLC dba GENETWORx | GENETWORx Covid-19 Nasal Swab Test; 12/15/2020 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (February 12, 2021); Letter Granting EUA Revision(s) (May 14, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (November 17, 2021) | None
08/07/2022 | Gravity Diagnostics, LLC | Gravity Diagnostics SARS-CoV-2 RT-PCR for use with DTC kits; 02/13/2021 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Individuals, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
08/07/2022 | Gravity Diagnostics, LLC | Gravity Diagnostics COVID-19 Test Home Collection Kit; 03/09/2021 | Home Collection Kit, Direct to Consumer (DTC), Screening | N/A | EUA Summary, Individuals, IFU | None | None
07/28/2022 | Laboratory Corporation of America (Labcorp) | Labcorp Seasonal Respiratory Virus RT-PCR DTC Test 05/16/2022 | Direct to Consumer (DTC), Real-time RT-PCR, Multi-analyte, Home Collection, Single Target | H | HCP, Individuals, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (July 28, 2022) | None
07/28/2022 | Laboratory Corporation of America (Labcorp) | Labcorp SARS-CoV-2 & Influenza A/B Assay; 9/30/2021 | Real-time RT-PCR, Multi-analyte, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (July 28, 2022) | None
07/28/2022 | Minute Molecular Diagnostics, Inc. | DASH SARS-CoV-2/S Test; 03/15/2022 | Real-time RT-PCR, Multiple Targets | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (July 28, 2022) | None
07/28/2022 | Laboratory Corporation of America (Labcorp) | Labcorp Seasonal Respiratory Virus RT-PCR Test; 05/17/2022 | Real-time RT-PCR, Multi-analyte, Home Collection, Single Target | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (July 28, 2022) | None
07/21/2022 | Meridian Bioscience, Inc. | Revogene SARS-CoV-2; 11/09/2021 | Real time RT-PCR, Single Target | H, M | HCP, Patients, IFU | None | None
07/21/2022 | PerkinElmer, Inc. | PKamp Respiratory SARS-CoV-2 RT-PCR Panel 1; 10/06/2021 | Real-time RT-PCR, Multi-analyte, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (December 14, 2021); Letter Granting EUA Revision(s) (January 21, 2022); Letter Granting EUA Revision(s) (July 21, 2022) | None
07/21/2022 | Color Health, Inc. | Color COVID-19 Self-Swab Collection Kit; 08/31/2020 | Home Collection Kit, Screening, Multiple Targets | N/A | EUA Summary, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (January 26, 2022); Letter Granting EUA Revision(s) (July 21, 2022) | None
07/21/2022 | Nexus Medical Labs, LLC | Nexus High Throughput SARS-CoV-2 Assay; 05/17/2022 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (July 21, 2022) | None
07/19/2022 | Audere | HealthPulse@home; 11/30/2021 | Home Collection Kit, Screening, Single Target | N/A | EUA Summary, IFU | None | None
07/14/2022 | Becton, Dickinson and Company (BD) | BD SARS-CoV-2 Reagents for BD MAX System; 04/08/2020 | Real-time RT-PCR, Screening, Multiple Targets | H, M | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (June 11, 2020); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (July 14, 2022) | None
07/14/2022 | Helix OpCo LLC (dba Helix) | Helix SARS-CoV-2 Test; 03/17/2022 | Real-time RT-PCR, Home Collection, Multiple Targets, Screening | H | HCP, Patients, EUA Summary, IFU (Home Collect) | None | None
07/07/2022 | Grifols Diagnostic Solutions Inc. | Procleix SARS-CoV-2 Assay; 02/10/2021 | TMA, Single Target | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
07/07/2022 | Quest Diagnostics Nichols Institute | Quest COVID-19 PCR Test Home Collection Kit; 03/21/2022 | Direct to Consumer (DTC), Home Collection Kit, Screening | N/A | EUA Summary, IFU, Individuals | Letter Granting EUA Revision(s) (July 7, 2022) | None
06/28/2022 | Abbott Molecular Inc. | Abbott RealTime SARS-CoV-2 assay; 03/18/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 1, 2020); Letter Granting EUA Amendment(s) (July 30, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
06/28/2022 | Abbott Molecular Inc. | Alinity m SARS-CoV-2 assay; 05/11/2020 | Real-time RT-PCR, Pooling, Screening, Multiple Targets | H, M | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (July 20, 2020); Letter Granting EUA Revision(s) (August 24, 2020) | None
06/28/2022 | Abbott Molecular Inc. | Alinity m Resp-4-Plex; 03/04/2021 | Real-time RT-PCR, Multi-analyte, Multiple Targets | H, M | HCP, Patients, IFU | Letter Granting EUA Revision(s) (June 10, 2021); Letter Granting EUA Revision(s) (July 1, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (February 7, 2022); Letter Granting EUA Revision(s) (March 30, 2022) | None
06/21/2022 | Laboratory Corporation of America (Labcorp) | COVID-19 RT-PCR Test; 03/16/2020 | Real-time RT-PCR, Home Collection, Pooling, Screening, Multiple Targets | H | HCP, Patients, EUASummary, IFU (Home Collect) | Letter Granting EUA Amendment(s) (April 14, 2020); Letter Granting EUA Amendment(s) (July 1, 2020); Letter Granting EUA Revision(s) (May 11, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (April 7, 2022) | None
06/15/2022 | Color Health, Inc. | Color COVID-19 Self-Swab Collection Kit with Saline; 04/14/2021 | Home Collection Kit, Screening | N/A | EUA Summary, IFU | Letter Granting EUA Revision(s) (January 31, 2022); Letter Granting EUA Revision(s) (June 15, 2022) | None
06/14/2022 | Roche Molecular Systems, Inc. | cobas SARS-CoV-2 Duo for use on the cobas 6800/8800 Systems; 06/14/2022 | Real-time RT-PCR, Quantitative, Multiple Targets | H, M | HCP, Patients, IFU | None | None
06/08/2022 | SML GENETREE Co., Ltd. | Ezplex SARS-CoV-2 G Kit; 01/13/2021 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (April 30, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
05/31/2022 | BioFire Defense, LLC | BioFire COVID-19 Test; 03/23/2020 | RT, Nested multiplex PCR, Pooling, Saliva, Multiple Targets | H, M | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 30, 2020); Letter Granting EUA Revision(s) (March 7, 2022); Letter Granting EUA Revision(s) (May 31, 2022) | None
05/27/2022 | MiraDx | MiraDx SARS-CoV-2 RT-PCR assay; 08/31/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
05/25/2022 | UCSD BCG EXCITE Lab | UCSD EXCITE COVID-19 EL Test 04/07/2022 | Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (May 25, 2022) | None
05/05/2022 | Quidel Corporation | Solana SARS-CoV-2 Assay; 12/23/2020 | Isothermal Reverse Transcriptase - Helicase-Dependent Amplification (RT-HDA), Single Target | H, M | HCP, Patients, IFU | Letter Granting EUA Revision(s) (March 9, 2021); Letter Granting EUA Revision(s) (March 25, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (May 5, 2022) | None
04/29/2022 | Cue Health Inc. | Cue COVID-19 Test for Home and Over The Counter (OTC) Use; 03/05/2021 | RT, Isothermal amplification, Over the Counter (OTC) Home Testing, Screening, Single Target | Home, H, M, W | HCP, Individuals, IFU, IFU (Home Test), FAQ | Viral Mutation Revision Letter - September 23, 2021 | None
04/26/2022 | Audere | HealthPulse@home Fusion 04/26/2022 | Home Collection Kit, Screening, Single Target | N/A | EUA Summary, IFU | None | None
04/26/2022 | BGI Genomics Co. Ltd | Real-Time Fluorescent RT-PCR Kit for Detecting SARS-CoV-2; 03/26/2020 | Real-time RT-PCR, Single Target | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 24, 2020); Letter Granting EUA Revision(s) (March 29, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
04/26/2022 | Cepheid | Xpert Xpress SARS-CoV-2 test; 03/20/2020 | Real-time RT-PCR, Multiple Targets | H, M, W | HCP, Patients, IFU for Labs,; IFU for Point-of-Care | Letter Granting EUA Amendment(s) (April 28, 2020); Letter Granting EUA Amendment(s) (August 8, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
04/26/2022 | PlexBio Co., Ltd. | IntelliPlex SARS-CoV-2 Detection Kit; 06/25/2020 | RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (February 3, 2021) | None
04/21/2022 | Premier Medical Laboratory Services | PMLS SARS-CoV-2 Assay; 01/07/2022 | Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | None | None
04/21/2022 | OPTI Medical Systems, Inc. | OPTI SARS-CoV-2/ Influenza A/B RT-PCR Test (Version 1 and Version 2); 04/21/2022 | Real-time RT-PCR, Multi-analyte, Multiple Targets | H | HCP, Patients, IFU | None | None
04/13/2022 | Euroimmun US, Inc. | EURORealTime SARS-Cov-2; 06/08/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (April 22, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
04/06/2022 | DC Department of Health | Test Yourself DC At-Home COVID-19 Collection Kit 04/06/2022 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Pooling, Screening, Multiple Targets | H | HCP, Individuals, EUA Summary, IFU (Home Collect) | None | None
03/25/2022 | Sansure BioTech Inc. | Novel Coronavirus (2019-nCoV) Nucleic Acid Diagnostic Kit (PCR-Fluorescence Probing); 05/04/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s)(March 25, 2022) | None
03/24/2022 | Clear Labs, Inc. | Clear Dx SARS-CoV-2 Test; 09/23/2020 | RT-PCR and Sequencing, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
03/23/2022 | Hologic, Inc. | Panther Fusion SARS-CoV-2 Assay; 03/16/2020 | Real-time RT-PCR, Pooling, Screening, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 24, 2020); Letter Granting EUA Revision(s) (January 22, 2021) | None
03/21/2022 | Quest Diagnostics Nichols Institute | Quest RC COVID-19 PCR DTC; 03/21/2022 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Pooling, Multiple Targets, Screening | H | HCP, Individuals, EUA Summary | None | None
03/21/2022 | Quest Diagnostics Nichols Institute | Quest PF COVID-19 PCR DTC; 03/21/2022 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Pooling, Multiple Targets, Screening | H | HCP, Individuals, EUA Summary | None | None
03/18/2022 | Tempus Labs, Inc. | iC SARS-CoV2 Test; 10/01/2020 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Viral Mutation Revision Letter - September 23, 2021 | None
03/15/2022 | Bio-Rad Laboratories, Inc | Bio-Rad SARS-CoV-2 ddPCR Test; 05/01/2020 | RT-droplet PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (December 9, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
03/03/2022 | Diversified Medical Healthcare | RapidRona Self-Collection Kit; 11/23/2020 | Home Collection Kit, Screening | N/A | EUA Summary, IFU (Collection) | Viral Mutation Revision Letter - September 23, 2021 | None
03/01/2022 | Cue Health Inc. | Cue COVID-19 Test; 06/10/2020 | RT, Isothermal amplification, Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (August 20, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
02/23/2022 | Assurance Scientific Laboratories | Assurance SARS-CoV-2 Panel; 05/15/2020 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
02/23/2022 | Assurance Scientific Laboratories | Assurance SARS-CoV-2 Panel DTC; 02/13/2021 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Screening, Single Target | H | HCP, Individuals, EUA Summary, IFU (Home Collect) | None | binx/Assurance Covid-19 Collection Kit
02/18/2022 | Sherlock BioSciences, Inc. | Sherlock CRISPR SARS-CoV-2 Kit; 05/06/2020 | RT-LAMP, CRISPR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
02/14/2022 | Zymo Research Corporation | Quick SARS-CoV-2rRT-PCR Kit; 05/07/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (May, 18, 2020); Letter Granting EUA Amendment(s) (May 28, 2020); Letter Granting EUA Revision(s) (December 30, 2020); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (February 14, 2022) | None
02/01/2022 | LetsGetChecked, Inc. | LetsGetChecked Coronavirus (COVID-19) Test; 05/28/2020 | Direct to Consumer (DTC), TMA, chemiluminescent, Home Collection, Screening, Pooling, Multiple Targets | H | HCP, Individuals, EUA Summary, IFU (Home Collect) | Letter Granting EUA Amendment(s) (July 6, 2020); Letter Granting EUA Revision(s) (November 1, 2021) | None
01/28/2022 | National Jewish Health | SARS-CoV-2 MassArray Test; 09/29/2020 | RT-PCR and MALDI-TOF Mass Spec. , Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (January 21, 2022) | None
01/26/2022 | Psomagen, Inc. | Psoma COVID-19 RT Test; 06/30/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (January 26, 2022) | None
01/26/2022 | Color Health, Inc. | Color COVID-19 Self-Swab Collection Kit DTC; 03/19/2021 | Home Collection Kit, Direct to Consumer (DTC), Screening | N/A | EUA Summary, Individuals, IFU | Letter Granting EUA Revision(s) (January 26, 2022) | None
01/26/2022 | STS Lab Holdco (a subsidiary of Amazon.com Services LLC) | Amazon Real-Time RT-PCR Test for Detecting SARS-CoV-2; 03/25/2021 | Real-time RT-PCR, Home Collection, Pooling, Screening, Single Target | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (December 17, 2021); Letter Granting EUA Revision(s) (January 26, 2022) | None
01/20/2022 | DiaCarta, Inc. | QuantiVirus SARS-CoV-2 Multiplex Test Kit; 07/21/2020 | Real-time RT-PCR, Single Target | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
01/19/2022 | Fast Track Diagnostics Luxembourg S.á.r.l. (a Siemens Healthineers Company) | FTD SARS-CoV-2; 05/05/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (July 9, 2020); Letter Granting EUA Revision(s) (April 7, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
01/19/2022 | Illumina, Inc. | Illumina COVIDSeq Test; 06/09/2020 | Sequencing, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (August 20, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
01/19/2022 | Viracor Eurofins Clinical Diagnostics | Viracor SARS-CoV-2 assay DTC; 02/26/2021 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Individuals, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
01/14/2022 | University of Illinois Office of the Vice President for Economic Development and Innovation | covidSHIELD; 02/24/2021 | Real-time RT-PCR, Saliva, Serial Screening, Home Collection, Pooling, Multiple Targets | H | HCP, Patients, EUA Summary IFU (Home Collect) | None | None
01/13/2022 | Kaiser Permanente Mid-Atlantic States | KPMAS COVID-19 Test; 06/13/2020 | Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Viral Mutation Revision Letter - September 23, 2021 | None
01/12/2022 | Viracor Eurofins Clinical Diagnostics | Viracor SARS-CoV-2 assay; 04/06/2020 | Real-Time RT-PCR, Pooling, Screening, Pooled Serial Screening - Swab, Multiple Targets | H | HCP, Patients, EUA Summary | Pooling and Serial Testing Amendment for Certain Molecular Diagnostic Tests for SARS-CoV-2 - Amendment Letter; Viral Mutation Revision Letter - September 23, 2021 | None
01/11/2022 | SEASUN BIOMATERIALS | U-TOP COVID-19 Detection Kit; 04/27/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (September 1, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
01/11/2022 | DiaCarta, Inc | QuantiVirus SARS-CoV-2 Test kit; 04/08/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
01/11/2022 | SEASUN BIOMATERIALS, Inc. | AQ-TOP COVID-19 Rapid Detection Kit PLUS; 10/05/2020 | RT-LAMP, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
01/06/2022 | PreciGenome LLC | FastPlex Triplex SARS-CoV-2 detection kit (RT-Digital PCR); 06/25/2020 | RT-digital droplet PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
01/06/2022 | George Washington University Public Health Laboratory | GWU SARS-CoV-2 RT-PCR Test; 08/07/2020 | Real-time RT-PCR, Multiple Targets, Home Collection | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Viral Mutation Revision Letter - September 23, 2021 | None
01/05/2022 | Seasun Biomaterials, Inc. | AQ-TOP COVID-19 Rapid Detection Kit; 05/21/2020 | RT-LAMP, Single Target | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
01/04/2022 | KogeneBiotech Co., Ltd. | PowerChek 2019-nCoV Real-time PCR Kit; 07/13/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | None | None
12/17/2021 | UCSD BCG EXCITE Lab | UCSD EXCITE COVID-19 Test 12/17/2021 | Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | None | None
12/14/2021 | Quest Diagnostics Nichols Institute | Quest Diagnostics Collection Kit for COVID-19; 10/08/2021 | Home Collection Kit | N/A | EUA Summary, IFU | None | None
12/14/2021 | Quest Diagnostics Nichols Institute | Quest Diagnostics HA SARS-CoV-2 Assay; 07/15/2020 | TMA, chemiluminescent, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
12/14/2021 | Quest Diagnostics Nichols Institute | Quest Diagnostics RC COVID-19+Flu RT-PCR; 12/04/2020 | Real-time RT-PCR, Multi-analyte, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collection) | Viral Mutation Revision Letter - September 23, 2021 | None
11/29/2021 | Kwokman Diagnostics, LLC | Kwokman Diagnostics COVID-19 Home Collection Kit; 08/13/2021 | Home Collection Kit | N/A | IFU, EUA Summary | None | None
11/19/2021 | Aeon Global Health | Aeon Global Health SARS-CoV-2 Assay; 09/30/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
10/15/2021 | Gravity Diagnostics, LLC | Gravity Diagnostics SARS-CoV-2 RT-PCR Assay; 11/23/2020 | Real-time RT-PCR, Home Collection, Saliva, Screening, Multiple Targets | H | HCP, Patients, EUA Summary | None | None
10/14/2021 | LMSI, LLC (dba Lighthouse Lab Services) | CovidNow SARS-CoV-2 Assay; 10/14/2021 | Real-time RT-PCR, Home Collection, Screening, Single Target | H | HCP, Patients, IFU, IFU (Home Collect) | None | None
09/22/2021 | Southern California Permanente Medical Group | Kaiser Permanente High Throughput SARS-CoV-2 Assay; 04/19/2021 | Real-Time RT-PCR, Saliva, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | None | None
09/22/2021 | Life Sciences Testing Center | Life Sciences Testing Center COVID-19 Test; 09/22/2021 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | None | None
09/03/2021 | Color Health, Inc. | Color SARS-CoV-2 RT-LAMP Diagnostic Assay DTC; 03/19/2021 | Direct to Consumer (DTC), RT, LAMP, Home Collection, Screening, Multiple Targets | H | EUA Summary, Individuals, HCP | None | None
08/27/2021 | Abbott Diagnostics Scarborough, Inc. | ID NOW COVID-19; 03/27/2020 | RT, Isothermal amplification, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 21, 2020) | None
08/27/2021 | TBG Biotechnology Corp. | ExProbe SARS-CoV-2 Testing Kit; 06/10/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (January 6, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
08/27/2021 | GK Pharmaceuticals Contract Manufacturing Operations | GK ACCU-RIGHT SARS-CoV-2 RT-PCR KIT; 09/18/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
08/26/2021 | Gencurix, Inc. | GenePro SARS-CoV-2 Test; 06/23/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | None | None
08/25/2021 | Empire City Laboratories | ECL COVID TEST SYSTEM-1 08/25/2021 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, IFU (Home Collect), EUA Summary | None | None
08/25/2021 | Empire City Laboratories | ECL COVID TEST SYSTEM 08/25/2021 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, IFU (Home Collect), EUA Summary | None | None
08/23/2021 | The Mount Sinai Hospital, Center for Clinical Laboratories | Mount Sinai SARS-CoV-2 Assay 08/23/2021 | Real-time RT-PCR, Home Collection, Saliva, Screening, Multiple Targets | H | HCP, Patients, IFU (Home Collect), EUA Summary | None | None
08/18/2021 | Infinity BiologiX LLC | Infinity BiologiX TaqPath SARS-CoV-2 Assay; 04/10/2020 | Real-time RT-PCR, Home Collection, Saliva, Pooling, Multiple Targets | H | HCP, Patients, IFU (Home Collect) , EUA Summary | Letter Granting EUA Revision(s) (March 11, 2021); Letter Granting EUA Revision(s) (November 30, 2020) | Vault Health COVID-19 Test; USGC Saliva Test Kit, hims/hers Saliva Test Kit; BioIQ COVID-19 Saliva Test; Concentric by Ginkgo; 1health.io Zero Contact; Base10 Saliva Test Kit; Purlab. Saliva Test Kit; Reliant Saliva Test Kit; E7 Health Saliva Test Kit; miinehealth Saliva Test Kit; Maverick Saliva Test Kit; SDTL Saliva Test Kit; AZOVA At-Home COVID-19 Test Collection Kit; Wellness 4 Humanity SDNA-1000 Saliva Collection Kit
08/18/2021 | INVITES BIOCORE CO., LTD. | BioCore 2019-nCoV Real Time PCR Kit; 05/21/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
08/13/2021 | binx health, Inc. | binx health At-Home Nasal Swab COVID-19 Sample Collection Kit; 10/20/2020 | Home Collection Kit | N/A | EUA Summary, IFU | Letter Granting EUA Revision(s) (August 13, 2021) | None
08/04/2021 | Spectrum Solutions LLC | SDNA-1000 Saliva Collection Device; 10/08/2020 | Saliva Collection Device | N/A | EUA Summary, IFU | None | None
07/29/2021 | QIAGEN GmbH | QIAstat-Dx Respiratory SARS-CoV-2 Panel; 03/30/2020 | Real-time RT-PCR, Multi-analyte, Multiple Targets | H, M | HCP, Patients, IFU | None | None
07/28/2021 | Access Genetics, LLC | OraRisk COVID-19 RT-PCR; 07/17/2020 | Real-time RT-PCR, Home Collection, Single Target | H | HCP, Patients, EUA Summary | None | None
07/22/2021 | DiaSorin Molecular LLC | Simplexa COVID-19 Direct assay; 03/19/2020 | Real-time RT-PCR, Multiple Targets | H, M | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (March 26, 2020); Letter Granting EUA Amendment(s) (April 13, 2020); Letter Granting EUA Amendment(s) (June 4, 2020) | None
07/22/2021 | PathogenDx, Inc. | DetectX-Rv; 04/20/2021 | RT-PCR, DNA Microarray Hybridization, Multiple Targets | H | HCP, Patients, IFU | None | None
07/16/2021 | Ambry Genetics Laboratory | Ambry COVID-19 RT-PCR Test; 01/22/2021 | Real-time RT-PCR, Home Collection, Saliva, Multiple Targets | H | HCP, Patients, IFU (Home Collect), EUA Summary | Letter Granting EUA Revision(s) (March 3, 2021); Letter Granting EUA Revision(s) (July 16, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
07/15/2021 | KimForest Enterprise Co., Ltd. | KimForest SARS-CoV-2 Detection Kit v1; 09/21/2020 | Real-time RT-PCR, Single Target | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
07/14/2021 | ISPM Labs, LLC dba Capstone Healthcare | Genus SARS-CoV-2 Assay; 08/03/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | None | None
07/09/2021 | Color Health, Inc. | Color SARS-CoV-2 RT-LAMP Diagnostic Assay; 05/18/2020 | RT, LAMP, Home Collection, Screening, Multiple Targets | H | HCP, Patients, EUA Summary | Letter Granting EUA Revision(s) (August 28, 2020); Letter Granting EUA Revision(s) (July 9, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
07/08/2021 | Harvard University Clinical Laboratory (HUCL) | Quaeris SARS-CoV-2 Assay; 05/21/2021 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | None | None
07/01/2021 | Everlywell, Inc. | Everlywell COVID-19 & Flu Test Home Collection Kit; 07/01/2021 | Home Collection Kit, Multi-analyte | N/A | IFU, EUA Summary | None | None
06/24/2021 | 3B Blackbio Biotech India Ltd., a subsidiary of Kilpest India Ltd. | TRUPCR SARS-CoV-2 Kit; 06/18/2020 | Real-time RT-PCR, Saliva, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (July 21, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
06/24/2021 | Vela Operations Singapore Pte Ltd | ViroKey SARS-CoV-2 RT-PCR Test; 08/05/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Viral Mutation Revision Letter - September 23, 2021 | None
06/24/2021 | Clinomics USA Inc. | Clinomics TrioDx RT-PCR COVID-19 Test; 02/04/2021 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
06/24/2021 | Clinical Enterprise, Inc. | Clinical Enterprise SARS-CoV-2 RT-PCR Assay; 04/13/2021 | Real-time RT-PCR, Screening, Pooled Serial Screening - Swab, Multiple Targets | H | HCP, Patients, EUA Summary | Pooling and Serial Testing Amendment for Certain Molecular Diagnostic Tests for SARS-CoV-2 - Amendment Letter; Viral Mutation Revision Letter - September 23, 2021 | None
06/22/2021 | Fulgent Therapeutics | Fulgent COVID-19 by RT-PCR Test; 05/15/2020 | Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Amendment(s) (June 15, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
06/17/2021 | WREN Laboratories LLC | WREN Laboratories COVID-19 PCR Test; 08/03/2020 | Real-time RT-PCR, Home Collection, Saliva, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Viral Mutation Revision Letter - September 23, 2021 | None
06/17/2021 | MobileDetect Bio Inc. | MobileDetect Bio BCC19 (MD-Bio BCC19) Test Kit; 09/01/2020 | RT-LAMP, Multiple Targets | H, M | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
06/17/2021 | WREN Laboratories LLC | WREN Laboratories COVID-19 PCR Test DTC; 06/17/2021 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Saliva Screening, Multiple Targets | H | HCP, Individuals, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
06/17/2021 | WREN Laboratories LLC | WREN Laboratories COVID-19 Saliva Test Collection Kit DTC; 06/17/2021 | Direct to Consumer (DTC), Home Collection Kit, Saliva, Screening, Multiple Targets | N/A | Individuals, EUA Summary, IFU | None | None
06/10/2021 | Clinical Enterprise, Inc. | EmpowerDX COVID-19 Home Collection Kit DTC; 10/15/2020 | Home Collection Kit, Direct to Consumer (DTC), Screening | N/A | EUA Summary, Individuals, IFU | None | None
06/08/2021 | Applied BioCode, Inc. | BioCode SARS-CoV-2 Assay; 06/15/2020 | RT-PCR, Pooling, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (October 22, 2020); Letter Granting EUA Revision(s) (June 8, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
06/02/2021 | Synergy Diagnostic Laboratory, Inc., DBA SynergyDx | SynergyDx SARS-CoV-2 RNA Test DTC; 04/16/2021 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Individuals, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (June 2, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
06/02/2021 | Synergy Diagnostic Laboratory, Inc., DBA SynergyDx | SynergyDx SARS-CoV-2 RNA Test; 04/16/2021 | Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (June 2, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
05/28/2021 | BioTNS Co. Ltd. | COVID-19 RT-PCR Peptide Nucleic Acid (PNA) kit; 06/30/2020 | RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
05/28/2021 | Pro-Lab Diagnostics | Pro-AmpRT SARS-CoV-2 Test; 08/13/2020 | RT, Isothermal amplification, Single Target | H | HCP, Patient, EUA Summary | Letter Granting EUA Revision(s) (May 28, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
05/25/2021 | Quidel Corporation | Lyra Direct SARS-CoV-2 Assay; 05/18/2020 | Real-time RT-PCR, Single Target | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (January 26, 2021); Letter Granting EUA Revision(s) (May 25, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
05/21/2021 | InBios International, Inc | Smart Detect SARS-CoV-2 rRT-PCR Kit; 04/07/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (June 3, 2020); Letter Granting EUA Amendment(s) (August 10, 2020); Letter Granting EUA Revision(s) (August 24, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
05/20/2021 | Wadsworth Center, New York State Department of Public Health | New York SARS-CoV-2 Real-time Reverse Transcriptase (RT)-PCR Diagnostic Panel; 02/29/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (March 15, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
05/19/2021 | The Kroger Co. | Kroger Health COVID-19 Test Home Collection Kit; 06/30/2020 | Home Collection Kit, Direct to Consumer (DTC), Screening | N/A | Individuals, IFU, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
05/17/2021 | Phosphorus Diagnostics LLC | Phosphorus COVID-19 RT-qPCR Test; 06/04/2020 | Real-time RT-PCR, Home Collection, Saliva, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect), IFU (Clinic) | Letter Granting EUA Amendment(s) (June 24, 2020); Letter Granting EUA Revision(s) (March 1, 2021); Viral Mutation Revision Letter - September 23, 2021 | Wheeler Labs COVID-19 RT-qPCR Test
05/17/2021 | Phosphorus Diagnostics LLC | Pinpoint by Phosphorus COVID-19 Test Home Collection Kit DTC; 05/17/2021 | Direct to Consumer (DTC), Home Collection Kit, Saliva, Screening, Multiple Targets | N/A | Individual, EUA Summary, IFU | None | None
05/17/2021 | Phosphorus Diagnostics LLC | Phosphorous COVID19 RT-qPCR Test DTC; 05/17/2021 | Real-time RT-PCR, Direct to Consumer (DTC), Screening, Salvia, Home Collection, Multiple Targets | H | HCP, Individuals, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
05/10/2021 | Jiangsu Bioperfectus Technologies Co., Ltd. | COVID-19 Coronavirus Real Time PCR Kit; 06/18/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (December 29, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
05/06/2021 | Quadrant Biosciences Inc. | Clarifi COVID-19 Test Kit; 09/22/2020 | Real-time RT-PCR, Saliva, Pooling, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
05/04/2021 | Agena Bioscience, Inc. | MassARRAY SARS-CoV-2 Panel; 10/26/2020 | RT-PCR, chip array and MALDI-TOF Mass Spec, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (November 30, 2020); Letter Granting EUA Revision(s) (January 27, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
04/13/2021 | Clinical Enterprise, Inc. | Clinical Enterprise SARS-CoV-2 RT-PCR Assay DTC; 04/13/2021 | Direct to Consumer (DTC), Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Individuals, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
04/12/2021 | PerkinElmer Genomics | PerkinElmer SARS-CoV-2 RT-qPCR Reagent Kit; 04/12/2021 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
04/02/2021 | Alimetrix, Inc. | Alimetrix SARS-CoV-2 RT-PCR Assay; 09/30/2020 | RT-PCR, Microarray Hybridization, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Viral Mutation Revision Letter - September 23, 2021 | None
04/01/2021 | P23 Labs, LLC. | P23 Labs TaqPath SARS-CoV-2 Assay; 05/21/2020 | Real-time RT-PCR, Home Collection, Saliva, Multiple Targets | H | HCP, Patients, IFU1 (Home Collect), IFU2 (Home Collect) EUA Summary | Letter Granting EUA Amendment(s) (June 17, 2020); Viral Mutation Revision Letter - September 23, 2021 | AZOVA P23 At-Home COVID-19 Test Collection Kit; binx health (powered by P23) At-home Saliva COVID-19 Test Collection Kit for the Group Setting
02/08/2021 | QDx Pathology Services | QDX SARS-CoV-2 Assay; 08/25/2020 | Real-time RT-PCR, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (February 8, 2021); Viral Mutation Revision Letter - September 23, 2021 | None
02/05/2021 | Access Bio, Inc. | CareStart COVID-19 MDx RT-PCR; 07/07/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (February 09, 2021); Viral Mutation Revision Letter - September 23, 2021 | KarmaCare COVID-19 MDx RT-PCR; AQGene COVID-19 MDx RT-PCRv
01/29/2021 | Diagnostic Solutions Laboratory, LLC | DSL COVID-19 Assay; 06/25/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
01/29/2021 | Sandia National Laboratories | SNL-NM 2019 nCoV Real-Time RT-PCR Diagnostic Assay; 07/27/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
01/28/2021 | Alpha Genomix Laboratories | Alpha Genomix TaqPath SARS-CoV-2 Combo Assay; 08/10/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
01/28/2021 | BayCare Laboratories, LLC | BayCare SARS-CoV-2 RT PCR Assay; 08/31/2020 | Real-time RT-PCR, Pooling, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
01/22/2021 | NeuMoDx Molecular, Inc. | NeuMoDx SARS-CoV-2 Assay; 03/30/2020 | RT-PCR, Collection Kit, Saliva, Multiple Targets | H, M | HCP, Patients, IFU, IFU (Collect) | Letter Granting EUA Amendment(s) (April 23, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
01/22/2021 | Express Gene LLC, DBA: Express Gene Molecular Diagnostics Laboratory | Express Gene 2019-nCoV RT-PCR Diagnostic Panel; 05/22/2020 | Real-time RT-PCR, Collection Kit, Saliva, Multiple Targets | H | HCP, Patients, EUA Summary, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
01/19/2021 | Hospital of the University of Pennsylvania | BD MAX COVID-19 ASSAY (Authorized by HHS/OASH); 01/19/2021 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
01/05/2021 | Primerdesign Ltd. | Primerdesign Ltd COVID-19 genesig Real-Time PCR assay; 03/20/2020 | Real-time RT-PCR, Single Target | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 8, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
12/28/2020 | Atila BioSystems, Inc. | iAMP COVID-19 Detection Kit; 04/10/2020 | RT, Isothermal amplification, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (July 18, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
12/28/2020 | SolGent Co., Ltd | DiaPlexQ Novel Coronavirus (2019-nCoV) Detection Kit; 05/21/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
12/28/2020 | Gene By Gene | Gene By Gene SARS-CoV-2 Detection Test; 07/07/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
12/28/2020 | BioSewoom, Inc. | Real-Q 2019-nCoV Detection Kit; 07/09/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
12/28/2020 | Solaris Diagnostics | Solaris Multiplex SARS-CoV-2 Assay; 08/10/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
12/28/2020 | T2 Biosystems, Inc. | T2SARS-CoV-2 Panel; 08/31/2020 | RT, amplification, T2 Magnetic resonance, Single Target | H, M | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
12/28/2020 | OPTOLANE Technologies, Inc. | Kaira 2019-nCoV Detection Kit; 09/01/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
12/28/2020 | UMass Memorial Medical Center | UMass Molecular Virology Laboratory 2019-nCoV rRT-PCR Dx Panel; 10/01/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
12/11/2020 | ResearchDx, Inc., DBA Pacific Diagnostics | PacificDx Covid-19; 12/11/2020 | TMA, chemiluminescent, Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
12/09/2020 | DxTerity Diagnostics, Inc. | DxTerity SARS-CoV-2 RT-PCR Test; 08/21/2020 | Real-time RT-PCR, Saliva, Multiple Targets | H | HCP, Patients, EUA Summary | Letter Granting EUA Revision(s) (December 9, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
11/24/2020 | Stanford Health Care Clinical Virology Laboratory | SARS-CoV-2 RT-PCR Assay; 04/08/2020 | Real-time RT-PCR, Home Collection, Single Target | H | HCP, Patients, EUA Summary, IFU (Home Collection) | Viral Mutation Revision Letter - September 23, 2021 | None
10/31/2020 | Beijing Wantai Biological Pharmacy Enterprise Co., Ltd. | Wantai SARS-CoV-2 RT-PCR Kit; 09/09/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Revision(s) (October 31, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
10/28/2020 | DNA Genotek Inc. | OMNIgene·ORAL OM-505 and OME-505 (OMNIgene·ORAL) saliva collection devices; 10/14/2020 | Saliva Collection Device | N/A | EUA Summary, IFU | None | None
10/22/2020 | Helix OpCo LLC | Helix COVID-19 Test; 07/23/2020 | Real-time RT-PCR, Home Collection, Screening, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Viral Mutation Revision Letter - September 23, 2021 | None
10/08/2020 | University of California, Los Angeles (UCLA) | UCLA SwabSeq COVID-19 Diagnostic Platform; 10/06/2020 | RT-PCR and Sequencing, Single Target | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
10/02/2020 | Cuur Diagnostics | Cuur Diagnostics SARS-CoV-2 Molecular Assay; 08/26/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
09/24/2020 | Acupath Laboratories, Inc. | Acupath COVID-19 Real-Time (RT-PCR) Assay; 06/29/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
09/21/2020 | HealthQuest Esoterics | HealthQuest Esoterics TaqPath SARS-CoV-2 Assay; 06/23/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
09/21/2020 | Boston Heart Diagnostics | Boston Heart COVID-19 RT-PCR Test; 07/16/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Letter Granting EUA Revision(s) (September 2, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
09/21/2020 | Eli Lilly and Company | Lilly SARS-CoV-2 Assay; 07/27/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Letter Granting EUA Revision(s) (September 21, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
09/21/2020 | Ethos Laboratories | Ethos Laboratories SARS-CoV-2 MALDI-TOF Assay; 08/03/2020 | RT-PCR and MALDI-TOF Mass Spec., Home Collection, Multiple Targets | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (August 11, 2020); Letter Granting EUA Revision(s) (September 18, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
09/21/2020 | Patients Choice Laboratories, LLC | PCL SARS-CoV-2 Real-Time RT-PCR Assay; 08/28/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
08/18/2020 | GenMark Diagnostics, Inc. | ePlex SARS-CoV-2 Test; 03/19/2020 | RT-PCR and electrochemical detection, Multiple Targets | H, M | HCP, Patients, IFU | Letter Granting EUA Revision(s) (August 18, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
08/17/2020 | ZhuHai Sinochips Bioscience Co., Ltd. | COVID-19 Nucleic Acid RT-PCR Test Kit; 08/17/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
08/08/2020 | Trax Management Services Inc. | PhoenixDx 2019-CoV; 04/20/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendments (May 11, 2020); Letter Granting EUA Amendment(s) (August 8, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
08/06/2020 | Helix OpCo LLC (dba Helix) | Helix COVID-19 NGS Test; 08/06/2020 | Sequencing, Single Target | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
08/03/2020 | Poplar Healthcare | Poplar SARS-CoV-2 TMA Pooling assay; 08/03/2020 | TMA, chemiluminescent, Pooling, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
07/31/2020 | University of California San Diego Health | UCSD RC SARS-CoV-2 Assay; 07/31/2020 | Real-time RT-PCR, Pooling, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
07/30/2020 | Clinical Reference Laboratory, Inc. | CRL Rapid Response; 07/30/2020 | Real-time RT-PCR, Home Collection, Saliva, Single Target | H | HCP, Patients, EUA Summary, IFU (Home Collect) | Viral Mutation Revision Letter - September 23, 2021 | None
07/24/2020 | Jiangsu CoWin Biotech Co., Ltd. | Novel Coronavirus (SARS-CoV-2) Fast Nucleic Acid Detection Kit (PCR-Fluorescence Probing); 07/24/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
07/13/2020 | Compass Laboratory Services, LLC | Compass Laboratory Services SARS-CoV2 Assay; 07/13/2020 | Real-time RT-PCR, Home Collection, Single Target | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
07/09/2020 | UCSF Health Clinical Laboratories, UCSF Clinical Labs at China Basin | SARS-CoV-2 RNA DETECTR Assay; 07/09/2020 | RT-LAMP, Single Target | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
06/26/2020 | Inform Diagnostics, Inc. | Inform Diagnostics SARS-CoV-2 RT-PCR Assay; 06/26/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
06/23/2020 | University of Alabama at Birmingham Fungal Reference Lab | FRL SARS CoV-2 Test; 06/23/2020 | Real-time RT-PCR, Single Target | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
06/17/2020 | The Ohio State University Wexner Medical Center | OSUWMC COVID-19 RT-PCR test; 06/17/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter - September 23, 2021 | None
05/08/2020 | Gnomegen LLC | Gnomegen COVID-19-RT-qPCR Detection Kit; 05/08/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None
04/28/2020 | Gnomegen LLC | Gnomegen COVID-19 RT-Digital PCR Detection Kit; 04/06/2020 | Real-time RT-digital PCR, Multiple Targets | H | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (April 28, 2020); Viral Mutation Revision Letter - September 23, 2021 | None
04/16/2020 | GenoSensor, LLC | GS"¢ COVID-19 RT-PCR KIT; 04/16/2020 | Real-time RT-PCR, Multiple Targets | H | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021 | None

^1^ Authorized settings include the following:

• H - Laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, that meet requirements to perform high complexity tests.

• M - Laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, that meet requirements to perform moderate complexity tests.

• W - Patient care settings operating under a CLIA Certificate of Waiver.

^2^ Authorization Documents include the Healthcare Provider (HCP) and Patient Fact Sheets and either the Manufacture Instructions/Package Insert (abbreviated to IFU) or the EUA Summary.

^3^ Abbreviations:

• RT-PCR = reverse transcriptase polymerase chain reaction;

• RT = reverse transcriptase;

• LAMP = loop-mediated isothermal amplification;

• MALDI-TOF = Matrix Assisted Laser Desorption/Ionization - Time of Flight;

• TMA = Transcription Mediated Amplification;

• qSTAR = Selective Temperature Amplification Reaction;

• CRISPR = clustered regularly interspaced short palindromic repeats;

#### Pooling and Serial Testing Amendment for Certain Molecular Diagnostic Tests for SARS-CoV-2

Amendment Letter

Appendix J - Sample Updated Fact Sheet for Health Care Providers

Appendix K - Sample Updated Fact Sheet for Patients

Date Added to Exhibit 1 | EUA Holder | Test Name | Indication(s)*
01/28/2022 | Vela Operations Singapore Pte. Ltd | ViroKey SARS-CoV-2 RT-PCR Test v2.0 | Media: Up to 3 (Appendix D)
06/24/2021 | Clinical Enterprise, Inc. | Clinical Enterprise SARS-SoV-2-RT-PCR Assay | Swab: Up to 10 (Appendix C)
06/23/2021 | Viracor Eurofins Clinical Diagnostics | Viracor SARS-CoV-2 assay | Swab: Up to 10 (Appendix C)
06/22/2021 | Biomeme, Inc. | Biomeme SARS-CoV-2 Real-Time RT-PCR Test | Swab: Up to 10 (Appendix C)Media: Up to 5 (Appendix G)
06/15/2021 | Clinical Research Sequencing Platform (CRSP), LLC at the Broad Institute of MIT and Harvard | CRSP SARS-CoV-2 Real-time Reverse Transcriptase (RT)-PCR Diagnostic Assay (Version 3) | Swab: Up to 10 (Appendix C)

* The indications in each appendix (A-H) differ in the number of specimens that can be pooled (up to 3, up to 5, or up to 10) and the type of pooling that can be done (media or swab pooling).

Tests authorized for Swab Pooling are authorized for:

• Qualitative detection of RNA from SARS-CoV-2 in pooled samples containing up to [3, 5, or 10, depending on the applicable appendix] individual human anterior nasal swabs placed in a single vial containing transport media after being collected by a healthcare provider (HCP) or self-collected under the supervision of an HCP from any individual, including individuals without symptoms or other reasons to suspect COVID-19, when tested at least once per week as part of a serial testing program.

This indication is authorized for use in laboratories certified under CLIA to perform high complexity tests except tests authorized for use in specific named or designated laboratories can only be used in such laboratories.

Tests authorized for Media Pooling are authorized for:

• Qualitative detection of RNA from SARS-CoV-2 in pooled samples containing aliquots of transport media from up to [3, 5, or 10, depending on the applicable appendix] individual human anterior nasal swab specimens that were collected by a healthcare provider (HCP) or self-collected under the supervision of an HCP from any individual and placed in individual vials containing transport media, including individuals without symptoms or other reasons to suspect COVID-19, when tested as part of a serial testing program including testing at least once per week.

This indication is authorized for use in laboratories certified under CLIA to perform high complexity tests except tests authorized for use in specific named or designated laboratories can only be used in such laboratories.

#### Umbrella EUA for SARS-CoV-2 Molecular Diagnostic Tests for Serial Testing

Tests will be added to Exhibit 1 of this EUA following submission of a complete notification to the FDA with the information required by the EUA, including self-certifying that the applicable validation has been completed, and confirmation by the FDA that the required documentation has been submitted. Being added to Exhibit 1 does not necessarily mean that the FDA has reviewed the underlying validation data submitted or confirmed that the test is appropriately validated.

EUA Letter of Authorization - Umbrella EUA for SARS-CoV-2 Molecular Diagnostic Tests for Serial Testing

Appendix L - Fact Sheet for Health Care Providers (Template)

Appendix M - Fact Sheet for Patients (Template)

Appendix N - Test Summary (Template)

##### Exhibit 1 of the Umbrella EUA for SARS-CoV-2 Molecular Diagnostic Tests for Serial Testing

This exhibit includes information for the RT-PCR molecular diagnostic tests for SARS-CoV-2 authorized by this umbrella EUA for SARS-CoV-2 Molecular Diagnostic Tests for Serial Testing. All tests authorized by this umbrella EUA are required to have at least two viral targets on the SARS-CoV-2 genome. Tests with multiple targets are more likely to continue to perform well when new variants emerge.

Date Added to Exhibit 1 | EUA Holder | Test Name | Additional Indication(s)* | Authorization Documents**
01/05/2023 | Scope Molecular Laboratory | Scope Molecular Laboratory SARS nCoV-2019 Multiplexed Assay | None5 | Test Summary, HCP, Patients
11/02/2022 | Rize Laboratory | Rize Laboratory SARS nCoV-2019 Multiplexed Assay | None | Test Summary, HCP, Patients
08/01/2022 | Helix Diagnostics | Helix Diagnostics SARS nCoV-2019 Multiplexed Assay | None | Test Summary, HCP, Patients
02/17/2022 | Applied DNA Clinical Labs, LLC. | Linea 2.0 COVID-19 Assay | Media: Up to n=5 (Appendix H) | Test Summary, HCP, Patients

* All tests authorized under this Umbrella EUA are authorized for (as described in appendix A):

• Qualitative detection of RNA from SARS-CoV-2 in individual human anterior nasal swab samples collected by a healthcare provider (HCP) or self-collected under the supervision of an HCP from individuals, including individuals without symptoms or other reasons to suspect COVID-19, when tested at least once per week. Each test is authorized for use in the single laboratory that developed the authorized test and that is certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, and meets requirements to perform high complexity tests.

• Additional indications included in appendices (B-K) differ in the number of specimens that can be pooled (up to 3, up to 5, or up to 10), the type of pooling that can be done (media or swab pooling), and the inclusion of use with home collected specimens.

Tests authorized for Swab Pooling (appendices B-D) are authorized for:

• Qualitative detection of RNA from SARS-CoV-2 in individual human anterior nasal swabs or pooled samples containing up to [3, 5, or 10, depending on the applicable appendix] individual human anterior nasal swabs placed in a single vial after being collected by a healthcare provider (HCP) or self-collected under the supervision of an HCP from individuals, including individuals without symptoms or other reasons to suspect COVID-19, when tested at least once per week. This test is authorized for use in the single laboratory that developed the test and that is certified under CLIA and meets requirements to perform high complexity tests.

Tests authorized for Media Pooling (appendices E-I) are authorized for:

• Qualitative detection of RNA from SARS-CoV-2 in individual human anterior nasal swabs or pooled samples containing aliquots of media from up to [3, 5, or 10, depending on the applicable appendix] individual human anterior nasal swab specimens that were collected by a healthcare provider (HCP) or self-collected under the supervision of an HCP from individuals, including individuals without symptoms or other reasons to suspect COVID-19 and placed in individual vials when tested at least once per week. This test is authorized for use in the single laboratory that developed the test and that is certified under CLIA and meets requirements to perform high complexity tests.

Tests authorized for Home Specimen Collection (appendices J-K) are authorized for the applicable above indications with the following addition regarding specimen collection:

• {or self-collected at home using the following authorized home collection kit(s): [specific named home collection kit(s) with which the test was validated] when used consistent with the home collection kit's authorization for individuals tested at least once per week}

** Authorization Documents include the Test Summary, Fact Sheet for Healthcare Providers (HCP) and Fact Sheet for Patients.

#### EUA for Molecular Diagnostic Tests for SARS-CoV-2 Developed And Performed By Laboratories Certified Under CLIA To Perform High Complexity Tests

EUA Letter of Authorization - Laboratories Who Have Developed a Molecular-Based Test (LDTs) for Coronavirus Disease 2019 (COVID-19)

Fact Sheet for Healthcare Providers

Fact Sheet for Patients

See Appendix A table below for a current list of included laboratories and their LTDs

The table below includes information for the high complexity molecular-based laboratory developed SARS-CoV-2 assays authorized by this Umbrella EUA during the COVID-19 public health emergency.

##### Appendix A: Authorized Molecular-Based Laboratory Developed Tests for Detection of Nucleic Acid from SARS-CoV-2

The table below includes information for the high complexity molecular-based laboratory developed SARS-CoV-2 assays authorized by this EUA during the COVID-19 public health emergency.

To see additional authorization documents, such as letters granting EUA amendments or revisions, for a specific test, select the plus (+) button beside the “Date Last Updated” for each test.

All authorized devices in the table below are assigned the QJR product code.

Date Last Updated | Laboratory | Letter Granting Inclusion under EUA and Original Issue Date | EUA Summary | Other Documents
03/28/2023 | Integrity Laboratories | SARS-CoV-2 Assay04/13/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
03/22/2023 | UTMG Pathology Laboratory | UTHSC/UCH SARS-CoV-2-RT-PCR Assay05/03/2020 | EUA Summary | Letter Granting EUA Amendment(s) (July 22, 2020); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) - March 22, 2023
03/07/2023 | Yale New Haven Hospital,Clinical Virology Laboratory | SARS-CoV-2 PCR test03/31/2020 | EUA Summary | Letter Granting EUA Amendment(s) (June 4, 2020); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (March 07, 2023)
03/07/2023 | Southwest Regional PCR Laboratory LLC. dba MicroGen DX | COVID-19 Key04/23/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
08/24/2022 | Nationwide Children's Hospital | SARS-CoV-2 Assay04/27/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
05/03/2022 | Cormeum Laboratory Services | Cormeum SARS-CoV-2 Assay06/12/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (May 3, 2022)
01/29/2021 | CSI Laboratories | CSI SARS-CoV-2 RT PCR Test06/01/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
01/28/2021 | AIT Laboratories | SARS-CoV-2 Assay04/24/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
12/28/2020 | Biocollections Worldwide, Inc. | Biocollections Worldwide SARS-Co-V-2 Assay05/07/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
09/22/2020 | Diatherix Eurofins Laboratory | SARS-CoV-2 PCR Test 04/22/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
09/21/2020 | Hackensack University Medical Center (HUMC) Molecular Pathology Laboratory | CDI Enhanced COVID-19 Test04/15/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
09/21/2020 | CirrusDx Laboratories | CirrusDx SARS-CoV-2 Assay04/15/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
09/14/2020 | Columbia University Laboratory of Personalized Genomic Medicine | TRIPLEX CII-SARS-CoV-2 rRT-PCR TEST05/12/2020 | EUA Summary | Letter Granting EUA Revision(s) (September 14, 2020); Viral Mutation Revision Letter - September 23, 2021
06/10/2020 | Warrior Diagnostics, Inc. | Warrior Diagnostics SARS-CoV-2 Assay06/10/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
06/04/2020 | Altru Diagnostics, Inc. | Altru Dx SARS-CoV-2 RT-PCR assay04/30/2020 | EUA Summary | Letter Granting EUA Amendment(s) (June 4, 2020); Viral Mutation Revision Letter - September 23, 2021
05/22/2020 | Avera Institute for Human Genetics | Avera Institute for Human Genetics SARS-CoV-2 Assay05/22/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
05/13/2020 | One Health Laboratories, LLC | SARS-CoV-2 Real-Time RT-PCR-Test05/13/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
04/24/2020 | Ultimate Dx Laboratory | UDX SARS-CoV-2 Molecular Assay *04/24/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
04/10/2020 | Orig3n, Inc. | Orig3n 2019 Novel Coronavirus (COVID-19) Test04/10/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
04/10/2020 | Specialty Diagnostic (SDI) Laboratories | SDI SARS-CoV-2 Assay *04/10/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021
04/02/2020 | Infectious Disease Diagnostics Laboratory - Children's Hospital of Philadelphia | SARS-CoV-2 RT-PCR test *04/02/2020 | EUA Summary | Viral Mutation Revision Letter - September 23, 2021

^1^ The tests listed in this table are all molecular-based tests for COVID-19 and the authorized setting is for use in the identified laboratory that is certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, to perform high complexity tests.

### Individual EUAs for Antigen Diagnostic Tests for SARS-CoV-2

Authorized EUA devices in the table below for SARS-CoV-2 antigen diagnostic tests are assigned the QKP product code. Antigen multi-analyte respiratory panel tests authorized in the table below are assigned the QMN product code.

Date EUA Issued or Last Updated | Entity | Diagnostic (Most Recent Letter of Authorization) and Date EUA Originally Issued | Attributes | Authorized Setting(s)^1^ | Authorization Documents^2^ | Other Documents | Other Brand Name(s)
11/18/2024 | Nano-Ditech Corporation | Nano-Check Influenza+COVID-19 Dual Test 07/08/2024 | Lateral Flow, Visual Read, Multi-analyte, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (November 18, 2024) | None
10/23/2024 | Princeton BioMeditech Corp. | ViraDx SARS-CoV-2/Flu A+B Rapid Antigen Test 09/08/2023 | Lateral Flow, Visual Read, Multi-analyte, Single Target | H, M, W | HCP, Patient, IFU | Letter Granting EUA Revision(s) (October 23, 2024) | None
10/18/2024 | OSANG LLC | OHC COVID-19/Flu Antigen Test Pro 03/21/2024 | Lateral Flow, Visual Read, Multi-analyte, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (May 21, 2024) Letter Granting EUA Revision(s) (October 18, 2024) | None
10/18/2024 | OSANG LLC | QuickFinder COVID-19/Flu Antigen Self Test 04/03/2024 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Multi-analyte, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (May 21, 2024) Letter Granting EUA Revision(s) (October 18, 2024) | None
10/09/2024 | iHealth Labs, Inc. | iHealth COVID-19/Flu A&B Rapid Test 05/07/2024 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Multi-analyte, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (September 12, 2024) Letter Granting EUA Revision(s) (October 9, 2024) | None
09/27/2024 | Healgen Scientific, LLC | Healgen COVID-19/Flu A&B Ag Combo Rapid Test Cassette (Swab) 06/10/2024 | Lateral Flow, Visual Read, Multi-analyte, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (September 27, 2024) | None
09/26/2024 | CorDx, Inc. | CorDx Tyfast Flu A/B & COVID-19 Multiplex Rapid Test 03/21/2024 | Lateral Flow, Visual Read, Multi-analyte, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (May 31, 2024) Letter Granting EUA Revision(s) (September 26, 2024) | None
09/26/2024 | CorDx, Inc. | CorDx TyFast Flu A/B & COVID-19 At Home Multiplex Rapid Test 04/05/2024 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Multi-analyte, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (May 31, 2024) Letter Granting EUA Revision(s) (September 26, 2024) | None
09/24/2024 | OraSure Technologies, Inc. | InteliSwab COVID-19 Rapid Test 06/04/2021 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening , Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Viral Mutation Revision Letter - September 23, 2021 Letter Granting EUA Revision(s) (August 3, 2022) Repeat Testing Revision Letter - November 1, 2022 Letter Granting EUA Revision(s) (March 23, 2023) Letter Granting EUA Revision(s) (September 26, 2023) | None
09/12/2024 | SD Biosensor, Inc. | STANDARD Q COVID-19 Ag Test 2.0 09/29/2023 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (May 1, 2024) Letter Granting EUA Revision(s) (September 12, 2024) | None
09/12/2024 | iHealth Labs, Inc. | iHealth COVID-19/Flu A&B Rapid Test Pro 05/31/2024 | Lateral Flow, Visual Read, Multi-analyte, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (September 12, 2024) | None
09/04/2024 | SEKISUI Diagnostics, LLC | OSOM Flu SARS-CoV-2 Combo Test 02/29/2024 | Lateral Flow, Visual Read, Multi-analyte, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (September 4, 2024) | None
09/04/2024 | SEKISUI Diagnostics, LLC | OSOM Flu SARS-CoV-2 Combo Home Test 2/29/2024 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Multi-analyte, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (September 4, 2024) | None
07/23/2024 | ACON Laboratories, Inc. | Flowflex Plus COVID-19 and Flu A/B Home Test 07/23/2024 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Multi-analyte, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | None | None
07/10/2024 | Genabio Diagnostics Inc. | Genabio COVID-19 Rapid Self-Test Kit07/08/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (August 23, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (July 10, 2024) | None
07/08/2024 | Maxim Biomedical, Inc. | MaximBio ClearDetect COVID-19 Antigen Home Test01/19/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (March 30, 2022); Letter Granting EUA Revision(s) (July 22, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 16, 2022); Letter Granting EUA Revision(s) (January 09, 2023); Letter Granting EUA Revision(s) (March 21, 2023); Letter Granting EUA Revision(s) (July 05, 2023); Letter Granting EUA Revision(s) (October 26, 2023); Letter Granting EUA Revision(s) (July 10, 2024) | None
07/02/2024 | Wondfo USA Co., Ltd. | WELLlife COVID-19 / Influenza A&B Test 04/19/2024 | Lateral Flow, Visual Read, Multi-analyte, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (July 2, 2024) | None
07/02/2024 | Wondfo USA Co., Ltd | WELLlife COVID-19 / Influenza A&B Home Test 04/30/2024 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Multi-analyte, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (May 21, 2024); Letter Granting EUA Revision(s) (July 2, 2024) | None
07/01/2024 | Advin Biotech Inc. | Advin COVID-19 Antigen Test @Home 12/22/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (September 19, 2023); Letter Granting EUA Revision(s) (January 03, 2024); Letter Granting EUA Revision(s) (March 22, 2024); Letter Granting EUA Revision(s) (July 1, 2024) | None
05/24/2024 | Watmind USA | Speedy Swab Rapid COVID-19 + Flu A&B Antigen Self-Test 05/24/2024 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Multi-analyte, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | None | None
05/08/2024 | Watmind USA | Speedy Swab Rapid COVID-19 + Flu A&B Antigen Test 05/08/2024 | Lateral Flow, Visual Read, Multi-analyte, Single Target | H, M, W | HCP, Patients, IFU | None | None
04/30/2024 | CTK Biotech, Inc. | ImmuView COVID-19 Antigen Home Test 12/20/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (April 30, 2024) | None
02/01/2024 | iHealth Labs, Inc. | iHealth COVID-19 Antigen Rapid Test Pro; 01/14/2022 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 27, 2022) | None
01/23/2024 | Xiamen Boson Biotech Co., Ltd. | Rapid SARS-CoV-2 Antigen Test Card; 04/06/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (September 2, 2022); Letter Granting EUA Revision(s) (October 18, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 22, 2022); Letter Granting EUA Revision(s) (May 5, 2023); Letter Granting EUA Revision(s) (December 21, 2023); Letter Granting EUA Revision(s) (January 23, 2024) | None
12/11/2023 | SD Biosensor, Inc. | Pilot COVID-19 At-Home Test12/24/2021 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target, Telehealth Proctor Supervised (optional) | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (March 7, 2022); Letter Granting EUA Revision(s) (April 28, 2022); Letter Granting EUA Revision(s) (June 24, 2022); Letter Granting EUA Revision(s) (October 14, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 11, 2023) | None
11/21/2023 | Abbott Diagnostics Scarborough, Inc. | BinaxNOW COVID-19 Antigen Self Test03/31/2021 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (January 7, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 21, 2022) | None
11/15/2023 | SEKISUI Diagnostics, LLC. | OSOM COVID-19 Antigen Rapid Test 09/24/2021 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (August 24, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (November 15, 2023) | None
09/26/2023 | OraSure Technologies, Inc. | InteliSwab COVID-19 Rapid Test Rx06/04/2021 | Lateral Flow, Visual Read, Prescription Home Testing, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (August 3, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (March 23, 2023); Letter Granting EUA Revision(s) (September 26, 2023) | None
09/26/2023 | OraSure Technologies, Inc. | InteliSwab COVID-19 Rapid Test Pro06/04/2021 | Lateral Flow, Visual Read, Serial Screening , Single Target | H, M, W | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (August 3, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (January 17, 2023); Letter Granting EUA Revision(s) (March 23, 2023); Letter Granting EUA Revision(s) (April 4, 2023); Letter Granting EUA Revision(s) (August 22, 2023); Letter Granting EUA Revision(s) (September 26, 2023) | None
09/26/2023 | OSANG LLC | OHC COVID-19 Antigen Self Test 04/06/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (August 19, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (February 21, 2023); Letter Granting EUA Revision(s) (March 15, 2023); Letter Granting EUA Revision(s) (September 26, 2023) | QuickFinder COVID-19 Antigen Self Test
09/20/2023 | Biosynchronicity Corporation | C-Sync COVID-19 Antigen Test 03/24/2023 | Lateral Flow, Visual Read, Serial Screening, Multiple Targets | H, M, W | HCP, Patient, IFU | Letter Granting EUA Revision(s) (July 24, 2023); Letter Granting EUA Revision(s) (September 20, 2023) | None
09/20/2023 | BioTeke USA, LLC | Bio-Self COVID-19 Antigen Home Test05/22/2023 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (September 20, 2023) | None
08/24/2023 | iHealth Labs, Inc. | iHealth COVID-19 Antigen Rapid Test11/05/2021 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target, Telehealth Proctor Supervised (optional) | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (March 29, 2022); Letter Granting EUA Revision(s) (April 4, 2022); Letter Granting EUA Revision(s) (July 8, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (January 11, 2023) | GoToKnow COVID-19 Antigen Rapid Test
08/15/2023 | LumiraDx UK Ltd. | LumiraDx SARS-CoV-2 Ag Test08/18/2020 | Microfluidic Immunofluorescence Assay, Instrument Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (January 26, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (February 17, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (March 29, 2023) | None
08/08/2023 | Quidel Corporation | Sofia 2 Flu + SARS Antigen FIA10/02/2020 | Lateral Flow, Fluorescence, Instrument Read, Multi-Analyte, Single Target | H, M, W | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (March 31, 2023) | None
07/17/2023 | Immunostics Inc. | Swab-N-Go Home Test COVID-19 Ag 07/17/2023 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | None | None
06/28/2023 | Princeton BioMeditech Corp. | Status COVID-19 Antigen Rapid Test for Home Use04/24/2023 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (June 28, 2023) | None
06/16/2023 | PHASE Scientific International, Ltd. | INDICAID COVID-19 Rapid Antigen At-Home Test 03/16/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (May 12, 2022); Letter Granting EUA Revision(s) (August 12, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 22, 2022); Letter Granting EUA Revision(s) (June 16, 2023) | None
06/16/2023 | PHASE Scientific International, Ltd. | INDICAID COVID-19 Rapid Antigen Test07/28/2021 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (January 14, 2022); Letter Granting EUA Revision(s) (February 22, 2022); Letter Granting EUA Revision(s) (May 12, 2022); Letter Granting EUA Revision(s) (August 12, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 28, 2022); Letter Granting EUA Revision(s) (June 16, 2023) | None
06/09/2023 | SEKISUI Diagnostics, LLC. | OSOM COVID-19 Antigen Home Test11/17/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | None | None
05/18/2023 | QIAGEN GmbH | QIAreach SARS-CoV-2 Antigen08/05/2021 | Digital Lateral Flow, Fluorescence, Instrument Read, Single Target | H, M | HCP, Patients, IFU | Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (May 18, 2023) | None
05/12/2023 | Princeton BioMeditech Corp. | Status COVID-19/Flu A&B02/04/2021 | Lateral Flow, Visual Read, Multi-analyte, Single Target | H, M, W | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (March 21, 2023); Letter Granting EUA Revision(s) (May 12, 2023) | None
05/12/2023 | Becton, Dickinson and Company (BD) | BD Veritor System for Rapid Detection of SARS-CoV-2 & Flu A+B03/24/2021 | Chromatographic Digital Immunoassay, Instrument Read, Multi-analyte, Single Target | H, M, W | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (May 12, 2023) | None
05/12/2023 | Nano-Ditech Corporation | Nano-Check COVID-19 Antigen At-Home Test05/12/2023 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | None | None
05/05/2023 | Xiamen Boson Biotech Co., Ltd. | Rapid SARS-CoV-2 Antigen Test Card 04/06/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (September 2, 2022); Letter Granting EUA Revision(s) (October 18, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 22, 2022); Letter Granting EUA Revision(s) (May 5, 2023) | None
05/03/2023 | Qorvo Biotechnologies, LLC. | Omnia SARS-CoV-2 Antigen Test04/13/2021 | Bulk Acoustic Wave (BAW) Biosensor, Instrument Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (October 25, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (March 1, 2023); Letter Granting EUA Revision(s) (May 5, 2023) | None
05/03/2023 | Siemens Healthcare Diagnostics, Inc. | Atellica IM SARS-CoV-2 Antigen (CoV2Ag)03/11/2022 | CLIA, Single Target | H, M | HCP, Patients, IFU | Letter Granting EUA Revision(s) (October 25, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (May 3, 2023) | None
05/03/2023 | Siemens Healthcare Diagnostics, Inc. | ADVIA Centaur SARS-CoV-2 Antigen (CoV2Ag)03/11/2022 | CLIA, Single Target | H, M | HCP, Patients, IFU | Letter Granting EUA Revision(s) (October 25, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (May 3, 2023) | None
04/28/2023 | iHealth Labs, Inc. | iHealth COVID-19 Antigen Rapid Test Pro01/14/2022 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 27, 2022) | None
04/21/2023 | DiaSorin, Inc. | LIAISON SARS-CoV-2 Ag03/26/2021 | CLIA, Single Target | H, M | HCP, Patients, IFU | Letter Granting EUA Revision(s) (July 12 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (February 16, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (April 21, 2023) | None
04/14/2023 | Azure Biotech, Inc. | Azure FaStep® COVID-19 Antigen Pen Home Test 04/14/2023 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | None | None
04/13/2023 | Beijing Hotgen Biotech Co., Ltd. | Hotgen COVID-19 Antigen Home Test11/17/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (April 13, 2023) | None
04/10/2023 | Abbott Diagnostics Scarborough, Inc. | BinaxNOW COVID-19 Ag Card Home Test12/16/2020 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Telehealth Proctor Supervised, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (January 7, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (April 10, 2023) | None
04/04/2023 | Quidel Corporation | QuickVue SARS Antigen Test12/18/2020 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (April 04, 2023) | None
03/30/2023 | Quidel Corporation | QuickVue At-Home COVID-19 Test03/01/2021 | Lateral Flow, Visual Read, Prescription Home Testing, Single Target | Home, H, M, W | HCP, Patients, IFU, IFU (Home Test) | Viral Mutation Revision Letter - September 23, 2021; Repeat Testing Revision Letter - November 1, 2022 | None
03/29/2023 | Salofa Oy | Sienna-Clarity COVID-19 Antigen Rapid Test Cassette05/20/2021 | Lateral Flow, Visual Read, Single Target | H, M, W | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (December 17, 2021); Letter Granting EUA Revision(s) (June 09, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (March 29, 2023) | Sienna COVID-19 Antigen Rapid Test Cassette; Clarity COVID-19 Antigen Rapid Test Cassette; OVIOS COVID-19 Antigen Rapid Test Cassette; Spring Health COVID-19 Antigen Rapid Test; Salocor COVID-19 Antigen Rapid Test Cassette
03/27/2023 | Celltrion USA, Inc. | Sampinute COVID-19 Antigen MIA10/23/2020 | Magnetic Force-assisted Electrochemical Sandwich Immunoassay (MESIA), Single Target | H, M | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (March 27, 2023) | None
03/21/2023 | Becton, Dickinson and Company (BD) | BD Veritor System for Rapid Detection of SARS-CoV-207/02/2020 | Chromatographic Digital Immunoassay, Instrument Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (July 23, 2020); Letter Granting EUA Revision(s) (December 10, 2021); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (March 21, 2023) | None
03/16/2023 | CorDX, Inc. | CorDx COVID-19 Ag Test11/21/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (March 16, 2023) | None
03/15/2023 | ACON Laboratories, Inc | Flowflex COVID-19 Antigen Home Test10/04/2021 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (October 15, 2021); Letter Granting EUA Revision(s) (April 20, 2022); Letter Granting EUA Revision(s) (September 2, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (November 18, 2022); Letter Granting EUA Revision(s) (March 15, 2023) | On/Go One COVID-19 Antigen Home Test
03/14/2023 | Access Bio, Inc. | CareStart COVID-19 Antigen Home Test08/02/2021 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (August 23, 2021); Letter Granting EUA Revision(s) (January 22, 2022); Letter Granting EUA Revision(s) (May 12, 2022); Letter Granting EUA Revisions(s) (June 7, 2022); Letter Granting EUA Revision(s) (August 29, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (February 01, 2023) | On/Go COVID-19 Antigen Self-Test
03/02/2023 | Celltrion USA, Inc. | Celltrion DiaTrust COVID-19 Ag Home Test10/21/2021 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Multiple Targets | Home, H, M, W | HCP, IFU, IFU (Home Test) | Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (November 4, 2022); Letter Granting EUA Revision(s) (January 20, 2023); Letter Granting EUA Revision(s) (March 02, 2023) | None
03/02/2023 | Celltrion USA, Inc. | Celltrion DiaTrust COVID-19 Ag Rapid Test04/16/2021 | Lateral Flow, Visual Read, Serial Screening, Multiple Targets | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (August 11, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (November 4, 2022); Letter Granting EUA Revision(s) (January 20, 2023); Letter Granting EUA Revision(s) (March 02, 2023) | Humasis COVID-19 Ag Test
03/01/2023 | Ortho Clinical Diagnostics, Inc. | VITROS Immunodiagnostic Products SARS-CoV-2 Antigen Reagent Pack01/11/2021 | Chemiluminescence Immunoassay, Instrument Read, Single Target | H, M | HCP, Patients, IFU | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (November 16, 2021); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (March 1, 2023) | None
02/27/2023 | Quidel Corporation | Sofia SARS Antigen FIA05/08/2020 | Lateral Flow, Fluorescence, Instrument Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Amendment(s) (June 9, 2020); Letter Granting EUA Amendment(s) (July 17, 2020); Viral Mutation Revision Letter - September 23, 2021; Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (February 27, 2023) | None
02/24/2023 | Oceanit Foundry LLC | ASSURE-100 Rapid COVID-19 Test02/28/2022 | Lateral Flow, Visual Read, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (May 4, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 2, 2022); Letter Graning EUA Revision(s) (February 24, 2023) | None
02/22/2023 | Mologic, Inc. | COVI-Go SARS-CoV-2 Ag Self-Test02/22/2023 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | None | None
02/21/2023 | GenBody Inc. | GenBody COVID-19 Ag07/13/2021 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (June 13, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (February 21, 2023) | None
02/21/2023 | Watmind USA | Speedy Swab Rapid COVID-19 Antigen Self-Test07/08/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (January 17, 2023); Letter Granting EUA Revision(s) (February 21, 2023) | None
02/17/2023 | Quidel Corporation | QuickVue At-Home OTC COVID-19 Test03/31/2021 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (July 21, 2022); Letter Granting EUA Revision(s) (September 23, 2022); Repeat Testing Revision Letter - November 1, 2022 | CVS Health At Home COVID-19 Test Kit; Walgreens At-Home COVID-19 Test Kit
02/17/2023 | Siemens Healthineers | CLINITEST Rapid COVID-19 Antigen Self-Test12/29/2021 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (June 23, 2022); Letter Granting EUA Revision(s) (October 12, 2022); Repeat Testing Revision Letter - November 1, 2022 | None
02/17/2023 | GenBody Inc. | GenBody COVID-19 Ag Home Test02/17/2023 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | None | None
02/16/2023 | Ellume Limited | Ellume COVID-19 Home Test12/15/2020 | Lateral Flow, Fluorescence, Instrument Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test), FAQ | Viral Mutation Revision Letter - September 23, 2021; Repeat Testing Revision Letter - November 1, 2022 | None
02/01/2023 | Ellume Limited | ellume.lab COVID Antigen Test07/08/2021 | Lateral Flow, Fluorescence, Instrument Read, Single Target | H, M, W | HCP, Patients, IFU | Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (February 01, 2023) | None
01/17/2023 | Access Bio, Inc. | CareStart COVID-19 Antigen test10/08/2020 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (March 15, 2021); Letter Granting EUA Revisions(s) (July 16, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (December 2, 2021); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (January 17, 2023) | None
01/13/2023 | Abbott Diagnostics Scarborough, Inc. | BinaxNOW COVID-19 Ag Card08/26/2020 | Lateral Flow, Visual Read, Single Target, Serial Screening | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (April 6, 2021); Viral Mutation Revision Letter - September 23, 2021; Letter Granting EUA Revision(s) (January 7, 2022); Letter Granting EUA Revision(s) (February 4, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (November 21, 2022) | None
01/06/2023 | InBios International Inc. | SCoV-2 Ag Detect Rapid Self-Test11/22/2021 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | Letter Granting EUA Revision(s) (March 3, 2022); Letter Granting EUA Revision(s) (May 26, 2022); Letter Granting EUA Revision(s) (September 28, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 23, 2022) | None
12/23/2022 | InBios International, Inc. | SCoV-2 Ag Detect Rapid Test05/06/2021 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (March 3, 2022); Letter Granting EUA Revision(s) (May 26, 2022); Repeat Testing Revision Letter - November 1, 2022; Letter Granting EUA Revision(s) (December 23, 2022) | None
12/22/2022 | Oceanit Foundry LLC | ASSURE-100 Rapid COVID-19 Home Test 12/22/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | None | None
12/15/2022 | Nano-Ditech Corp. | Nano-Check COVID-19 Antigen Test12/06/2021 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | Letter Granting EUA Revision(s) (Feburary 1, 2022); Repeat Testing Revision Letter - November 1, 2022 | None
12/06/2022 | ACON Laboratories, Inc. | Flowflex COVID-19 Antigen Rapid Test 12/06/2022 | Lateral Flow, Visual Read, Serial Screening, Single Target | H, M, W | HCP, Patients, IFU | None | None
11/21/2022 | Azure Biotech Inc. | Fastep COVID-19 Antigen Home Test11/21/2022 | Lateral Flow, Visual Read, Over the Counter (OTC) Home Testing, Serial Screening, Single Target | Home, H, M, W | HCP, IFU, IFU (Home Test) | None | None

^1^ Authorized settings include the following:

• H - Laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, that meet requirements to perform high complexity tests.

• M - Laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, that meet requirements to perform moderate complexity tests.

• W - Patient care settings operating under a CLIA Certificate of Waiver.

^2^ Authorization Documents include the Healthcare Provider (HCP) and Patient Fact Sheets and either the Manufacture Instructions/Package Insert (abbreviated to IFU) or the EUA Summary.

### In Vitro Diagnostics EUAs - Other Tests for SARS-CoV-2

#### Individual EUAs for Diagnostic Breath Tests for SARS-CoV-2

Authorized breath tests for the detection of volatile organic compounds associated with SARS-CoV-2 infection are assigned the QSH product code.

Date EUA Issued or Last Updated | Entity | Diagnostic (Most Recent Letter of Authorization) and Date EUA Originally Issued | Attributes | Authorized Setting(s)^1^ | Authorization Documents^2^ | Other Brand Name(s)
04/14/2022 | InspectIR Systems LLC | InspectIR COVID-19 Breathalyzer; 04/14/2022 | Rapid gas chromatography-mass spectrometry (GC-MS), Five Volatile Organic Compounds (VOCs), Screening | Near Patient/Point-of-Care | HCP, Patients, IFU | None

^1^ Authorized settings noted as 'Near Patient/Point-of-Care' include environments where the patient specimen is both collected and analyzed and the test is performed by a qualified, trained operator under the supervision of a healthcare provider licensed or authorized by state law to prescribe tests.

^2^ Authorization Documents include the Healthcare Provider (HCP) and Patient Fact Sheets and either the Manufacture Instructions/Package Insert (abbreviated to IFU) or the EUA Summary.

#### Individual EUAs for Genotyping Tests for SARS-CoV-2

Authorized SARS-CoV-2 genotyping tests are assigned the QTA product code.

Date EUA Issued or Last Updated | Entity | Diagnostic (Most Recent Letter of Authorization) and Date EUA Originally Issued | Attributes | Authorized Setting(s)^1^ | Authorization Documents^2^ | Other Brand Name(s)
12/06/2023 | Laboratory Corporation of America (Labcorp) | Clear Dx SARS-CoV-2 WGS v3.0 Test08/01/2023 | Next Generation Sequencing (NGS), PANGO lineage | H | HCP, Patients, EUA Summary | Letter Granting EUA Revision(s) (September 13, 2023); Letter Granting EUA Revision(s) (December 6, 2023)
06/10/2022 | Laboratory Corporation of America (Labcorp) | Labcorp VirSeq SARS-CoV-2 NGS Test06/10/2022 | Next Generation Sequencing (NGS), PANGO lineage | H | HCP, Patients, EUA Summary | None

^1^ Authorized settings include the following:

H - Laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, that meet requirements to perform high complexity tests.

M - Laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, that meet requirements to perform moderate complexity tests.

W - Patient care settings operating under a CLIA Certificate of Waiver.

^2^ Authorization Documents include the Healthcare Provider (HCP) and Patient Fact Sheets and either the Manufacture Instructions/Package Insert (abbreviated to IFU) or the EUA Summary.

### Serology and Other Adaptive Immune Response Tests for SARS-CoV-2

#### Individual EUAs for Serology and Other Adaptive Immune Response Tests for SARS-CoV-2

Authorized devices in the table below are assigned the QKO product code.

Date EUA Issued or Last Updated | Entity | Diagnostic (Most Recent Letter of Authorization) and Date EUA Originally Issued | Attributes3 | Authorized Setting(s)1 | Authorization Documents2 | Other Documents | Other Brand Name(s)
06/07/2024 | Abbott Laboratories Inc. | AdviseDx SARS-CoV-2 IgG II03/01/2021 | IgG, CMIA, Semi-quantitative | H, M | HCP, Recipients, IFU-ARCHITECT, IFU-Alinityi | Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (June 20, 2024) | None
09/21/2023 | Ortho-Clinical Diagnostics, Inc. | VITROS Immunodiagnostic Products Anti-SARS-CoV-2 Total N Reagent Pack used in combination with the VITROS Immunodiagnostic Products Anti-SARS-CoV-2 Total N Antibody Calibrators07/22/2021 | Total Antibody, CLIA | H, M | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (September 21, 2023) | None
12/06/2022 | Diazyme Laboratories, Inc. | Diazyme SARS-CoV-2 Neutralizing Antibody CLIA Kit12/06/2022 | Total Neutralizing Antibodies, CLIA | H, M | HCP, Recipients, IFU | None | None
08/31/2022 | LumiraDx UK Ltd. | LumiraDx SARS-CoV-2 Ab Test08/02/2021 | Total Antibody, Fluorescence Immunoassay, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (August 31, 2022) | None
08/24/2022 | Roche Diagnostics, Inc. | Elecsys Anti-SARS-CoV-2 S11/25/2020 | Total Antibody, ECLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (May 4, 2021); Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (February 9, 2022); Letter Granting EUA Revision(s) (August 24, 2022) | None
07/21/2022 | Innovita (Tangshan) Biological Technology Co., Ltd. | Innovita 2019-nCoV Ab Test (Colloidal Gold)11/23/2020 | IgM and IgG, Lateral Flow | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
07/21/2022 | Adaptive Biotechnologies Corporation | T-Detect COVID Test03/05/2021 | T-cell receptor beta (TCR β), Sequencing | H | HCP, Recipients, EUA Summary | Letter Granting EUA Revision(s) (July 21, 2022) | None
07/13/2022 | Ortho-Clinical Diagnostics, Inc. | VITROS Immunodiagnostic Products Anti-SARS-CoV-2 IgG Quantitative Reagent Pack used in combination with the VITROS Immunodiagnostic Products Anti- SARS-CoV-2 IgG Quantitative Calibrator07/09/2021 | IgG, CLIA, Quantitative | H, M | HCP, Recipients, IFU | Letter Granting EUA Revisions(s) (September 8, 2021); Letter Granting EUA Revisions(s) (June 29, 2022) | None
05/31/2022 | LG Chem, Ltd. | AdvanSure SARS-CoV-2 IgG(RBD) ELISA 05/31/2022 | IgG, ELISA | H | HCP, Recipients, IFU | None | None
05/24/2022 | Abbott Laboratories Inc. | SARS-CoV-2 IgG assay04/26/2020 | IgG, CMIA | H, M | HCP, Recipients, IFU-ARCHITECT, IFU-Alinityi | Letter Granting EUA Amendment(s) (May 9, 2020); Letter Granting EUA Amendment(s) (June 22, 2020); Letter Granting EUA Revision(s) (September 18, 2020); Letter Granting EUA Revision(s) (December 1, 2020); Viral Mutation Revision Letter (September 23, 2021) | None
05/19/2022 | LG Chem, Ltd. | AdvanSure SARS-CoV-2 IgG(S1) ELISA05/19/2022 | IgG, ELISA | H | HCP, Recipients, IFU | None | None
04/21/2022 | Emory Medical Laboratories | SARS-CoV-2 RBD IgG test06/15/2020 | IgG, ELISA | H | HCP, Recipients, EUA Summary | Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (April 21, 2022) | None
03/09/2022 | Luminex Corporation | xMAP SARS-CoV-2 Multi-Antigen IgG Assay07/16/2020 | IgG, FMIA | H | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
03/09/2022 | Megna Health, Inc. | Rapid COVID-19 IgM/IgG Combo Test Kit07/17/2020 | IgM and IgG, Lateral Flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (March 9, 2022) | None
03/04/2022 | Siemens Healthcare Diagnostics Inc. | Dimension EXL SARS‑CoV‑2 IgG (CV2G)01/08/2021 | IgG, CLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (April 2, 2021); Viral Mutation Revision Letter (September 23, 2021) | None
03/04/2022 | Siemens Healthcare Diagnostics Inc. | Dimension Vista SARS‑CoV‑2 IgG (COV2G)01/08/2021 | IgG, CLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (April 2, 2021); Viral Mutation Revision Letter (September 23, 2021) | None
03/01/2022 | EUROIMMUN US, Inc. | EUROIMMUN Anti-SARS-CoV-2 S1 Curve ELISA (IgG)10/04/2021 | IgG, ELISA, Semi-quantitative | H, M | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (March 1, 2022) | None
03/01/2022 | Jiangsu Well Biotech Co., Ltd. | Orawell IgM/IgG Rapid Test09/23/2020 | IgM and IgG, Lateral Flow | H, M | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (November 10, 2020); Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (November 5, 2021) | INDICAID COVID-19 IgM/IgG Rapid Test
02/28/2022 | QIAGEN, GmbH | QIAreach Anti-SARS-CoV-2 Total Test05/11/2021 | Total Antibody, Digital Lateral Flow | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (February 28, 2022) | None
02/25/2022 | Bio-Rad Laboratories, Inc. | Platelia SARS-CoV-2 Total Ab assay04/29/2020 | Total Antibody, ELISA | H | HCP, Recipients, IFU | Letter Granting EUA Amendment(s) (July 21, 2020); Letter Granting EUA Revision(s) (October 30, 2020); Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (February 25, 2022) | None
02/14/2022 | Hangzhou Laihe Biotech Co., Ltd. | LYHER Novel Coronavirus (2019-nCoV) IgM/IgG Antibody Combo Test Kit (Colloidal Gold)06/19/2020 | IgM and IgG Lateral Flow | H, M | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (August 12, 2020); Letter Granting EUA Revision(s) (December 2, 2020); Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (February 14, 2022) | None
02/09/2022 | EUROIMMUN US Inc. | Anti-SARS-CoV-2 ELISA (IgG)05/04/2020 | IgG, ELISA | H | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
02/01/2022 | GenScript USA Inc. | cPass SARS-CoV-2 Neutralization Antibody Detection Kit11/06/2020 | Total Neutralizing Antibodies, Blocking ELISA, Semi-quantitative | H | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (February 1, 2022) | None
02/01/2022 | NOWDiagnostics, Inc. | ADEXUSDx COVID-19 Test05/24/2021 | Total Antibody, Lateral Flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | None | None
01/31/2022 | Assure Tech. (Hangzhou Co., Ltd) | Assure COVID-19 IgG/IgM Rapid Test Device07/06/2020 | IgM and IgG, Lateral Flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (January 31, 2022) | Ecotest COVID-19 IgG/IgM Rapid Test Device; Fastep COVID-19 IgG/IgM Rapid Test Device
01/26/2022 | Healgen Scientific LLC | COVID-19 IgG/IgM Rapid Test Cassette (Whole Blood/Serum/Plasma)05/29/2020 | IgM and IgG Lateral Flow | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
01/19/2022 | Siemens Healthcare Diagnostics Inc. | Atellica IM SARS-CoV-2 IgG (sCOVG)03/23/2021 | IgG, CLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | None | None
01/18/2022 | Siemens Healthcare Diagnostics Inc. | Dimension Vista SARS-CoV-2 Total antibody assay (COV2T)06/08/2020 | Total Antibody, CLIA | H, M | HCP, Recipients, IFU | Letter Granting EUA Amendment(s) (August 7, 2020); Letter Granting EUA Revision(s) (October 30, 2020); Viral Mutation Revision Letter (September 23, 2021) | None
01/18/2022 | Siemens Healthcare Diagnostics Inc. | Dimension EXL SARS-CoV-2 Total antibody assay (CV2T)06/08/2020 | Total Antibody, CLIA | H, M | HCP, Recipients, IFU | Letter Granting EUA Amendment(s) (August 7, 2020); Letter Granting EUA Revision(s) (October 30, 2020); Viral Mutation Revision Letter (September 23, 2021) | None
01/18/2022 | Diazyme Laboratories, Inc. | Diazyme DZ-Lite SARS-CoV-2 IgG CLIA Kit07/08/2020 | IgG, CLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
01/18/2022 | Diazyme Laboratories, Inc. | Diazyme DZ-Lite SARS-CoV-2 IgM CLIA Kit08/17/2020 | IgM, CLIA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
12/17/2021 | Beckman Coulter, Inc. | Access SARS-CoV-2 IgG06/26/2020 | IgG, CLIA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
12/16/2021 | Biohit Healthcare (Hefei) Co. Ltd. | Biohit SARS-CoV-2 IgM/IgG Antibody Test Kit06/18/2020 | IgM and IgG Lateral Flow | H, M | HCP, Recipients, IFU | Letter Granting EUA Amendment(s) (August 3, 2020); Letter Granting EUA Revision(s) (October 17, 2020); Viral Mutation Revision Letter (September 23, 2021) | ThermoGenesis SARS-CoV-2 IgM/IgG Antibody Test Kit
12/16/2021 | Shenzhen New Industries Biomedical Engineering Co., Ltd. | MAGLUMI 2019-nCoV IgM/IgG09/14/2020 | IgM and IgG, CLIA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
12/15/2021 | ACON Laboratories, Inc. | ACON SARS-CoV-2 IgG/IgM Rapid Test12/15/2020 | IgM and IgG, Lateral Flow | H, M | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (June 28, 2021); Viral Mutation Revision Letter (September 23, 2021) | None
12/13/2021 | NanoEntek America, Inc. | FREND COVID-19 total Ab09/29/2020 | Total Antibody, FIA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
12/13/2021 | Beckman Coulter, Inc. | Access SARS-CoV-2 IgM10/08/2020 | IgM, CLIA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
12/13/2021 | ZEUS Scientific, Inc. | ZEUS ELISA SARS-CoV-2 Total Antibody Test System05/11/2021 | Total Antibody, ELISA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
12/09/2021 | Immunodiagnostic Systems Ltd. | IDS SARS-CoV-2 IgG02/10/2021 | IgG, CLIA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
12/08/2021 | ZEUS Scientific, Inc. | ZEUS ELISA SARS-CoV-2 IgG Test System10/06/2020 | IgG, ELISA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
11/19/2021 | Sugentech, Inc. | SGTi-flex COVID-19 IgG09/03/2020 | IgG, Lateral Flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (November 2, 2021); Letter Granting EUA Revision(s) (November 19, 2021) | TekiTrust COVID-19 IgG
11/02/2021 | Nirmidas Biotech, Inc. | MidaSpot COVID-19 Antibody Combo Detection Kit12/31/2020 | IgM and IgG, lateral flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (January 25, 2021); Letter Granting EUA Revision(s) (February 5, 2021); Letter Granting EUA Revision(s) (April 12, 2021); Letter Granting EUA Revision(s) (July 29, 2021); Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (November 2, 2021) | None
10/22/2021 | InBios International, Inc. | SCoV-2 Detect Neutralizing Ab ELISA10/22/2021 | Total Neutralizing Antibodies, ELISA | H | HCP, Recipients, IFU | None | None
10/07/2021 | DiaSorin Inc. | LIAISON SARS-CoV-2 S1/S2 IgG04/24/2020 | IgG, CLIA | H, M | HCP, Recipients, IFU | Letter Granting EUA Amendment(s) (July 22, 2020); Letter Granting EUA Revision(s) (October 19, 2020); Viral Mutation Revision Letter (September 23, 2021); Letter Granting EUA Revision(s) (October 7, 2021) | None
10/01/2021 | Abbott Laboratories Inc. | AdviseDx SARS-CoV-2 IgM 10/09/2020 | IgM, CMIA | H, M | HCP, Recipients, IFU-ARCHITECT, IFU-Alinityi | None | None
09/14/2021 | Siemens Healthcare Diagnostics Inc. | ADVIA Centaur SARS-CoV-2 Total (COV2T)05/29/2020 | Total Antibody, CLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | None | None
08/24/2021 | InBios International, Inc | SCoV-2 Detect IgG Rapid Test08/24/2021 | IgG, Lateral Flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | None | None
08/18/2021 | Beckman Coulter, Inc. | Access SARS-CoV-2 IgG II03/22/2021 | IgG, CLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | None | None
08/12/2021 | Access Bio, Inc. | CareStart COVID-19 IgM/IgG07/24/2020 | IgM and IgG, Lateral Flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (October 31, 2020); Letter Granting EUA Revision(s) (March 19, 2021) | Rapid Response Liberty COVID-19 IgG/IgM; KarmaCare SARS-CoV-2 IgM/IgG
08/10/2021 | Diabetomics, Inc. | CovAb SARS-CoV-2 Ab Test06/04/2021 | Total Antibody, Lateral Flow, Oral Fluid | H, M, W | HCP, Recipients, IFU | None | None
08/10/2021 | Siemens Healthcare Diagnostics Inc. | ADVIA Centaur SARS-CoV-2 IgG (sCOVG)06/17/2021 | IgG, CLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
07/22/2021 | Ortho-Clinical Diagnostics, Inc. | VITROS Immunodiagnostic Products Anti-SARS-CoV-2 Total N Reagent Pack used in combination with the VITROS Immunodiagnostic Products Anti-SARS-CoV-2 Total N Antibody Calibrators07/22/2021 | Total Antibody, CLIA | H, M | HCP, Recipients, IFU | None | None
07/13/2021 | Roche Diagnostics | Elecsys Anti-SARS-CoV-205/02/2020 | Total Antibody, ECLIA | H, M | HCP, Recipients, IFU | Letter Granting EUA Amendment(s) (June 4, 2020); Letter Granting EUA Amendment(s) (July 21, 2020); Letter Granting EUA Revision(s) (October 23, 2020); Letter Granting EUA Revision(s) (July 13, 2021); Viral Mutation Revision Letter (September 23, 2021) | None
07/12/2021 | Salofa Oy | Sienna-Clarity COVIBLOCK COVID-19 IgG/IgM Rapid Test Cassette07/13/2020 | IgM and IgG, Lateral Flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (July 12, 2021); Viral Mutation Revision Letter (September 23, 2021) | Clarity COVIBLOCK COVID-19 IgG/IgM Rapid Test Cassette; Sienna COVID-19 IgG/IgM Rapid Test Cassette
06/24/2021 | Symbiotica, Inc. | COVID-19 Self-Collected Antibody Test System04/05/2021 | IgG, ELISA, Home Collection, Fingerstick Dried Blood Spot | H | HCP, Recipients, EUA Summary, IFU (Home Collect) | Letter Granting EUA Revision(s) (June 24, 2021); Viral Mutation Revision Letter (September 23, 2021) | None
06/24/2021 | Access Bio, Inc. | CareStart EZ COVID-19 IgM/IgG06/24/2021 | IgM and IgG, Lateral Flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
06/01/2021 | Siemens Healthcare Diagnostics Inc. | Atellica IM SARS-CoV-2 Total (COV2T)05/29/2020 | Total Antibody, CLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
05/19/2021 | DiaSorin, Inc. | LIAISON SARS-CoV-2 TrimericS IgG05/19/2021 | IgG, CLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
05/14/2021 | InBios International, Inc. | SCoV-2 Detect IgG ELISA06/10/2020 | IgG, ELISA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
04/26/2021 | ADVAITE, Inc. | RapCov Rapid COVID-19 Test01/11/2021 | IgG, Lateral Flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (April 26, 2021); Viral Mutation Revision Letter (September 23, 2021) | None
04/19/2021 | Inova Diagnostics, Inc. | QUANTA Flash SARS-CoV-2 IgG04/19/2021 | IgG, CLIA, Semi-quantitative | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
03/29/2021 | Ortho Clinical Diagnostics, Inc. | VITROS Immunodiagnostic Products Anti-SARS-CoV-2 Total Reagent Pack04/14/2020 | Total Antibody, CLIA | H, M | HCP, Recipients, IFU | Letter Granting EUA Amendment(s) (May 9, 2020); Letter Granting EUA Revision(s) (October 30, 2020); Letter Granting EUA Revision(s) (January 29, 2021); Viral Mutation Revision Letter (September 23, 2021) | None
03/25/2021 | InBios International, Inc. | SCoV-2 Detect IgM ELISA06/30/2020 | IgM, ELISA | H | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
03/15/2021 | bioMérieux SA | VIDAS SARS-CoV-2 IgM08/06/2020 | IgM, ELFA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
03/15/2021 | bioMérieux SA | VIDAS SARS-CoV-2 IgG08/06/2020 | IgG, ELFA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
03/12/2021 | Beijing Wantai Biological Pharmacy Enterprise Co., Ltd. | WANTAI SARS-CoV-2 Ab Rapid Test07/10/2020 | Total Antibody, Lateral Flow | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
02/12/2021 | Ortho-Clinical Diagnostics, Inc. | VITROS Immunodiagnostic Products Anti-SARS-CoV-2 IgG Reagent Pack04/24/2020 | IgG, CLIA | H, M | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (May 20, 2020); Letter Granting EUA Revision(s) (October 23, 2020); Viral Mutation Revision Letter (September 23, 2021) | None
01/19/2021 | Phadia AB | EliA SARS-CoV-2-Sp1 IgG Test01/11/2021 | IgG, Fluoroenzyme Immunoassay, Semi-quantitative | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
01/15/2021 | United Biomedical, Inc. | UBI SARS-CoV-2 ELISA01/15/2021 | IgG, ELISA | H | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
12/21/2020 | Hangzhou Biotest Biotech Co., Ltd. | RightSign COVID-19 IgG/IgM Rapid Test Cassette06/04/2020 | IgM and IgG Lateral Flow, Fingerstick Whole Blood | H, M, W | HCP, Recipients, IFU | Letter Granting EUA Amendment(s) (July 23, 2020); Letter Granting EUA Revision(s) (August 31, 2020); Viral Mutation Revision Letter (September 23, 2021) | Premier Biotech COVID-19 IgG/IgM Rapid Test Cassette; CoronaCHEK COVID-19 IgG/IgM Rapid Test Cassette
11/24/2020 | Kantaro Biosciences, LLC | COVID-SeroKlir, Kantaro Semi-Quantitative SARS-CoV-2 IgG Antibody Kit11/24/2020 | IgG, ELISA, Semi-quantitative | H | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
11/06/2020 | Xiamen Biotime Biotechnology Co., Ltd. | BIOTIME SARS-CoV-2 IgG/IgM Rapid Qualitative Test07/24/2020 | IgM and IgG, Lateral Flow | H, M | HCP, Recipients, IFU | Letter Granting EUA Revision(s) (October 23, 2020); Letter Granting EUA Revision(s) (October 30, 2020); Letter Granting EUA Revision(s) (November 6, 2020); Viral Mutation Revision Letter (September 23, 2021) | Telepoint SARS-CoV-2 IgG/IgM Rapid Qualitative Test
10/28/2020 | Quansys Biosciences, Inc. | Q-Plex SARS-CoV-2 Human IgG (4 Plex) 10/28/2020 | IgG, CLIA | H | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
10/08/2020 | Genalyte, Inc. | Maverick SARS-CoV-2 Multi-Antigen Serology Panel v210/08/2020 | Total Antibody, photonic ring immunoassay | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
09/29/2020 | Nirmidas Biotech, Inc. | Nirmidas COVID-19 (SARS-CoV-2) IgM/IgG Antibody Detection Kit09/29/2020 | IgM and IgG, Lateral Flow | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
09/09/2020 | BioCheck, Inc. | BioCheck SARS-CoV-2 IgM Antibody Test Kit09/09/2020 | IgM, CLIA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
09/09/2020 | BioCheck, Inc. | BioCheck SARS-CoV-2 IgG Antibody Test Kit09/09/2020 | IgG, CLIA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
08/31/2020 | TBG Biotechnology Corp. | TBG SARS-CoV-2 IgG / IgM Rapid Test Kit08/31/2020 | IgM and IgG, Lateral Flow | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
08/25/2020 | Biocan Diagnostics Inc. | Tell Me Fast Novel Coronavirus (COVID-19) IgG/IgM Antibody Test08/25/2020 | IgM and IgG, Lateral Flow | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
08/17/2020 | BioCheck, Inc. | BioCheck SARS-CoV-2 IgG and IgM Combo Test08/17/2020 | IgM and IgG, CLIA | H, M | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
08/05/2020 | Beijing Wantai Biological Pharmacy Enterprise Co., Ltd. | WANTAI SARS-CoV-2 Ab ELISA08/05/2020 | Total Antibody, ELISA | H | HCP, Recipients, IFU | Viral Mutation Revision Letter (September 23, 2021) | None
06/04/2020 | Vibrant America Clinical Labs | Vibrant COVID-19 Ab Assay06/04/2020 | IgM and IgG, CLIA | H | HCP, Recipients, EUA Summary | Viral Mutation Revision Letter (September 23, 2021) | None
04/30/2020 | Wadsworth Center, New York State Department of Health | New York SARS-CoV Microsphere Immunoassay for Antibody Detection04/30/2020 | Total Antibody, FMIA | H | HCP, Recipients, EUA Summary | Viral Mutation Revision Letter (September 23, 2021) | None
04/15/2020 | Mount Sinai Laboratory | COVID-19 ELISA IgG Antibody Test04/15/2020 | IgG, ELISA | H | HCP, Patients, EUA Summary | Viral Mutation Revision Letter (September 23, 2021) | None

^1^ Authorized settings include the following:

• H - Laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, that meet requirements to perform high complexity tests.

• M - Laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, that meet requirements to perform moderate complexity tests.

• W - Patient care settings operating under a CLIA Certificate of Waiver.

^2^ Authorization Documents include the Healthcare Provider (HCP) and Patient Fact Sheets and either the Manufacture Instructions/Package Insert (abbreviated to IFU) or the EUA Summary.

^3^ Abbreviations: CLIA = chemiluminescence immunoassay; ELISA = enzyme-linked immunosorbent assay; ECLIA = electrochemiluminescence immunoassay; FMIA = fluorescent microsphere Immunoassay, CMIA = chemiluminescent microparticle immunoassay; ELFA = enzyme-linked fluorescence assay

#### Revision Concerning Viral Mutations

On September 23, 2021, the FDA revised the EUAs of certain molecular, antigen, and serology tests to establish additional Conditions of Authorization in response to the continued emergence of new variants of SARS-CoV-2. The revision requires test developers to update their authorized labeling and evaluate the impact of SARS-CoV-2 viral mutations on their test's performance as outlined in the letter. This revision is effective as of September 23, 2021 for all EUAs that are within the scope of the revision. This revision does not apply to EUAs for authorized IL-6 assays or standalone specimen collection devices and does not apply to EUAs that include substantially equivalent viral mutation conditions of authorization.

The FDA has determined that establishing additional conditions is necessary to mitigate the potential risk of false negative results due to either decreased sensitivity or non-reactivity associated with SARS-CoV-2 viral mutations. As set forth in the September 23, 2021 letter, developers of authorized tests that are within the scope of the revision are now required to routinely monitor emerging viral mutations and their potential impact on the performance of the authorized SARS-CoV-2 test(s). If potential impacts are identified, the EUA holder must communicate with the FDA and end users about the potential risk that presence of the mutations may have on test performance. The EUA holder must also update their authorized labeling consistent with the revision letter and submit the labeling to the FDA within 3 months of September 23, 2021. By taking these steps, the FDA and the test developer can quickly act in response to the potential risks identified and, when applicable, share the findings on SARS-CoV-2 Viral Mutations: Impact on COVID-19 Tests (https://www.fda.gov/medical-devices/coronavirus-covid-19-and-medical-devices/sars-cov-2-viral-mutations-impact-covid-19-tests?utm_medium=email&utm_source=govdelivery).

Viral Mutation Revision Letter – September 23, 2021

#### Umbrella EUA for Independently Validated Serology Tests for SARS-CoV-2

On April 28, 2020, FDA issued an umbrella EUA for SARS-CoV-2 Antibody Tests (Lateral flow or Enzyme-linked immunosorbent assay (ELISA) tests) that have been evaluated in an independent validation study performed at the National Institutes of Health's (NIH) National Cancer Institute (NCI), or by another government agency designated by the FDA, and are confirmed by the FDA to meet the criteria set forth in the Scope of Authorization of the EUA. To date, however, no device has been added to the list of authorized devices in Appendix A of the letter of authorization.

On July 21, 2020, FDA determined, based on information and experience since issuing this EUA, that circumstances support revocation of this umbrella EUA so that FDA may issue individual EUAs. Individual EUAs will allow for broader indications and scopes of authorization, individualized conditions of authorization to address any issue unique to a specific test, and more streamlined EUA amendments, such as additional uses that would not fall under this umbrella EUA.

Accordingly, the EUA was revoked under Section 564(g)(2)(C) of the Federal Food, Drug, and Cosmetic (FD&C) Act.

### IVDs for Management of COVID-19 Patients

Authorized IL-6 Diagnostic Tests are assigned the QLC product code. Authorized sodium citrate blood specimen collection tubes are assigned the QPW product code.

Date EUA Issued or Last Updated | Entity | Diagnostic (Most Recent Letter of Authorization) and Date EUA Originally Issued | Attributes | Authorized Setting(s)^1^ | Authorization Documents^2^ | Other Documents | Other Brand Name(s)
08/18/2021 | Becton, Dickinson and Company | BD Vacutainer Plus Citrate Plasma Tubes (UK Manufacturing Site) 07/22/2021 | Blood Collection Tube | H,M | HCP and Authorized Laboratories, IFU | None | None
12/18/2020 | Siemens Healthcare Diagnostics Inc. | ADVIA Centaur IL6 assay12/18/2020 | One-step Direct Chemiluminescent Immunoassay | H, M | HCP, Patients, IFU | None | None
10/01/2020 | Beckman Coulter, Inc. | Access IL-610/01/2020 | One-step immunoenzymatic ("sandwich") assay, IL-6 | H, M | HCP, Patients, IFU | None | None
06/02/2020 | Roche Diagnostics | Elecsys IL-606/02/2020 | Immunoassay-IL-6 | H, M | HCP, Patients, IFU | None | None

^1^ Authorized settings include the following:

• H - Laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, that meet requirements to perform high complexity tests.

• M - Laboratories certified under the Clinical Laboratory Improvement Amendments of 1988 (CLIA), 42 U.S.C. §263a, that meet requirements to perform moderate complexity tests.

• W - Patient care settings operating under a CLIA Certificate of Waiver.

^2^ Authorization Documents include the Healthcare Provider (HCP) and Patient Fact Sheets and either the Manufacture Instructions/Package Insert (abbreviated to IFU) or the EUA Summary.

## Infusion Pump EUAs

Date EUA Issued | Device Type | Letter of Authorization | Fact Sheets | Assigned Product Code | Other Documents
04/11/2020 | Infusion Pump | B. Braun Space and Outlook Pumps | - Healthcare Providers; - Patients | QOY | - None

## Personal Protective Equipment EUAs

November 8, 2023 - The COVID-19 public health emergency (PHE) declared under section 319 of the Public Health Service (PHS) Act expired (https://www.hhs.gov/about/news/2023/02/09/fact-sheet-covid-19-public-health-emergency-transition-roadmap.html) on May 11, 2023. The COVID-19 enforcement policy guidances within scope of the Transition Plan for Medical Devices That Fall Within Enforcement Policies Issued During the Coronavirus Disease 2019 (COVID-19) Public Health Emergency (https://www.fda.gov/regulatory-information/search-fda-guidance-documents/transition-plan-medical-devices-fall-within-enforcement-policies-issued-during-coronavirus-disease) (see List 1) are no longer in effect.

For information on EUAs that were previously issued but no longer in effect, including revoked EUAs, see Historical Information about Device Emergency Use Authorizations (https://www.fda.gov/medical-devices/emergency-use-authorizations-medical-devices/historical-information-about-device-emergency-use-authorizations).

### Umbrella EUA for Surgical Masks

EUA Letter of Authorization - Umbrella EUA for Surgical Masks (Reissued March 6, 2023)

Fact Sheet for Healthcare Personnel

#### Appendix A: Authorized Surgical Masks

All authorized surgical masks in the table below (Appendix A) are assigned the QMF product code.

Date of Addition | Manufacturer | Authorized Product Name (including model number)
02/09/2023 | MDT Medical Products | MDT Medical Products 3PLY Mask
02/07/2023 | Medplan Private Limited | MED-2002-EL (50 pieces/box)
09/29/2022 | PADM Medical Inc. | PRECISION ECO™ Compostable / Plant Based Procedural Mask with Earloops (black - 100195, white - 100196)
09/02/2022 | PADM Medical™ Procedural Masks with Ear loops | Surgical Mask, Model Number – SL3P1710
07/07/2022 | ARCH MedTech, LLC | ARCH MedTech Level 3 Surgical Mask – AMT-001L (Earloop)ARCH MedTech Level 3 Surgical Mask – AMT-002T (Ear Ties)
06/30/2022 | Delta Medco, LLC | Delta Medco Disposable Surgical Face Mask with Earloops (Model DSM0001)
03/04/2022 | Supermax Healthcare Canada – Supermax Medical | Surgical Mask, Model Number – 2110Surgical Mask, Model Number – 2120
01/18/2022 | SafeSource Direct, LLC | SafeSource Direct Surgical Mask with Ear Loops (Model EUA3001)
01/14/2022 | Little Rapids Corporation | Graham Medical® Surgical Masks – Model Numbers: 88037 & 88038
01/14/2022 | Supermax Healthcare Canada – Supermax Medical | Surgical Mask, Model Number – 2130
01/12/2022 | Sidra Medical Supply Inc. | Sidra Surgical Face Mask AD3PL2WH
11/19/2021 | EcoGuard Inc. | Disposable Single Use 4-Ply Earloop, model EcoGuard A ECO05
11/05/2021 | Mahe Medical Service GmbH | Mahe Medical Disposable Surgical Face Mask with Earloops, Model 001-USA-E
10/29/2021 | MOCACARE Corporation | MOCACARE Surgical Mask (Level 3)Model number: BC1005
10/28/2021 | DediCare Medical Solution LLC | Surgical Mask, Model Number – SM3101
07/12/2021 | SurgiMac Manufacturing Inc. | Surgical Mask (Model – MAC-6501)
07/02/2021 | Sesa LLC | Sesa Health Surgical Mask (Model Number - SH.PPE.SM.2L3)
07/02/2021 | LM Surgical Mask | 3-ply level 3 Earloop - LM07873-ply level 3 Head Straps - LM1019
07/01/2021 | Connecticut Mask Company, LLC | CMC Surgical Mask 10 (Model - CMC 10; ASTM Level 1)CMC Surgical Mask 30 (Model - CMC30; ASTM Level 3)
05/26/2021 | Linghe International co. Ltd. | Linghe Disposable, Single-Use Surgical Mask (Model Number: Best02)
05/21/2021 | Medtecs USA Corporation | Medtecs Medical Mask (Model FM-140G)
05/21/2021 | Filtra-Systems Company, LLC | Filtra Systems Surgical Face Mask (Model number – 0605202)
05/12/2021 | Lumensource, LLC | Lumensource Surgical Mask Model # PKM-S201B
05/07/2021 | Altor Safety | 3 Ply Surgical Mask (Model # 62212); 4 Ply Surgical Mask (Model #62232)
05/07/2021 | Health Pro Supplies Limited | Medical Surgical Mask HP2723 (Large); Medical Surgical Mask HP9503
04/29/2021 | Phoenix Quality MFG, LLC | PQM LibertyAir Surgical MaskModel - S-9501-EUA
04/29/2021 | Honeywell International Inc. | Procedure Mask with Earloops (PM345 C)
04/29/2021 | Honeywell International Inc. | Procedure Mask with Earloops (PM345 D)
04/29/2021 | Honeywell International Inc. | Procedure Mask with Earloops (PM345 E)
04/28/2021 | Devshree International Pvt. Ltd. | Hoplon Brand Disposable Single Use Surgical Masks Level 1 per ASTM F2100 H3SS
04/21/2021 | GRAFICA VENETA S.p.A. | MASK MEDICA GV 2 GV2-GVII-202007
04/19/2021 | BLUETRACK, Inc. | Healthcare Pro Surgical MasksS-3050-WH
04/16/2021 | Manohar Filaments Private Limited | 3 Ply Surgical MaskMF-SM3-EH
04/06/2021 | Keeo Life Private Limited | 3PLY Surgical Mask KF-SM3-EL4PLY Surgical Mask KF-SM4-EL
03/30/2021 | PZero Innovations, Inc. | PZero Surgical Mask Model Number: FM20PZ00
03/29/2021 | Protektair, Inc | Protektair-3 Surgical Mask Model #: PSM-3000
03/19/2021 | Cleveland Veteran Business Solutions | CVBS Surgical Mask - Model Number: SM1
02/12/2021 | SIO International Wisconsin, Inc | Sharp MQ-3050 Surgical mask; Foxconn MQ-3050 Surgical mask
01/29/2021 | 131co Inc. | ARX Surgical Mask (Model number ARX1001)
01/22/2021 | Honeywell International Inc. | Procedure Mask with EarloopsModel #: 559250M D
01/19/2021 | KNH Enterprise Co., Ltd. | KNH Surgical Face Mask Model Numbers: 902E1 (Ear Loop Level 1 – inner loop) 902E1-1 (Ear Loop Level 1 – outer loop) 902E2 (Ear Loop Level 2 – inner loop) 902E2-1 (Ear Loop Level 2 – outer loop) 902D1-M (3D Level 1 – size M) 902D1-L (3D Level 1 – size L) 902D2-M (3D Level 2 – size M) 902D2-L (3D Level 2 – size L) 902Z1 (Z-Folded Level 1) 902Z1 (Z-Folded Level 2)
12/19/2020 | Honeywell International Inc. | Procedure Mask with EarloopsModel #: 559250M B and 559250M C
12/16/2020 | Honeywell International Inc. | Procedure Mask with EarloopsModel #: 559250M
12/10/2020 | Danameco Medical Joint Stock Corporation | D-Care Surgical Face Mask 3 ply (white), TAMMY Surgical Face Mask 3 ply (white)Model/AMIS Numbers: KTY60WK050, KTY75WK050, KTY74WK050
12/10/2020 | MOCACARE Corporation | MOCACARE Procedure Mask (Level 1)Model #: BC1003
12/09/2020 | Nomad Goods | Nomad Surgical Mask N-MASK-3
11/20/2020 | Rymco Medical | Surgical Mask (Tie-On)Model #: IMABEU; Surgical Mask (Earloop)Model #: IMSBEU
11/06/2020 | EcoGuard Inc. | Surgical Mask - Disposable Single-Use 4-Ply EarloopModel #: EcoGuard A ECO03; Surgical Mask - Disposable Single-Use 4-Ply Tie-onModel #: EcoGuard A ECO04
11/03/2020 | Fischer Manufacturing, LLC | Heartland Health Surgical Mask
10/15/2020 | Brandix Apparel Solutions Limited | Disposable Surgical Mask BRNDX-DSM-001-LARGE
10/08/2020 | WPT Corporation | WPT ASTM F2100-19 Level 3 Earloop Surgical Face Mask (Model # SMS2020)
10/05/2020 | Hanesbrands, Inc. | Hanes Surgical Mask 01, Small and Large
08/18/2020 | Venus Group, Inc. | Venus Medical Grade Disposable Surgical Mask
08/08/2020 | Outdoor Research | Outdoor Research Surgical Mask model #OR2159

#### Surgical Masks Removed from Appendix A

Date No Longer Authorized | Manufacturer | Surgical Mask Model(s) No Longer Authorized
06/14/2023 | PADM Medical Inc. | PRECISION ECO™ Compostable / Plant Based Procedural Mask with Earloops (black - 100195, white - 100196)
03/30/2022 | INTAI Technology CORP | INTAI SURGICAL MASK (non-sterile) - ASTM Level3(Model 9W001200); INTAI SURGICAL MASK (non-sterile) - ASTM Level3(Model 9W001201)
12/16/2021 | Liberty Mask, LLC | LM Surgical Mask Level 3; LM Surgical Mask Level 2
09/03/2021 | Altor Safety | 4 Ply Surgical Mast (Model #62232)
07/23/2021 | Altor Safety | 3 Ply Surgical Mask (Model #62222)
07/06/2021 | Premium-PPE Amerishield | Premium PPE Amerishield Disposable Surgical Mask Model #: PPE-M-AS-SUR-lvl2-S
03/19/2021 | Homtex, Inc. | Sovereign America Surgical MaskModel #: 2000SM1, Blue color
02/03/2021 | EcoGuard Inc. | Surgical Mask - Disposable Single-Use 3-Ply EarloopModel #: EcoGuard B ECO01; Surgical Mask - Disposable Single-Use 3-Ply Tie-onModel #: EcoGuard B ECO02
01/22/2021 | Premier Guard USA LLC | Premier Guard USA Surgical Face Mask 20-1002-SFM3

### N95 and Other Respirators EUAs (including EUAs for NIOSH-Approved N95s and imported respirators)

Date EUA Issued | (PPE) Letter of Authorization | Other Documents
03/28/2020 | NIOSH-Approved Air Purifying Respirators for Use in Health Care Settings During Response to the COVID-19 Public Health Emergency | EUA Clarification Letter on Respirators

### Face Shields and Other Barrier EUAs

Date EUA Issued | (PPE) Letter of Authorization | Other Documents | Procode Assigned
05/06/2021 | Negative Pressure SteriDome (NPS) | - Fact Sheet for Healthcare Providers; - Fact Sheet for Patients; - Instructions for Use | QLE
05/04/2021 | ISOCUBE SS and ISOCUBE ONE | - Fact Sheet for Healthcare Personnel; - Fact Sheet for Patients; - ISCOCUBE SS: Instructions for Use Healthcare Personnel and Facilities; - ISCOCUBE One: Instructions for Use Healthcare Personnel and Facilities | QLE
04/01/2021 | Individual Biocontainment Unit (IBU) | - Fact Sheet for Healthcare Providers; - Fact Sheet for Patients; - Instructions for Healthcare Providers; - Instructions for Healthcare Facilities | QLE
03/29/2021 | AerosolVE Device(Revised Labeling 06/11/2021) | - Fact Sheet for Patients; - Fact Sheet for Healthcare Providers; - Instructions for Use | QLE
03/29/2021 | AerosolVE Device(Revised Labeling 06/11/2021) | - Fact Sheet for Patients; - Fact Sheet for Healthcare Providers; - Instructions for Use | QLE
12/18/2020 | SCONE(Re-issued 04/12/2021) | - Fact Sheet for Patients; - Fact Sheet for Healthcare Providers; - Instructions for Healthcare Providers and Facilities | QLE
09/24/2020 | COVIAGE | - Fact Sheet for Healthcare Providers; - Fact Sheet for Patients; - Instructions for Healthcare Facilities: Assembly, Disassembly, and Disinfection of COVIAGE; - Instructions for Healthcare Personnel (HCP): Use of COVIAGE | QLE
07/24/2020 | Airway Dome | - Fact Sheet for Healthcare Providers; - Fact Sheet for Patients; - Instructions for Healthcare Facilities: Assembly and Disposal of the Airway Dome; - Instructions for Healthcare Provider (HCP): Use of the Airway Dome | QLE
06/13/2020 | Negative-pressure Respiratory System with Advanced Ventilation Return (NRSAVR-100) | - Fact Sheet for Healthcare Providers; - Fact Sheet for Patients; - Instructions for Healthcare Facilities; - Instructions for Healthcare Personnel | QLE
05/27/2020 | Gowns and Other Apparel | None | QPK
05/08/2020 | Patient Isolation Transport Unit (PITU) Device | - Fact Sheet for Healthcare Providers; - Fact Sheet for P atients; - PITU Set Up and Operation Guide; - PITU User Manual | QLE
04/13/2020 | Airborne Isolation Hood Device | - Fact Sheet for Healthcare Personnel; - Fact Sheet for Patients; - Instructions for Use for Healthcare Facilities; - Instructions for Use for Healthcare Personnel | QLE
04/09/2020 | Face Shields | - None | QPK

## Withdrawal Due to Other Reasons

Date EUA Issued | Date of Withdrawal | PPE (Letter of Authorization) | Other Documents | Procode Assigned
05/19/2020 | 12/19/2022 | COVID-19 Airway Management Isolation Chamber (CAMIC)(Reissued 06/22/2020) | - Fact Sheet for Healthcare Providers; - Fact Sheet for Patients; - Instructions for Healthcare Facilities - Assembly, Disassembly and Disinfection of the CAMIC; - Instructions for Healthcare Personnel - Use of the CAMIC | QLE

## Remote or Wearable Patient Monitoring Devices EUAs

November 8, 2023 - The COVID-19 public health emergency (PHE) declared under section 319 of the Public Health Service (PHS) Act expired (https://www.hhs.gov/about/news/2023/02/09/fact-sheet-covid-19-public-health-emergency-transition-roadmap.html) on May 11, 2023. The COVID-19 enforcement policy guidances within scope of the Transition Plan for Medical Devices That Fall Within Enforcement Policies Issued During the Coronavirus Disease 2019 (COVID-19) Public Health Emergency (https://www.fda.gov/regulatory-information/search-fda-guidance-documents/transition-plan-medical-devices-fall-within-enforcement-policies-issued-during-coronavirus-disease) (see List 1) are no longer in effect.

Date EUA Issued | Device Type | Letter of Authorization | Fact Sheets | Other Documents | Assigned Product Code
05/14/2020 | Remote Patient QT Interval Monitor | G Medical Innovations, Ltd., VSMS Patch | - Healthcare Providers; - Patients | - Professional User Guide, VSMS Patch; - Quick Start Guide, VSMS Patch | QNY
05/11/2020 | Nurse Call System | Ascom(US), Inc., teleCARE | - Healthcare Providers; - Patients | | QNZ
05/08/2020 | Patient Isolation Transport Unit (PITU) | Patient Isolation Transport Unit (PITU) Device | - Healthcare Providers; - Patients | | QLE
05/05/2020 | Remote Patient QT Interval Monitor | PhysiolGuard, ECG-QT Analysis System | - Healthcare Providers; - Patients | - Lay User Instructions for Use; - MiCorA100 User Manual; - Analysis Platform User Manual | QNY
04/26/2020 | Remote Patient Monitor | VitalConnect, Inc., VitalPatch | - Healthcare Providers; - Patients | - Instructions for Use, VitalPatch Biosensor | QNY
04/21/2020 | Remote Patient Monitor | IntelliVue Patient Monitors, Philips Medizin Systeme Boeblingen GmbH | - Healthcare Providers; - Patients | - Instructions for IntelliVue Active Display; - Instructions for IntelliVue Patient Monitors | QLJ

## Respiratory Assist Devices EUAs

November 8, 2023 - The COVID-19 public health emergency (PHE) declared under section 319 of the Public Health Service (PHS) Act expired (https://www.hhs.gov/about/news/2023/02/09/fact-sheet-covid-19-public-health-emergency-transition-roadmap.html) on May 11, 2023. The COVID-19 enforcement policy guidances within scope of the Transition Plan for Medical Devices That Fall Within Enforcement Policies Issued During the Coronavirus Disease 2019 (COVID-19) Public Health Emergency (https://www.fda.gov/regulatory-information/search-fda-guidance-documents/transition-plan-medical-devices-fall-within-enforcement-policies-issued-during-coronavirus-disease) (see List 1) are no longer in effect.

Date EUA Issued | Device Type | Letter of Authorization | Fact Sheets | Other Documents | Assigned Product Code
06/30/2021 | Incentive Spirometer Accessory | Tidal Medical Technologies LLC, InSee | Healthcare Providers; Patients | Device User Manual | QOO
07/10/2020 | non-Invasive Vagus Nerve Stimulator | electroCore, Inc., gammaCore Sapphire CV | - Healthcare Providers; - Patients | - IFU | QPR
05/01/2020 | Respiratory Muscle Stimulator | Liberate Medical, LLC VentFree Respiratory Muscle Stimulator Device | - Healthcare Providers; - Patients | - IFU - Model A; - IFU - Model B | QPR
04/22/2020 | Respiratory Assist Device | ALung Technologies, Inc., Hemolung RAS | - Healthcare Providers; - Patients | - Instructions for Hemolung RAS; - Instructions for Hemolung CR4 | QLN
4/14/2020 | Diaphragmatic Pacing Therapy System (DPTS) | Lungpacer Medical, Inc. Diaphragm Pacing Therapy System (DPTS) | - Healthcare Providers; - Patients | - Letter Granting EUA Amendment(s) (May 5, 2020); - IFU; - Intermediate Cable IFU; - Live Catheter Kit IFU; - Handheld Controller IFU | QPR
04/13/2020 | Diaphragmatic Pacing Therapy System (DPTS) | Synapse Biomedical, Inc. TransAeris Diaphragmatic Pacing Therapy System (DPTS) | - Healthcare Providers; - Patients | - IFU; - Surgical Procedures IFU | QPR

## Ventilators and Ventilator Accessories EUAs

November 8, 2023 - The COVID-19 public health emergency (PHE) declared under section 319 of the Public Health Service (PHS) Act expired (https://www.hhs.gov/about/news/2023/02/09/fact-sheet-covid-19-public-health-emergency-transition-roadmap.html) on May 11, 2023. The COVID-19 enforcement policy guidances within scope of the Transition Plan for Medical Devices That Fall Within Enforcement Policies Issued During the Coronavirus Disease 2019 (COVID-19) Public Health Emergency (https://www.fda.gov/regulatory-information/search-fda-guidance-documents/transition-plan-medical-devices-fall-within-enforcement-policies-issued-during-coronavirus-disease) (see List 1) are no longer in effect.

- EUA Letter of Authorization - Ventilators, anesthesia gas machines modified for use as ventilators, and positive pressure breathing devices modified for use as ventilators (collectively referred to as "ventilators"), ventilator tubing connectors, and ventilator accessories
- Facts Sheets for Healthcare Providers
- Facts Sheets for Patients
- Appendix A: Criteria for Safety, Performance and Labeling

### Appendix B: Authorized Ventilators, Ventilator Tubing Connectors, and Ventilator Accessories (Updated October 4, 2022)

The tables below lists the ventilators, ventilator tubing connectors, and ventilator accessories authorized in this umbrella EUA during the COVID-19 public health emergency.

#### Authorized Ventilators

Date of Authorization | Manufacturer | Product Name | Device Description | Assigned Product Code | Intended Use
04/20/2022 | DIMAR S.r.l. a Socio Unico | Dimar NIV Helmet | Ventilator, non-continuous, Mask | QOQ | The Dimar NIMV Helmet is a single use patient interface indicated for the treatment of patients requiring non-invasive mechanical ventilation respiratory support therapy. It can be employed on conscious adult patients in upright or lying position. The Dimar NIMV Helmet is intended for prescription use only in a hospital setting and limited to use with respiratory support equipment containing Respiratory Rate and Pressure alarms. The NIMV Helmet is to be used under careful monitoring by qualified healthcare providers.
03/30/2021 | The Ventilator Project | AIRA V1.0 | Ventilator, Continuous, Facility Use | QOS | The AIRA Ventilator is indicated for the minimum ventilatory support of adult patients weighing at least 100 lbs. (45.4 kg) who require continuous ventilation. The ventilator is a restricted medical device intended for use by qualified, trained personnel under the direction of a doctor when an FDA-cleared ventilator is not available due to the COVID-19 pandemic.
03/22/2021 | O2U, Inc. | O2U Ventilator: Model 100 | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | The O2U ventilator is intended to provide continuous or intermittent ventilatory support for the care of adult patients who require mechanical ventilation when an FDA-cleared ventilator is not available due to the COVID-19 pandemic. The O2U ventilator is intended to be used in a hospital or other institutional healthcare environment. The ventilator is intended to be used by qualified and trained medical professionals for use with various combinations of specified patient circuits, interfaces (mask or intubation), and other accessories. The O2U ventilator is intended for single patient use for a period of up to 7 days. It is reusable but must be returned to the manufacturer for factory service (reprocessing) after each patient use, before use on next patient.
03/01/2021 | Nectar Product Development | BreathDirect BDR-19 | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | BreathDirect Ventilator (BDR-19) is intended to provide positive pressure ventilatory support for adults who may or may not (or no longer) need invasive ventilation.; The BDR-19 is intended to be used in the intensive care ward, intermediate care ward, long term acute care hospital or in the recovery room. The BDR-19 is intended to be attended by a professional operator for patients who are dependent on mechanical ventilation and is intended for use in critical care environments in a professional healthcare facility.; The BDR-19 is to be used only by order of a qualified physician and by medically qualified personnel, trained in the operation, and within the stated specification limits.; Due to the limited battery life, the BDR-19 is not intended for use as a transport ventilation device.; The BDR-19 is intended for a 2-year design life and is for Emergency Use Authorization (EUA) in the United States of America (USA).
02/24/2021 | CAE Healthcare | CaeAir1 | Emergency Ventilator | QOT | The CAEAir1 mechanical ventilator is indicated to provide emergency continuous invasive ventilatory support with the provision of an adjustable percentage of oxygen in the breathing gas for adult patients who require mechanical ventilation when an FDA-cleared ventilator is not available due to the COVID-19 pandemic. The ventilator is intended for use in healthcare facilities under the direction of a physician.
02/23/2021 | DeVilbiss | IntelliPAP/SleepCube Model DV56 ST Series Bilevel | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | The DeVilbiss IntelliPAP/SleepCube Model DV56 ST Series Bilevel is intended for use in treating OSA and respiratory insufficiency non-invasively in spontaneously breathing patients 30 Kg and above by means of application of positive air pressure. The Device is to be used in home and clinical environments.
02/08/2021 | Löwenstein Medical Technology GmbH + Co. KG | LUISA Life Support Ventilator LM150TD | Emergency Ventilator | QOT | The LUISA provides continuous or intermittent ventilatory support for adult patients who require mechanical ventilation. The LUISA device is intended to be used in home, institution/hospital and portable applications for both invasive and non-invasive ventilation.; Caution: The LUISA device is not intended for use as an emergency transport ventilator.; Caution: In the US, Federal law restricts this device to sale by or on the order of a physician.; The LUISA Ventilator has NOT been FDA cleared or approved. The LUISA Ventilator has been authorized by FDA under an EUA and is authorized only for the duration of the declaration that circumstances exist justifying the authorization of the emergence use of ventilators, ventilator tubing connectors, and ventilator accessories under section 564(b)(1) of the Act U.S.C. § 360bbb-3(b)(1), unless the authorization is terminated or revoked sooner.; This EUA will be effective until the declaration that circumstances exist justifying the authorization of the emergence use of ventilators, ventilator tubing connectors, and ventilator accessories during the COVID-19 pandemic is terminated under section 564(b) (2) of the Act or the EUA is revoked under section 564(g) of the Act.
12/04/2020 | Skanray USA | SKANRESPIRO/SKANRESPIRO PLUS | Emergency Ventilator | QOT | SKANRESPIRO Ventilator is intended for continuous and intermittent mechanical ventilation to provide positive pressure ventilatory support to Adults and Pediatrics patients aged two (2) years and above. It is intended to be used within hospital intensive care ward, recovery room, emergency medical care. SKANRESPIRO is portable and can be mounted on a trolley for intra-hospital transport. SKANRESPIRO is intended to be used by qualified and trained personnel under the supervision of Medical practitioner, within its stated technical specification.
12/02/2020 | CorVent Medical, Inc. | CorVent RESPOND 19 Ventilator | Emergency Ventilator | QOT | The RESPOND 19 Ventilator is an electrically powered ventilator intended to provide continuous, invasive ventilatory support for the care of adult patients (of at least 60 lbs.) who require mechanical ventilation. The RESPOND 19 Ventilator is intended for use in a hospital, or similar clinical environments, by qualified, trained personnel under the direction of a licensed physician. Personnel must become thoroughly familiar with these instructions prior to using the RESPOND 19 Ventilator.
09/23/2020 | Belkin International, Inc. | Belkin FlexVent Gas Operated Emergency Ventilator (Resuscitator) | Emergency Ventilator | QOT | The FlexVent is intended for use only by properly trained personnel on adult patients who require mechanically-assisted emergency, short-term constant flow, pressure cycled ventilation or resuscitation in an emergency situation or during transportation.
09/18/2020 | Medicreations LLC | MediVent ICU- MCV | Emergency Ventilator | QOT | The MediVent ICU series ventilator system is intended to provide continuous or intermittent ventilation for adult patients who require invasive or noninvasive respiratory support. The MediVent ICU offers mandatory and spontaneous ventilation modes as well as respiratory monitoring. The MediVent ICU is intended for use by qualified, trained personnel under the direction of a physician in hospitals and hospital-type facilities. MediVent ICU series ventilator system is not cleared or approved in the United States and has been granted an Emergency Use Authorization by the FDA for use during the COVID-19 pandemic. The MediVent ICU series ventilator system provides patients with emergency ventilatory support when no cleared or approved standard ventilators are available.
08/21/2020 | MICo Medical s.r.o. | MICo Medical CoroVent | Emergency Ventilator | QOT | The CoroVent ventilation device is intended for the emergency, invasive ventilation of adult patients greater than 21 years of age, with body weight greater than 50 kg (110 lbs), and with respiratory failure due to COVID-19. The CoroVent provides pressure-limited continuous mandatory ventilation (VC-CMV) to ventilation dependent patients. The CoroVent is intended to be used by physicians in hospital facilities. The CoroVent is not a transport ventilator. The CoroVent is not cleared or approved in the United States and has been granted an Emergency Use Authorization by the FDA for use during the COVID-19 pandemic. The CoroVent provides patients with emergency ventilatory support when no cleared or approved standard ventilators are available.
08/18/2020 | Breas Medical Inc | Z2 Bilevel | Ventilator, Continuous, Minimal Ventilatory Support | QOR | The Z2 Bilevel is intended to provide continuous or intermittent ventilatory support for the care of adults who require mechanical ventilation. The Z2 Bilevel is for patients under the supervision of healthcare professionals within a healthcare facility. For invasive ventilation, the Z2 Bilevel is to be used in the Intensive Care Unit (ICU) only. For non-invasive ventilation, the Z2 Bilevel is to be used in the Emergency Room / ICU environment only. The Z2 Bilevel is provided under FDA Emergency Use Authorization (EUA) relating to the COVID-19 pandemic.
08/07/2020 | Hillrom | Life 2000 Ventilation System Product No. BT-V5 | Ventilator, Continuous, Facility Use | QOS | The Life20000 Ventilator is intended to provide continuous or Intermittent ventilatory support for the care of individuals who require mechanical ventilation. The ventilator is intended for use by qualified, trained personnel under the direction of a physician. Specifically, the ventilator is applicable for adult patients who require the following types of ventilatory support:; - Positive Pressure Ventilation, delivered invasively (via ET tube) or non-invasively (via mask).; - Assist/Control mode of ventilation.; The ventilator is suitable for use in Institutional settings.
08/04/2020 | VORTRAN Medical Technology 1, Inc | VORTRAN GO2VENT with PEEP Valve | Emergency Ventilator | QOT | The VORTRAN GO2VENT with PEEP Valve is to be used by properly trained personnel to deliver emergency, short term, constant flow, pressure cycled ventilator support on patients weighing 10kg and above.
08/04/2020 | Nanotronics Imaging, Inc | nHale BiPAP device (Amended October 3, 2022) | Ventilator, Continuous, Minimal Ventilatory Support | QOR | The nHale BiPAP is intended to be used by healthcare providers in healthcare facilities(e.g., hospitals, assisted living facilities, nursing homes) as well as spaces converted for the care of large numbers of COVID-19 patients (e.g., convention centers, university dormitories, motels, etc.) to support spontaneously breathing adults weighing over 30kg suffering from COVID-19 disease. The nHale BiPAP is a non-invasive ventilator designed to be used in non-life-threatening situations, for spontaneously breathing patients, where a patient is in need of breathing assistance but is not in need of invasive ventilatory support based on standard medical protocols.
07/31/2020 | LifeMech, Inc. | LifeMech A-VS | Emergency Resuscitator | QOU | Intended for use by qualified, trained personnel under the direction of a physician only when an FDA-cleared clinical ventilator is not available during the COVID-19 pandemic.; The LifeMech A-VS is an automated manual resuscitator bag designed to provide basic ventilator functionality to a single patient at a time, in an emergency situation when there are no other options available to the patient. It does not replace standard mechanical ventilation but acts as a bridge to standard mechanical ventilation. The A-VS has been designed to meet AAMI guidelines for Emergency Use Ventilators and functions with existing bag valve masks (BVM)/manual resuscitator bags. The manual resuscitator bags that are currently indicated for use with this device are:; - Ambu Spur II with POP-off valve; - Smiths Medical Portex 8500P
06/26/2020 | Stewart & Stevenson Healthcare Technologies, LLC | Apollo ABVM | Emergency Resuscitator | QOU | The Apollo ABVM is an emergency use resuscitator intended for short term use under the direction of critical care physicians and respiratory therapists to provide continuous or intermittent mechanical ventilation to a patient only when an FDA-cleared clinical ventilator is not available during the COVID-19 pandemic. This device mechanically actuates a manual resuscitator and may assist patients in breathing support in order to meet emergency demands for ventilators. The Apollo ABVM is intended for application for adult patients only. The Apollo ABVM is restricted medical device intended for use in hospitals only
06/26/2020 | SAGICO USA, LLC | V2O SAGICO SYSTEM | Ventilator, Continuous, Facility Use | QOS | The V2O SAGICO SYSTEM Ventilator is an electronically controlled, electronically powered machine, which is used in ICU, in Respiratory Department or Emergency Department for the rescue and therapy of the patient with respiratory insufficiency, and in other departments for providing respiratory support for the patient. The V2O SAGICO SYSTEM is to be used only by properly trained healthcare professionals.
06/24/2020 | Air Boost | AustinP51 | Emergency Resuscitator | QOU | The AustinP51 is a portable emergency use resuscitator designed to provide either continuous or intermittent ventilatory support for patients requiring mechanical ventilation through volume control. The AustinP51 should only be used by those professionals who are qualified and trained in the use of general ventilation equipment, or who are specifically trained on the AustinP51 system. The AustinP51 emergency use resuscitator (EURS) is intended to treat adults during the COVID-19 pandemic as authorized by the appropriate FDA EUA and should only be used when no FDA cleared or approved ventilators are available.
06/19/2020 | World Ventilator Foundation (WVF) | WorldVent Ventilator | Emergency Ventilator | QOT | The World Ventilator Foundation (WVF) WorldVent is intended to provide continuous ventilation for adult patients who require invasive respiratory support. It provides Volume Controlled Ventilation (VCV) mode provided in both mandatory and spontaneous assist control fashions as well as respiratory monitoring.The WorldVent is intended for use in hospitals and hospital-type facilities by properly trained healthcare professionals for short term ventilation in the adult population when no FDA cleared ventilators are available during the COVID-19 pandemic.
06/17/2020 | NeoNatal Rescue, LLC | AdultLife Pro Ventilator | Emergency Ventilator | QOT | The AdultLife Pro Ventilator is intended for emergency ventilatory care of hospitalized adult patients greater than 35kg in weight who are experiencing respiratory insufficiency or respiratory failure. The unit is designed to be used at the bedside in hospital environments, from an intensive care unit to other facilities, for use by trained professionals in respiratory care. Patients can be treated with the AdultLife Pro Ventilator for as long as their symptoms persist. AdultLife Pro Ventilator provides patients with emergency ventilatory support when no alternative standard ventilators are available.
06/10/2020 | Enexor BioEnergy, LLC | X-VENT Emergency Ventilator | Emergency Ventilator | QOT | The X-VENT is a continuous use, emergency ventilator intended to provide invasive and non-invasive ventilatory support for adult patients > 35 kg of weight with respiratory insufficiency or failure. The X-VENT is to be used under prescription only and is intended to be used in hospitals, hospital-type facilities, or other institutional health care environments. X-VENT provides patients with emergency ventilatory support when no alternative standard ventilators are available.; The X-VENT is intended for use by qualified physicians and respiratory therapists who have undergone training on the use of the X-VENT ventilator. It provides three (3) modes of ventilation: pressure control, volume control, and assist control (volume and pressure).
06/09/2020 | Nanotronics Imaging, Inc | nHale BiPAP device | Ventilator, Continuous, Minimal Ventilatory Support | QOR | The nHaleTM is a bi-level positive air pressure (BIPAP) device to support respiratory therapy of spontaneously breathing adults weighing over 30kg suffering from COVID-19 disease in traditional healthcare facilities (e.g., hospitals, assisted living facilities, nursing homes) as well as spaces converted for the care of large numbers of COVID-19 patients (e.g., convention centers, university dormitories, motels, etc.). The nHaleTM is a non-invasive ventilator designed to be used in non-life-threatening situations, for spontaneously breathing patients, where a patient is in need of breathing assistance but is not in need of invasive ventilatory support based on standard medical protocols.
06/08/2020 | BioMedInnovations, LLC | SuppleVent | Emergency Ventilator | QOT | The SuppleVent Ventilator is an Emergency Use Ventilator (EUV) indicated to provide continuous ventilatory support of adult patients who require mechanical ventilation when an FDA cleared ventilator is not available due to COVID-19 pandemic. The ventilator is intended for institutional use by qualified, trained personnel under the direction of a doctor. Institutional use includes Intensive Care Unit (ICU) or other hospital environments including intra-hospital transport and temporary hospital facilities.
06/01/2020 | NASA Jet Propulsion Laboratory | VITAL Compressor | Emergency Ventilator | QOT | The VITAL Compressor ventilator is intended to provide continuous ventilatory support for adult (body weight ≥ 50 kg) patients who require mechanical ventilation. VITAL provides patients with emergency ventilatory support when no alternative standard ventilators are available. The VITAL Compressor ventilator is a restricted medical device intended for use by qualified healthcare provider who understands the functionality of the device operating under the direction of a physician.
06/01/2020 | Fitbit, Inventec Appliances Corp (Authorized Distributor) | Fitbit Flow (Amended October 8, 2020) | Emergency Resuscitator | QOU | The Fitbit Flow is indicated for the continuous mechanical ventilatory support of adult patients. The Fitbit Flow is an accessory to a manual resuscitator and consists of a reusable mechanical actuator and the single-use, disposable tubing assembly. The Fitbit Flow supports conventional Volume Control and Pressure Control modes of ventilation, as well as an "Assist Control" feature to support breaths triggered by the patient. The Fitbit Flow is intended for use by qualified, trained personnel under the direction of a physician only when an FDA-cleared clinical ventilator is not available during the COVID-19 pandemic.
05/22/2020 | Guangzhou Hypnus Healthcare Co., Ltd | BA825W, BA825, ST830W and ST830 | Ventilator, Continuous, Minimal Ventilatory Support | QOR | Hypnus Positive Airway Pressure Device 8 Series are indicated to provide non-invasive positive airway pressure to spontaneously breathing patients weighing over 30kg with Obstructive Sleep Apnea (OSA), and BPAP-T mode and BPAP-ST mode can be used for respiratory insufficiency. This device is intended for hospital and home use. It is not intended for patients dependent on mechanical ventilation.
05/22/2020 | Origin Medical Devices Inc. | Panther 5 Model P5DLVENT | Ventilator, Continuous, Facility Use | QOS | The PANTHER 5 ventilator is intended to provide continuous ventilation to adult patients requiring respiratory support. The device is intended for facility use under clinical supervision.
05/20/2020 | SysMed (China) Co., Ltd | Resware BI 20 S, Resware BI Auto S, Resware BI 25 S/T, Resware BI 30 S/T, ZiZ Auto, Aurora Bi-Level S, Aurora Bi-Level S/T, Aurora Bi-Level Auto S | Ventilator, Continuous, Minimal Ventilatory Support | QOR | The Resware, ZiZmer, and Aurora CPAP products provide positive pressure therapy for the treatment of obstructive sleep apnea or respiratory insufficiency in spontaneously breathing adults weighing over 30 kg (66 lbs). This product can be used in the home as well as in clinical/hospital environments.
05/18/2020 | SysMed (China) Co., Ltd | VM series- DPAP20 Plus, DPAP25 Plus, DPAP25 Pro, DPAP30 Pro | Ventilator, Continuous, Minimal Ventilatory Support | QOR | The device delivers positive pressure therapy for the treatment of Obstructive Sleep Apnea or respiratory insufficiency in spontaneously breathing adults weighing over 30kg (66 lbs). It is for use in the home or hospital/institutional environment.
05/15/2020 | CMI Health | Beijing Aeonmed Shangrila510S | Emergency Transport Ventilator | QOT | The Shangrila510S is an emergency transport ventilator intended to be used to provide ventilatory support in the emergency rooms of hospitals, transfer after operations, field and occasions where first aid or transfer is needed for care of adult ,pediatric patients weighting at least 3.5 kg who require mechanical ventilation.
05/12/2020 | Lanick Med Systems LLC | Lyra x1 and Lyra x2 Ventilators | Ventilator, Continuous, Facility Use | QOS | The LYRA xl ventilator is a mechanical ventilator designed to provide invasive and noninvasive, continuous or intermittent. respiratory support for pediatric and adult patients.; Intended areas of use:; - In the intensive care ward or in the recovery room.; - During transfer of-ventilated patients within the hospital. The LYRA xl ventilator is intended for use by qualified. trained personnel under the direction of a physician and within the limits of its stated technical specifications.; The LYRA x2 ventilator is a mechanical ventilator designed to provide invasive and noninvasive, continuous or intermittent, respiratory support for pediatric and adult patients. Intended areas of use:; - In the intensive care ward or in the recove1y room; - During transfer of ventilated patients within the hospital. The LYRA x2 ventilator is intended for use by qualified, trained personnel under the direction of a of a physician and within the limits of its stated technical specifications. May 12,
05/08/2020 | Taiyuan Shanghai Medical | Fabius Plus / Fabius Plus XL | Gas Machine, Anesthesia | QOT | Fabius plus is an inhalation anesthesia workstationfor use in operating, induction and recovery rooms.It may be used with O2, N2O, and AIR supplied by a medical gas pipeline system or by externally mounted gas cylinders.Fabius plus is equipped with a compact breathing system, providing fresh-gas decoupling, PEEP, and pressure limitation. The following ventilation options are available: –Volume Controlled Ventilation -Pressure Controlled Ventilation (Optional) –Pressure Support (Optional) –SIMV/PS (Optional) –Manual Ventilation –Spontaneous Breathing. Fabius plus is equipped with an electrically driven and electronically controlled ventilator and monitors for airway pressure (P), volume (V), and inspiratoryoxygen concentration (Fi02).
05/08/2020 | Somnetics International, Inc. | Transcend 3 BiPAP | Ventilator, Non-Continuous | QOQ | The Transcend 3 BiPAP is intended for the therapy of adults weighing over 66 pounds (30 kg) with mild to moderate respiratory distress. The device delivers positive airway pressure (PAP), specifically positive end-expiratory pressure (PEEP) with ventilatory support, to provide ventilation assistance and breathing support. The device is intended for use in healthcare settings.
05/07/2020 | AutoMedX, Inc. | SAVe II+ (M50016, M50017) | Powered Emergency Ventilator | QOT | The SAVe II series are intended to provide ventilatory support for adults during CPR or when Positive-Pressure Ventilation (PPV) is required to manage Acute Respiratory Failure (ARF) or other situations where mechanical ventilation is needed. The SAVe II series are appropriate for adults that weigh at least 45 kg. It is intended to be used in pre-hospital, field hospitals, outpatient environments, hospitals, ICU's, transport environments or any other healthcare environment requiring the use of a ventilator.
05/06/2020 | Hunan Beyond Medical Technology Co., Ltd | BEYOND C20A CPAP | Ventilator, Continuous, Minimal Ventilatory Support | QOR | The C20A CPAP is designed for delivery of positive airway pressure to provide non-invasive ventilation for adult patients with respiratory insufficiency or obstructive sleep apnea (OSA) in home or hospital environment.
05/06/2020 | Hunan Beyond Medical Technology Co., Ltd | BEYOND B30P BiPAP | Ventilator, Continuous, Minimal Ventilatory Support | QOR | The B-30P BiPAP is designed for delivery of positive airway pressure to provide non-invasive ventilation for adult patients with respiratory insufficiency or obstructive sleep apnea (OSA) in home or hospital environment. The device is to be used only under the prescription of a licensed health care professional.
05/06/2020 | Guangzhou Hypnus Healthcare Co., Ltd. | Hypnus ST730 | Ventilator, Continuous, Minimal Ventilatory Support | QOR | The device is indicated to provide non-invasive positive airway pressure to spontaneously breathing patients weighing over 30kg with Obstructive Sleep Apnea (OSA) or respiratory insufficiency. This device is intended for hospital and home use. It is not intended for patients dependent on mechanical ventilation.
05/05/2020 | Vayu Global Health Innovations | Vayu bubble Continuous Positive Airway Pressure Circuit ("Vayu bCPAP') | Continuous Positive Airway Pressure Circuit | QOQ | The Vayu bCPAP system is intended to provide continuous positive airway pressure in the hospital environment to spontaneously breathing neonates and infants, up to 5 kg in weight, that require respiratory support due to conditions associated with prematurity, such as Respiratory Distress Syndrome, or other conditions where the physician desires and prescribes CPAP.
05/02/2020 | BMC Medical CO., LTD., China | Luna G3 BPAP S/T- LG3800-G3 B30VT | Ventilator, Continuous, Minimal Ventilatory Support | QOR | The G3 B30VT BPAP is a Bi-level PAP (Bi-level Positive Airway Pressure) device, which is intended to provide non-invasive ventilation for patients with Obstructive Sleep Apnea (OSA) and Respiratory Insufficiency. These devices are intended for adult patients by prescription in the home or hospital/institutional environment.
05/02/2020 | ZIBO ZHONGXUN MEDICAL EQUIPMENT CO. LTD | ZXH-550 | Emergency Ventilator | QOT | The ventilator is intended to provide continuous ventilatory support for adult patients who require mechanical ventilation. The ventilator is a restricted medical device intended for use in hospitals and hospital-type facilities, which provide respiratory care for patients requiring respiratory support.
05/02/2020 | JIUXIN MEDICAL | JIXI H-100 | Emergency Ventilator | QOT | The ventilator is intended to provide continuous ventilatory support for adult patients who require mechanical ventilation. The ventilator is a restricted medical device intended for use in hospitals and hospital-type facilities, which provide respiratory care for patients requiring respiratory support.
05/01/2020 | Elemaster S.p.A. Tecnologie Elettroniche | Mechanical Ventilator Milano (MVM) | Emergency Ventilator | QOT | The MVM is a pressure-regulated mechanical ventilator designed for adult patients to provide emergency ventilatory support when no alternative standard ventilators are available.; The device should be used by:; - healthcare professionals responsible for the treatment of a patient on ventilation support equipment, and; - staff who will be performing routine maintenance on the device. The MVM is intended to provide ventilation support for intensive therapy during the COVID-19 pandemic for patients who require mechanical ventilation and weigh more than 40 kg (88 lbs).
05/01/2020 | Wilcox Industries Corp | Wilcox PATRIOT SAVR (Amended July 21, 2020) | Emergency Ventilator | QOT | PATRIOT SAVR is indicated for emergency continuous or intermittent mechanical support of adult patients when their ventilatory status cannot be maintained by high flow oxygen by nasal cannula, and a FDA cleared ventilator is not available. Target PatientsThe SAVR is applicable for adult patients who require the general types of invasive or non-invasive ventilatory support, as prescribed by an attending doctor:; - Positive Pressure ventilation; - Assist/Control, SIMV modes of ventilation; The SAVR provides multiple alarms states but minimal monitoring capability, and thus the level of patient criticality should be considered before use. It is not indicated for Level 3 Critical Care patients. Target EnvironmentsThe ventilator is suitable for use in institutional and portable settings. Target OperatorsThis ventilator must be used only under the responsibility and on the prescription of a doctor.The ventilator may be operated by the following caregivers:; - Respiratory therapists; - Doctors; - Nurses
04/30/2020 | NASA Jet Propulsion Laboratory | VITAL ventilator | Emergency Ventilator | QOT | The VITAL ventilator is intended to provide continuous ventilatory support for adult (body weight ≥ 50 kg) patients who require mechanical ventilation. VITAL provides patients with emergency ventilatory support when no alternative standard ventilators are available. The VITAL ventilator is a restricted medical device intended for use by qualified healthcare provider who understands the functionality of the device operating under the direction of a physician.
04/30/2020 | Venti-Now | Venti-Now ResuscitatorModel JM-P2020A | Emergency Resuscitator | QOU | The Venti-Now resuscitator is indicated for continuous or intermediate mechanical support of adult patients who require mechanical ventilation. The resuscitator is a restricted medical device intended for use by qualified, trained personnel under the direction of a Physician for COVID-19/Emergency use when no FDA-cleared ventilators are available. It is essential to read, understand, and follow these instructions before using the Venti-Now resuscitator. The Venti-Now resuscitator is a volumetric device that compresses a disposable BVM bag to create the positive pressure airflow to the patient. As such its use is applicable for use where a BVM unit is in use today. In addition, the unit has means to control Tidal volume, Inhalation/Exhalation rates, and bpm that make it suitable for a broader range of target patients than manually pumped BVM bags.
04/28/2020 | Shenzhen Yamind Medical Tech | CPAP Devices: DM28-20C-G;Auto CPAP Devices: DM28-20A-W, DM28-20A-WP;BiPAP Devices: DM28-20S-G, DM28-20SA-G, DM28-20ST-G, DM28-25S-B, DM28- 25SA-BP, DM28-25ST-BP, DM28-30ST-B, DM28-30ST-BP, DM28-30STA-BP | Ventilator, Non-Continuous | QOQ | The subject device provides noninvasive ventilation for patients with obstructive sleep apnea. It is indicated for adult patients weighing more than 30kg and can be used in homes and hospitals. It is not intended for life support, or for central sleep apnea. It may be used to improve the oxygenation and ventilation in the treatment of acute respiratory illness or difficulty breathing.
04/27/2020 | Resvent Medical Technology CO., Ltd's | iBreeze 30STA device | Ventilator, Non-Continuous | QOQ | The iBreeze 30STA PAP system delivers positive airway pressure therapy for the treatment of Obstructive Sleep Apnea (OSA) in spontaneously breathing patients weighing over 30kg (66lbs), it is for use in the home, hospital, or institutional environment.
04/24/2020 | AutoMedX Inc. | SAVe II Series Ventilator | Powered Emergency Ventilator | QOT | The SAVe II series are intended to provide ventilatory support for adults during CPR or when Positive-Pressure Ventilation (PPV) is required to manage Acute Respiratory Failure (ARF) or other situations where mechanical ventilation is needed. The SAVe II series are appropriate for adults that weigh at least 45 kg. It is intended to be used in pre-hospital, field hospitals, outpatient environments, hospitals, ICU's, transport environments or any other healthcare environment requiring the use of ventilator.
04/24/2020 | SLS Medical Technology Corp. Ltd. | CP101/CP101S Series | Ventilator, Non-Continuous | QOQ | This CPAP (Continuous Positive Airway Pressure) product can provide a continuous and positive airway in patients with respiratory insufficiency. This product provides 4~20 cmH2O of positive airway pressure and is equipped Oxygen Inlet to allow multiple Oxygen sources i.e. Oxygen generator. It is intended to be used under prescription of a physician.
04/24/2020 | Zhejiang LifeMed Technology Co., Ltd. | LA Series Ventilators LA20C, LA20A, LA20B, LA20B, LA25B, LA25B | Ventilator, Non-Continuous | QOQ | The LifeMed LA Series Ventilator is a ventilator indicated for the treatment of respiratory insufficiency in patients weighing more than 30kg (66 lbs). It is intended for hospital use. The built-in humidifier is intended for repeated use by the same patient.
04/23/2020 | Amsino International Inc's | YUWELL YH-725 BiPAP | Ventilator, Non-Continuous | QOQ | The YH-725 Bi-level device is indicated for treatment of sleep apnea hypopnea syndrome in patients weighing more than 66lb (30kg). It is intended both for home use and hospital use. The humidifier is intended for single patient use in the home environment and re-use in a hospital/institutional environment.
04/22/2020 | Virgin Orbit | Virgin Orbit Resuscitator (AmendedApril 23, 2020) | Emergency Resuscitator | QOU | This emergency use resuscitator is for use with appropriate critical care monitoring on adults (>18 years of age) requiring mechanical ventilation during declaration of National Emergency where ventilator need has surpassed ventilator supply and no other ventilatory support devices are available.
04/20/2020 | 3B Medical Inc | Luna G3 B30VT | Ventilator, Continuous, Minimal Ventilatory Support | QOR | The G3 B30VT BPAP is a Bi-level PAP (Bi-level Positive Airway Pressure) device, which is intended to provide non-invasive ventilation for patients with Obstructive Sleep Apnea (OSA) and Respiratory Insufficiency. These devices are intended for adult patients by prescription in the home or hospital/institutional environment.
04/20/2020 | Resvent | iBreeze PAP | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | The iBreeze PAP system delivers positive airway pressure therapy for the treatment of Obstructive Sleep Apnea (OSA) in spontaneously breathing patients weighting over 30kg (66lbs) for use in the home, hospital, or institutional environment.
04/17/2020 | Spiro Devices LLC | Spiro Wave (Amended June 8, 2020) | Emergency Resuscitator | QOU | The Spiro Wave is an automated manual resuscitator that has been designed specifically to meet AAMI guidelines for emergency use resuscitators and provide respiratory support for adult patients in acute respiratory failure. It does not replace standard mechanical ventilation but acts as a bridge to standard mechanical ventilation by increasing the functionality of existing manual resuscitator bags. The Spiro Wave is compatible with existing manual resuscitator bags, and clinicians can control key ventilatory parameters. The Spiro Wave is designed to provide basic ventilator functionality to a single adult patient, in an emergency situation when there are no other options available to the patient.
04/17/2020 | RESMED | AirCurve 10 ST-A | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | The AirCurve 10 ST-A is indicated to provide noninvasive ventilation for patients weighing more than 30lbs (13 kg) with respiratory insufficiency or obstructive sleep apnea (OSA). The iVAPS mode is indicated for patients weighing more than 66lbs (30 kg). The AirCurve 10 ST-A is intended for home and hospital use. The humidifier is intended for single patient use in the home environment and re-use in a hospital/institutional environment.
04/17/2020 | PVA | PREVENT | Emergency Resuscitator | QOU | PREVENT is indicated for emergency resuscitation with appropriate critical care monitoring on adult patients weighing at least 66 pounds that require mechanical respiratory support where standard ventilators are not available during the National Emergency.
04/16/2020 | Hillrom | MetaNeb 4 | Intermittent Positive Pressure Breathing Device | QOQ | The MetaNeb 4 System is indicated for mobilization of secretions, lung expansion therapy, the treatment and prevention of pulmonary atelectasis, and also has the ability to provide supplemental oxygen when used with compressed oxygen. Patient Population â€" 5 years old and above whom can follow verbal instructions. Environment of Use â€" Hospitals, sub-acute and nursing facilities, physician offices, clinics, and home settings.
04/14/2020 | University of Minnesota Medical School and Boston Scientific Corporation | Coventor Adult Manual Resuscitator Compressor | Emergency Resuscitator | QOU | This device is intended for compression of an adult manual resuscitator device intended for pulmonary resuscitation of adult patients for whom no other appropriate means of mechanical ventilation exists due to resource limitations from pandemic conditions in the region of use.
04/14/2020 | Umbulizer | UMV-001 EUA | Emergency Resuscitator | QOU | The Umbulizer UMV-001 is intended to provide ventilatory support to adults when Positive Pressure Ventilation (PPV) is required to manage Acute Respiratory Failure (ARF). The Umbulizer series is appropriate for adults that weigh at least 45 kg (approximately 99 lbs). It is intended to be used in a pre-hospital, field hospital, and transport environments, as well as hospital settings where sufficient standard ventilators are not available.
04/13/2020 | SecondBreath LLC | Pneumatic Resuscitator device | Emergency Resuscitator | QOU | The SecondBreath LLC Pneumatic Resuscitator is an electric pneumatic ventilator. This system uses compressed air to drive a pneumatic cylinder equipped with a plunger to compress an AMBU bag and provides the patient with positive inspiratory pressure. This device is intended only for use for transport or emergency resuscitation unless there are no other ventilation modalities available due to emergency resource limitations. The user can set tidal volume (TV), inspiratory to expiratory (I:E) ratio, respiratory rate, expiratory pause, and inspired oxygen (FiO2) at a constant 1.0 rate. Pure oxygen can be delivered through the AMBU bag. The device can only be operated in volume control (VC) continuous mandatory ventilation mode. Continuous end-tidal carbon dioxide monitoring is required for safe use of this device since there are no alarms for TV not met/exceeded. Additionally, power supply needs to be monitored as there is a loss of power alarm but no backup power supply to provide ventilation.
04/08/2020 | AMBULANC TECH.CO.,LTD | Models 6000S, T5, T7 | Emergency Transport Ventilator | QOT | Model 6000S - The 6000S ventilator is intended to provide continuous ventilation for patients who require invasive or noninvasive respiratory support and weigh more than 15KG (Infants, children, adults). The 6000S ventilator offers IPPV (Intermittent Positive Pressure Ventilation Mode), AC (Assisted Control Ventilation Mode), CPR auxiliary modes, etc. The 6000S ventilator can display the monitoring pressure waveform and interface parameters (Pmax, Pmean) in real time. The 6000S Ventilator is intended for use in emergency treatment outside the hospital and in-hospital transportation, and it runs under the central oxygen supply of the hospital or an oxygen cylinder pressure greater than 2.7Bar.; Model T5 - The T5 ventilator is intended to provide continuous ventilation for patients who require invasive or noninvasive respiratory support (Infants, children, adults), with a tidal volume greater than 50ml. The T5 ventilator offers capacity control (IPPV, VAC, VSIMV), pressure control (PCV, PAC, PSIMV), noninvasive breathing (CPAP) modes, etc. It also has CPR auxiliary function and ETCO2 detection function. The T5 ventilator can display pressure waveform, ETCO2 waveform and parameters (pressure, tidal volume, ETCO2) in real time. The T5 ventilator is intended for use in out-of-hospital emergency treatment (first aid treatment on the ground, at sea, and in the air) and in-hospital transportation run under the central oxygen supply of the hospital or an oxygen cylinder pressure greater than 2.7Bar. Model T7 - The T7 ventilator is intended to provide continuous ventilation for patients with weight greater than 2kg (infants, children, adults) who require invasive or noninvasive respiratory support, with a tidal volume greater than 20ml. The T7 ventilator offers volume control (IPPV, VAC, VSIMV), pressure control (PCV, PAC, PSIMV), non-invasive (CPAP, CPAP + PSV, BiPPV, APRV), advanced ventilation (PRVC, PRVC + PSV, APRV + PSV), resuscitation mode (CPR, RSA, HFNC), etc.; and has functions such as ETCO2, ring chart, respiratory mechanics and trend chart. The T7 ventilator can display pressure waveform, flow waveform, tidal volume waveform, ETCO2 waveform and interface parameters (pressure, tidal volume, ETCO2, FIO2) in real time. The T5 ventilator is intended for use in out-of-hospital emergency treatment (first aid treatment on the ground, at sea, and in the air) and in-hospital transportation run under the central oxygen supply of the hospital or an oxygen cylinder pressure greater than 2.7Bar.
04/08/2020 | Philips Respironics | E30 ventilator | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | The Philips Respironics E30 ventilator is intended to provide invasive and non-invasive ventilatory support for individuals with Respiratory Insufficiency. It is specifically for the care of adult and pediatric patients >7 years of age and >18kgs. It is intended to be used in the hospital or other institutional healthcare environments, as well as spaces converted for the care of large numbers of COVID-19 patients (e.g. convention centers, university dormitories, motels). The Philips Respironics E30 ventilator is intended for use by qualified, trained personnel under the direction of a physician.
04/08/2020 | Incoba LLC | Apogee | Oxygen Conserver | QOQ | The Apogee gas conserver is intended as a delivery device for medical grade oxygen from high-pressure oxygen cylinders. This is an ambulatory device which allows patients to ambulate longer than they would with a continuous flow regulator on the same cylinder. The Apogee is intended to be used in the hospital, healthcare facilities, or home care environments.; The Apogee Device shall be used by trained professionals either in a doctor's office or clinical setting initially. However, once recommended by the physician or healthcare provider the device can be prescribed for use within a home environment for subsequent treatments.; The Apogee Device essential performance is to provide short puffs of air during operation as noted on the display for nasal output L or R. In the event air is not delivered use the bypass adaptor and return the device to Dynaris for immediate replacement.; The Apogee unit is a regulated device and carries warnings and cautions regarding safe use of this product. Failure to read this manual and adhere to the warnings and caution stated within the manual can affect device performance and potentially harm to the user.; The Apogee Device and its accessories do not contain any natural rubber latex-containing components.
04/07/2020 | DrÃ¤gerwerk AG & Co. KGaA | Atlan A350 and Atlan A350 XL | Gas-Machine, Anesthesia | QOT | This device is intended for use in anesthetizing adults, pediatric patients, and neonates. The device can be used for mechanical ventilation, manual ventilation,pressure-supported spontaneous breathing, and spontaneous breathing. The device is equipped with the following basic functions:; - Ventilation monitoring; - Inspiratory O2 measurement; - Device monitoring; - Anesthetic gas receiving system; The following options are additionally available:; - Patient-gas measurement module for O2, CO2, N2O, and anesthetic gases; - O2 insufflation; Anesthesia is achieved through a mixture of pure oxygen and Air (medical compressed air) or pure oxygen and nitrous oxide, with the addition of volatileanesthetic agents. Ventilation is accomplished on the patient through a laryngeal mask, a breathing mask, or an endotracheal tube. The integrated breathing system can be used with partial rebreathing (low-flow or minimum-flow).
04/07/2020 | VenTec Life Systems | V+Pro Emergency Ventilator | Ventilator, Continuous | QOS | VOCSN Unified Respiratory System is intended to provide continuous or intermittent ventilatory support for the care of individuals who require mechanical ventilation. It may be used in invasive and non-invasive applications. VOCSN is intended for pediatric through adult patients weighing at least 5 kg. It is intended for use in home, hospital, institutional, and transport settings, including portable applications.
04/06/2020 | CoLabs | COVID Ventor | Emergency Ventilator | QOT | The COVID Ventor system is an emergency use ventilator used to provide adult patients with emergency ventilatory support when no alternative FDA-approved ventilators are available.Â The COVID Ventor System consists of the reusable Ventor Console (Console) and the single use, disposable Ventor-Specific Breathing Circuit (Breathing Circuit).Â The COVID Ventor is able to provide Pressure Controlled, Pressure Supported, and Volume Controlled long-term ventilatory support in emergency situations
04/06/2020 | MEKICS Co,. Ltd | MTV1000 ventilator | Ventilator, Continuous | QOS | MTV1000 ventilator is designed for use on patient population sizes from pediatric through adult who require respiratory support or mechanical ventilation and weigh a minimum of 5.0 kg. It is suitable for service in hospitals to provide continuous positive pressure ventilatory support using medical oxygen and compressed medical air from internal air sources to deliver oxygen concentrations of 21% to 100%. Ventilatory support can be delivered invasively or noninvasive.
04/05/2020 | Covidien LLC | Puritan Bennett 560 Ventilator System | Ventilator, Continuous, | QOS | The Puritan Bennett 560 Ventilator is indicated for the continuous or intermittent mechanical ventilatory support of patients weighing at least 11 lb (5 kg) who require mechanical ventilation. The ventilator is a restricted medical device intended for use by qualified, trained personnel under the direction of a doctor. It is essential to read, understand, and follow these instructions before using the Puritan Bennett 560 Ventilator. Specifically, the ventilator is applicable for adult and pediatric patients who require the following general types of invasive or non-invasive ventilatory support, as prescribed by an attending doctor:; - Positive Pressure ventilation; - Assist/Control, SIMV, or CPAP modes of ventilation; - Breath types including Volume Control, Pressure Control, and Pressure Support The ventilator is suitable for use in institutional, home, and portable settings. It is not intended for use in Emergency Medical Service (EMS) such as an emergency transport.
04/03/2020 | Dragerwerk AG & CO. KGaA | Babylog VN800 and VN600 | Critical Care Ventilator | QOV | The intensive care ventilator Babylog is intended for the ventilation of neonates from 0.4 kg (0.88 lb) up to 10 kg (22 lb), and pediatric patients from 5 kg (11 lb) up to 20 kg (44lb) bodyweight. This device provides mandatory ventilation modes and ventilation modes for supporting spontaneous breathing as well as ventilation monitoring.
04/03/2020 | GE Healthcare | pNeuton Model A-E Ventilator | Ventilator, Continuous, Facility Use | QOS | The pNeuton Ventilator is intended for continuous mechanical ventilation of patients in the following patient populations and use locations: Patient population - adult / pediatric patients 23 Kg and greater who require the following general types of ventilatory support:; - positive pressure ventilation delivered invasively (via an ET tube) or non-invasively (via a mask); - CMV and IMV modes of ventilation; - with or without PEEP / CPAP; - with oxygen or a mixture of air and oxygen The ventilator is suitable for use in:; - Hospitals and alternate care units to meet the needs for mechanical ventilation; - Pre-hospital transport applications including accident scene, emergency rescue vehicles; - Hospital ICU transport applications including emergency, radiology, surgery and post anesthesia/recovery; - Air transport via helicopter or fixed wing
04/02/2020 | BMC Medical CO., LTD | Luna G3 BPAP 25A- LG3700 | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | The G3 B25A BPAP System is a Bi-level PAP (Bi-level Positive Airway Pressure) device, which is intended to provide non-invasive ventilation for patients with Obstructive Sleep Apnea (OSA) and Respiratory Insufficiency. These devices are intended for adult patients by prescription in the home or hospital/institutional environment.
04/02/2020 | BMC Medical Co., Ltd. | Y-30T | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | BPAP System (Y-30T Model) is a Bi-level PAP (Bi-level Positive Airway Pressure) device, which is intended to provide non-invasive ventilation for patients with obstructive Sleep Apnea (OSA) and Respiratory Insufficiency. Y-30T device is intended for adult patient by prescription in the home or hospital/institutional environment. This device is not intended for life support. The optional Heated Humidifier used with the Y-30T device together is indicated for taking humidifying and heating air from the device.
04/02/2020 | Dragerwerk AG & CO. KGaA | Evita V800 and Evita V600 | Critical Care Ventilator | QOV | The intensive care Ventilator Evita is intended for the Ventilation of adults, adolescents, children, infants and neonates. This device provides mandatory Ventilation modes and Ventilation modes for supporting spontaneous breathing as well as Ventilation monitoring
04/01/2020 | Philips Respironics | VX850 Ventilator | Critical Care Ventilator | QOV | The VX850 ventilator is intended to provide continuous or intermittent respiratory support and monitoring of pediatric and adult patients. The VX850 is intended to be used in a hospital or other institutional healthcare environment and is intended for intra-facility transport. The VX850 ventilator is intended for use by qualified, trained personnel under direction of a physician. The VX850 is intended for use with pediatric (infants) ages 2 months to 2 years and weighing 5 kg or greater, up to and including adult patients.
03/31/2020 | RESMED | GA ST | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | The GA non-invasive ventilator is an assist ventilator and is intended to augment patient breathing. It is intended solely for spontaneously breathing individuals who require mechanical ventilation: patients with respiratory failure, chronic respiratory insufficiency, or obstructive sleep apnea in a hospital or other institutional settings under the direction of a physician. The ventilator is intended to support patients weighing 20 kg (44 lb) or greater. The ventilator is intended to be used by qualified medical professionals, such as physicians, nurses, and respiratory therapists.
03/31/2020 | RESMED | Flexo Bi-Level ST | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | Flexo Bi-level positive airway pressure therapy device is used to provide non-invasive ventilatory support of mechanical ventilation for: Patients who are independent and spontaneously breathing, Patients with respiratory insufficiency and sleeping breathing disorders. It can provide both a stable continuous positive airway pressure and a bi-level positive airway pressure. It is not a life support ventilator. It is intended to be used in the home or professional medical environment. The therapeutic pressure is prescribed by a physician according to patients' condition.
03/31/2020 | RESMED | AirCurve S T (AmendedApril 17, 2020) | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | AirCurve ST device has indications for use that include respiratory insufficiency. The AirCurve ST device is indicated for the treatment of obstructive sleep apnea (OSA) in patients weighing more than 66 lb (30kg). It is intended for home and hospital use.
03/31/2020 | Amsino | YUWELLÂ®YH-730 Bi-level PAP and YH-830 Bi-level PAP | Ventilator, Non-Continuous | QOQ | The Bi-level device is indicated for treatment of sleep apnea hypopnea syndrome in patients weighing more than 66lb (30kg). It is intended both for home use and hospital use. The water tank is intended for single patient use in the home environment and re-use in a hospital/institutional environment.
03/31/2020 | Inovytec | Ventway Sparrow | Ventilator, Continuous | QOS | The Ventway Sparrow ventilator is intended to provide continuous or intermittent ventilatory support for the care of individuals who require mechanical ventilation. Specifically, the ventilator is applicable for adult and pediatric patients weighing at least 5 kg (11 lb), who require the following types of ventilatory support: SIMV - VC (PS), CPAP. The Ventway Sparrow lung ventilator is intended for emergency use and during transportation. It may be used for invasive or non-invasive ventilation presets. The ventilator is a restricted medical device intended for use by qualified, trained personnel under the direction of a physician.
03/30/2020 | RESMED | Stellar 150 (Amended September 1, 2020) | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | The Stellar 150 is intended to provide ventilation for non-dependent, spontaneously breathing adult and pediatric patients (30 lb/13 kg and above) with respiratory insufficiency, or respiratory failure, with or without obstructive sleep apnea. The device is for noninvasive use, or invasive use (with the use of the ResMed Leak Valve). The iVAPS mode with optional AutoEPAP is intended for patients weighing more than 66lb (30kg).Operation of the device includes both stationary, such as in hospital or home, or mobile, such as wheelchair usage.
03/30/2020 | RESMED | Lumis 150 VPAP ST (Amended April 17, 2020) | Ventilator, Continuous, Minimal Ventilatory Support, Facility Use | QOR | The ResMed Lumis 150 VPAP ST devices are indicated to provide non-invasive ventilation for patients weighing more than 30 lbs (13 kg), or more than 66 lbs (30kg) in iVAPS mode, with respiratory insufficiency or obstructive sleep apnea (OSA). They are intended for home and hospital use. The ResMed Lumis 150 VPAP ST devices can be used with an attachable humidifier that is intended for single patient use in the home environment and re-use in a hospital/institutional environment.
03/28/2020 | Shenzen Mindray Bio-medical Electronics | Mindray SV300/SV600/SV800 ventilators | Critical Care Ventilator | QOV | This product is intended to provide ventilation assistance and breathing support for adult,pediatric and infant patients
03/28/2020 | Vyaire Medical, Inc. | LTV2 model 2200 and LTV model 2150 | Critical Care Ventilator | QOV | LTV2 model 2200 and 2150 ventilators are intended to provide continuous or intermittent ventilatory support for the care of the individuals who require mechanical ventilation. The use environment is for institutional use. Institutional use includes ICU or other hospital environments including intra-hospital transport.Â The Model 2200 can operate with high O2.Â The Model 2150 operates with low pressure.
03/25/2020 | Beijing Aeonmed Co., Ltd | VG70 ventilator | Critical Care Ventilator | QOV | Mechanical ventilation of patients in ICU

#### Ventilators Removed from Appendix B

Date No Longer Authorized | Manufacturer | Ventilator Model(s) No longer Authorized | Device Description | Assigned Product Code
06/21/2023 | GE Healthcare | pNeuton Model A-E Ventilator | Ventilator, Continuous, Facility Use | QOS
04/03/2024 | Dragerwerk AG & CO. KGaA | Evita V800 and Evita V600 | Critical Care Ventilator | QOV
04/03/2024 | Dragerwerk AG & CO. KGaA | Babylog VN800 and VN600 | Critical Care Ventilator | QOV

#### Authorized Ventilator Tubing Connectors

Date of Authorization | Manufacturer | Product Name | Device Description | Assigned Product Code | Intended Use
05/29/2020 | Bloom Energy | Ventilator Sharing and Monitoring | Patient Circuit Connector | QOX | The Ventilator Sharing and Monitoring System allows a single critical care ventilator to be used for up to four adult patients for ventilator support during the COVID-19 pandemic when individual ventilators are not available.
04/29/2020 | Northwell Health, Inc. | Northwell 3D Printed BiPAP Adapter | Ventilator Tubing Connector | QOO | The Northwell Health 3D Printed BiPAP Adapter ("Adapter") is intended for use as an exhalation port that enables invasive use of a bilevel positive airway pressure (BiPAP) machine with a pressure control ventilation (PCV) option as a pressure-controlled ventilator.
04/29/2020 | Formlabs Inc. | Formlabs 3D Printed BiPAP Adapter | Ventilator Tubing Connector | QOO | The Formlabs 3D Printed BiPAP Adapter ("Adapter") is intended for use as an exhalation port that enables invasive use of a BiPAP with a pressure control ventilation (PCV) option as a pressure-controlled ventilator.
04/19/2020 | MakeMedical | VentMI | Dual Patient Circuit Connector | QOX | A single ventilator fitted with the VentMI Ventilator Splitter can be used for two adult patients with the same pathology for ventilatory support for up to fourteen (14) days during the COVID-19 pandemic when individual ventilators are not available.

### Ventilator Accessories Removed from Appendix B

Date removed from Appendix B | Manufacturer | Ventilator Tubing Connector Model(s) No Longer Authorized
03/27/2022 | Great Group Medical Co., LTD | GGM Breathing Circuit Bacterial Filter; Models: VH-3110 (Model: Adult with luer port), VH-3210 (Model: Adult/Child with luer port), VH-3211 (Model: Adult/Child without luer port), VH-3310 (Model: Pediatric with luer port); and Bacterial / Virial Respirator Filters: VF-2150 (Model: Adult), VF-2151 (Model: Adult/Child), VF-2152 (Model: Adult/Child), VF-2153 (Adult/Child without port), VF-2160 (Model: Adult without port), VF-2160-1 (Adult with port)
02/09/2021 | Vent Multiplexor LLC | Vent Multiplexor
02/09/2021 | Covidien LLC | DAR Adult Dual Patient Breathing Circuit 301P14429
02/09/2021 | Safe Flight Instrument Corporation | Safe Flight 9100-1 Quad Vent
02/09/2021 | Safe Flight Instrument Corporation | Safe Flight 9100-3 Quad Vent
02/09/2021 | Stryker Instruments | Flow Control Valve
02/09/2021 | Valhalla Medical Supply, LLC | Single-Use Emergency Ventilator 2-Way Manifold
02/09/2021 | The New Bureau | The Single Path Airway Rapid Retrofit Optional Workflow ("Sparrow") COVID-19 Co-Ventilator Assist Device
02/09/2021 | Dr. Bryan Lai | VentSplitter Emergency Ventilator Circuit Splitter and Flow Limiters
08/28/2020 | Prisma Health | Ventilation Expansion Splitter (VESper)
10/14/2024 | Invent Medical Corporation | High Flow Humidifier (HFT-150)

### Authorized Ventilator Accessories

Date of Authorization | Manufacturer | Product Name | Device Description | Assigned Product Code | Intended Use
04/20/2022 | DIMAR S.r.l. a Socio Unico | Dimar CPAP Helmet | Ventilator, non-continuous, Mask | QOO | The Dimar CPAP Helmet is a single use patient interface indicated for the treatment of patients requiring Continuous Positive Airway Pressure respiratory support therapy. It can be employed on conscious adult patients in upright and lying position. The Dimar CPAP Helmet is intended for prescription use only in a hospital setting.
04/28/2021 | PEEP-Alert Technologies, Inc. | PEEP-Alert Pressure and Flow Monitor | Positive End Expiratory Pressure Breathing Attachment | QOO | The PEEP-Alert Pressure and Flow Monitor is a non-patient contacting medical device that measures and displays delivered positive end-expiratory pressure (PEEP) and gas flow. PEEP-Alert is designed for use with a ventilatory assistance helmet (VAH) as used in the intensive care unit, clinic, and emergency settings for adult and pediatric patients. PEEP-Alert has audible and visual indicators if delivered PEEP and gas flow do not reflect the clinician’s setting. Alarm settings for the minimum and maximum delivered PEEP and fresh gas flowrate should be set by the clinician based upon their assessment of the patient’s respiratory requirements.
03/19/2021 | Vyaire Medical, Inc. | AirLife DuoTherm Humidification System | Respiratory Humidifier | QOP | The AirLife DuoTherm Humidification System delivers heated, humidified respiratory gases to patients receiving invasive or non-invasive therapy. It is intended for adult patients only within the scope of this EUA submission. The device is intended to be used in professional healthcare environments under the supervision of a licensed healthcare practitioner.
03/15/2021 | Great Group Medical Co., Ltd. | Disposable Heater Wire Breathing Circuit | Respiratory Humidifier | QOP | The heated wire breathing system is intended to deliver the gas that is humidified and heated by the humidifier chamber. The humidified and heated gas from the humidifier chamber to deliver to the patient airway is through the heater wire to maintain or heat up the temperature. It is compatible with GGM Respiratory Humidifier (EUA200690) through the connection of GGM heater wire adapter.; For those patients who need mechanical ventilation, positive airway pressure assistance, or general medical gases.
02/12/2021 | Vapotherm Inc | HVT2.0 | Respiratory Humidifier | QOP | The HVT 2.0 system is intended to deliver warmed and humidified high-flow respiratory gases to spontaneously breathing adult patients and pediatric patients (5 kg and up). The device is intended to be used in hospital, sub-acute facility and home-use settings. The HVT 2.0 is not cleared or approved in the US and has been granted an Emergency Use Authorization by the FDA for use during the COVID-19 pandemic. HVT 2.0 delivers high-flow respiratory gases to patients when no cleared or approved standard high-flow ventilation devices are available.
02/02/2021 | Pall Medical | Breathing Circuit Filter | Breathing Circuit Filters | QPH | The Pall Breathing Circuit Filter model BB22-15A is a single use bi-directional bacterial/viral removal filter and heat and moisture exchanger that is indicated for providing machine side filtration on ventilators with a gas outlet fitting that complies with ISO 5356-1 and where filtration of inspired and/or expired gases is desired to protect the patient, staff and/or interior of the breathing system from patient-derived contamination during assisted ventilation. Intended for single use of up to 24 hours, in conjunction with a hospital protocol that ensures hygienic and mechanical integrity of the system. Provides greater than 99.999% bacterial and viral efficiency.
01/06/2021 | Vyaire Medical, Inc. | Sterile Water for Humidifier | Respiratory Humidifier | QOP | The Sterile Water for Humidifier is intended to provide a supply of sterile water to unfilled respiratory humidifier chambers for inhalation purposes.; It is intended to be used in institutional and non-institutional care settings. It is substitute to the sterile water intended to be used for inhalation with a mechanical ventilator, when these devices are not available.
11/23/2020 | Azimuth Sleep Solutions | PortPatch | Ventilator, non-continuous, Mask | QOW | PortPatch is intended to reduce the spread of airborne particulates through the exhalation ports, anti-asphyxia valves and carbon dioxide vents on full-face or non-rebreathing CPAP and other ventilation masks.
10/16/2020 | Invent Medical Corporation | High Flow Humidifier (HFT-150) | Respiratory Humidifier | QOP | HFT 150 system is for spontaneously breathing adult patients who would benefit from receiving high flow warmed and humidified respiratory gases. The flow may be from 2 - 60 L/min depending on the patient interface. The HFT 150 is used in hospital and long-term care facilities.
08/14/2020 | Intersurgical, Inc | Intersurgical StarMed CaStar R Hood for NIV | Ventilator, non-continuous, Mask | QOW | Helmet for non-invasive ventilation and CPAP in hospital environment. The treatment may only be performed under careful monitoring by expert operators. Suitable for treatment of respiratory insufficiency in hypoxemic / hypercapnic adult patients.
08/12/2020 | Covidien, LLC | Puritan Bennet Reusable Pediatric-Adult Expiratory Filter | Breathing Circuit Filters | QPH | The Puritan Bennett Reusable Pediatric-Adult Expiratory Filter is designed for the Puritan Bennett 980 Series Ventilator (hereafter "PB980 Ventilator") to prevent bacteria in the patient's exhaled gas from venting to room air.
08/07/2020 | Prudent American Technologies, Inc | Fixed Resistance Connector Valve | Ventilator Tubing Connector | QOO | The Fixed Connector Resistance Valve as a part of the Adaptable BiPAP Circuit (ABC) is intended for use on adult patients suffering from acute respiratory distress or insufficiency. The ABC can be substituted for FDA-cleared BiPAP breathing circuits with an exhalation port in cases where these FDA-cleared circuits are unavailable due to shortages during the COVID-19 pandemic. For use in bilevel ventilation, continuous positive airway pressure (CPAP), or invasive mechanical ventilation in pressure control modes with PEEP above 5 cmH2O. The ABC facilitates invasive mechanical ventilation and non-invasive ventilation with the support of a bilevel positive airway pressure (BiPAP) machine. When treating COVID patients, any bilevel breathing circuit should be used with a non-vented anti-asphyxiation valve mask with an appropriate viral filter on the exhalation port.
08/04/2020 | Lombardi Undersea LLC | Subsalve Oxygen Treatment Hood | Ventilator, non-continuous, Mask | QOW | The Subsalve Oxygen Treatment Hood is a patient interface intended for helmet based Non Invasive Positive Pressure Ventilation (NIPPV) according to clinician established protocols to treat Acute Respiratory Distress Symptoms (ARDS) resulting from COVID-19. The device is for adults only and intended for use in Intensive Care Unit (ICU) settings.
07/17/2020 | Great Group Medical (GGM) | GGM Respiratory Humidifier, Models VH-2100, VH2600A, and VH-2600 | Respiratory Humidifier | QOP | The GGM Respiratory Humidifier is intended to warm and add humidity to gases delivered to patients requiring mechanical ventilation or positive pressure breathing assistance via an endotracheal tube or face mask. For use by trained personnel only within a hospital/institutional environment. This device is intended to be used only with the GGM Respiratory Humidifier Heated Wire Breathing System and GGM Respiratory Humidification Chamber.
07/08/2020 | Circadiance | SleepWeaver Prevent Mask | Ventilator, non-continuous, Mask | QOW | The SleepWeaver Prevent Nasal Mask is intended to provide an interface for Continuous Positive Airway Pressure (CPAP) or Bi-Level therapy. This mask is intended for single-patient reuse in the home and single-patient reuse in the hospital / institutional environment. This mask is to be used on patients greater than 66 lbs (30 kg). The filter mask present in SleepWeaver Prevent is intended to filter exhaled air to reduce the likelihood that the exhaled air may contaminate the room air around the person using the mask.
06/23/2020 | Vincent Medical (Dong Guan) Manufacturing. Co., LTD. | Heat and Moisture Exchanging Filters (HMEF): HMEF 1000 Straight (Model 504-011, part number 51008027), HMEF 1000 Angled (Model 504-011, part number 51008028), HMEF Midi Straight (Model 504-011, part number 51008029), HMEF Midi Angled (Model 504-011, part number 51008030); and Bacterial / Viral Respirator Filters: BSF103 low resistance (Model 510-014, part number 51008082) and BSF201 High performance (Model 504-011, part number 51008083) | Breathing Circuit Filters | QPH | HME / Filter - For use with ventilators, anesthesia machines and open flow systems where filtration of inspired and/or expired gases is desired and to maintain moisture levels in the patient's respiratory tract during anesthesia, artificial respiration, and other types of assisted ventilation. Use up to 24 hours. For adults with Tidal Volumes > 300 ml.; Filter only - For use with ventilators, anesthesia machines and open flow systems where filtration of inspired and/or expired gases is desired. Use up to 24 hours. For adults with tidal volume > 300 ml.
05/20/2020 | Vincent Medical Manufacturing Co., Ltd | O2FLO High Flow Respiratory Humidifier (VUN-001) | Respiratory Humidifier | QOP | The O2FLO High Flow Heated Respiratory Humidifier (VUN-001) is intended to deliver warmed and humidified respiratory gases to spontaneously breathing patients with a flow rate from 2LPM to 60LPM and is capable of providing high flow therapy. The device can be used in the emergency room, outpatient department, inpatient department and other diagnostic and treatment rooms.
04/28/2020 | Janisys | Janisys CPAP Flow Generator | Positive End Expiratory Pressure Breathing Attachment | QOO | The Janisys CPAP Flow Generator, when used in conjunction with a PEEP valve, is used to provide CPAP to a spontaneously breathing adult in hospital settings. The DD-3 variable-flow model is intended to provide 28%-100% FIO2 and the DD-4 fixed-flow model is intended to provide 28%-33% FIO2.
04/14/2020 | 3B Medical, Inc. | 3B Hi-Flow H80 | Respiratory Humidifier | QOP | H-80 series humidifier is for the treatment of spontaneously breathing patients who would benefit from receiving high flow warmed and humidified respiratory gases. This device is for patients by prescription in the home or hospital/institutional environment. The device is only allowed to be used after the physician provides guidance for the patient and targeted setting of the device; the physician should ensure that the patient understands all functions and methods of operation of the device.
04/13/2020 | SMD Manufacturing, LLC | ReddyPort Mini NIV Access Elbow | Elbow Connector for Mask | QOO | The ReddyPort Mini NIV Access Elbow is intended to provide an interface for application of CPAP or bi-level therapy. The elbow is for single patient use in the hospital/institutional environment. The elbow is to be used on patients 7 years or older (>40lbs/18.2kg) for whom CPAP or bi-level therapy has been prescribed

## Other Medical Device EUAs

November 8, 2023 - The COVID-19 public health emergency (PHE) declared under section 319 of the Public Health Service (PHS) Act expired (https://www.hhs.gov/about/news/2023/02/09/fact-sheet-covid-19-public-health-emergency-transition-roadmap.html) on May 11, 2023. The COVID-19 enforcement policy guidances within scope of the Transition Plan for Medical Devices That Fall Within Enforcement Policies Issued During the Coronavirus Disease 2019 (COVID-19) Public Health Emergency (https://www.fda.gov/regulatory-information/search-fda-guidance-documents/transition-plan-medical-devices-fall-within-enforcement-policies-issued-during-coronavirus-disease) (see List 1) are no longer in effect.

This page lists EUAs not described in any of the other pages in the Coronavirus Disease 2019 (COVID-19) Emergency Use Authorizations for Medical Devices Section.

Templates for these EUA submissions are available to help facilitate the preparation, submission, and authorization of an EUA.

Date EUA Issued | Device Type | Letter of Authorization | Fact Sheets | Other Documents | Assigned Product Code
03/15/2023 | LVEF Screen | Anumana Inc, ELEFT | Healthcare Providers; Patients | IFU | QLL
03/19/2021 | Symptom Screening Tool | Tiger Tech Solutions, Inc., Tiger Tech COVID Plus Monitor | Users; Recipients | IFU | QOA
11/21/2020 | Extracorporeal Membrane Oxygenation | Terumo Cardiovascular CAPIOX Emergency Bypass System | Healthcare Providers; Patients | IFU | QOD
09/24/2020 | Predictive Screening | COVIage | Healthcare Providers; Patients | IFU | QLM
08/03/2020 | Left Ventricular Support System | Abiomed, Inc., Impella LV Systems | Healthcare Providers; Patients | IFU - Impella Ventricular Support System 2.5, CP, 5.0, and LD; IFU - Impella Ventricular Support System 5.5; IFU - Impella Ventricular Support System CP | QOC
05/29/2020 | Right Ventricular Assist Catheter | Abiomed, Inc., Impella RP System | Healthcare Providers; Patients | IFU | QOC
05/26/2020 | Predictive Screening | CLEW Medical Ltd. | Healthcare Providers; Patients | IFU; Letter Granting EUA Amendment(s) (June 30, 2020) | QLM
04/18/2020 | Face Mask (non-Surgical) | Face Mask (non-Surgical) | | Face Mask EUA FAQ (https://www.fda.gov/medical-devices/emergency-situations-medical-devices/faqs-emergency-use-authorization-face-masks-non-surgical) | QKR