# Drug and Biological Therapeutic Products

The Emergency Use Authorization (EUA) authority allows FDA to help strengthen the nation’s public health protections against chemical, biological, radiological, and nuclear (CBRN) threats including infectious diseases, by facilitating the availability and use of medical countermeasures (https://www.fda.gov/emergency-preparedness-and-response/about-mcmi/what-are-medical-countermeasures) (MCMs) needed during public health emergencies. Learn more about Emergency Use Authorization (https://www.fda.gov/emergency-preparedness-and-response/mcm-legal-regulatory-and-policy-framework/emergency-use-authorization).

FDA expects the COVID-19 public health emergency (PHE) declared by the Department of Health and Human Services under the Public Health Service Act to expire on May 11, 2023. The ending of the COVID-19 PHE will not impact CDER's ability to authorize treatments for emergency use. Existing EUAs for products will remain in effect, and the agency may continue to issue new EUAs if the situation meets the criteria to do so. Read more about what happens to EUAs when a public health emergency ends (https://www.fda.gov/emergency-preparedness-and-response/mcm-legal-regulatory-and-policy-framework/faqs-what-happens-euas-when-public-health-emergency-ends).

## EUAs for CDER-regulated Products

Date of First EUA Issuance | Most Recent Letter of Authorization (PDF) | Authorized Use ^1^ | Fact Sheets and Manufacturer Instructions/ Package Insert (PDF) | Federal Register Notice for EUA
3/22/2024 | Pemgarda (220 KB) (reissued April 3, 2024 and August 26, 2024) Letter Granting EUA Amendment (May 17, 2024) (219 KB) Letter Granting EUA Amendment (September 26, 2024) (275 KB) | For emergency use for the pre-exposure prophylaxis of coronavirus disease 2019 (COVID-19) in adults and adolescents (12 years of age and older weighing at least 40 kg): who are not currently infected with SARS-CoV-2 and who have not had a known recent exposure to an individual infected with SARS-CoV-2 and who have moderate-to-severe immune compromise due to a medical condition or receipt of immunosuppressive medications or treatments and are unlikely to mount an adequate immune response to COVID-19 vaccination. | Healthcare Providers (466 KB) (Updated September 26, 2024) Patients and Caregivers (192 KB) (Updated August 26, 2024) Frequently Asked Questions on the Emergency Use Authorization of Pemgarda (225 KB) (Updated September 26, 2024) CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | Federal Register Notice for EUA FRN EUA May 28, 2024 (https://www.federalregister.gov/d/2024-11640)
4/4/2023 | Gohibic (757KB) (reissued April 12, 2023) | Gohibic is authorized for the treatment of COVID-19 in hospitalized adults when initiated within 48 hours of receiving invasive mechanical ventilation (IMV) or extracorporeal membrane oxygenation (ECMO). | Healthcare Providers (2310KB); Patients and Caregivers (950KB); Frequently Asked Questions on the Emergency Use Authorization of Gohibic (141 KB); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | FRN EUA
11/08/2022 | Kineret (256KB) | Kineret (anakinra) is authorized for the treatment of COVID-19 in hospitalized adults with pneumonia requiring supplemental oxygen (low- or high-flow oxygen) who are at risk of progressing to severe respiratory failure and likely to have an elevated plasma soluble urokinase plasminogen activator receptor (suPAR). | Healthcare Providers (6560KB); Patients and Caregivers (4130KB); Frequently Asked Questions on the Emergency Use Authorization of Kineret (1750KB); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | FRN EUA March 13, 2023 (https://www.federalregister.gov/public-inspection/2023-05073/emergency-use-authorization-drug-product-during-the-covid-19-pandemic-availability)
02/11/2022 | Bebtelovimab (https://www.fda.gov/drugs/drug-safety-and-availability/fda-announces-bebtelovimab-not-currently-authorized-any-us-region) (460KB) (reissued August 5 and October 27, 2022); Letter Granting EUA Amendment (March 30, 2022) (216KB); Letter Granting EUA Amendment (September 16, 2022) (194KB); Letter Granting EUA Amendment (November 4, 2022) (310KB); FDA Announces Bebtelovimab is Not Currently Authorized in Any US Region (https://www.fda.gov/drugs/drug-safety-and-availability/fda-updates-bebtelovimab) (November 30, 2022); ASPR and FDA Statement on Shelf-Life Extension of Bebtelovimab (https://aspr.hhs.gov/COVID-19/Therapeutics/updates/Pages/important-update-28Oct2022.aspx) (October 28, 2022) | Bebtelovimab is not currently authorized in any U.S. region due to the high frequency of circulating SARS-CoV-2 variants that are non-susceptible to bebtelovimab. Therefore, bebtelovimab may not be administered for treatment of COVID-19 under the Emergency Use Authorization until further notice by the Agency.; Bebtelovimab is authorized for the treatment of mild-to-moderate COVID-19 in adults and pediatric patients (12 years of age and older weighing at least 40 kg) with positive results of direct SARS-CoV-2 viral testing who are at high risk for progressing to severe COVID-19, including hospitalization or death, and for whom alternative COVID-19 treatment options approved or authorized by FDA are not accessible or clinically appropriate. | Healthcare Providers (763 KB) (updated November 4, 2022); Patients, Parents, and Caregivers (245KB)(updated November 4, 2022); • Spanish (141 KB); Frequently Asked Questions on the Emergency Use Authorization of Bebtelovimab (1 MB); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | FRN EUA March 22, 2022 (https://www.federalregister.gov/documents/2022/03/22/2022-06009/authorization-of-emergency-use-of-a-biological-product-during-the-covid-19-pandemic-availability)
12/23/2021 | Lagevrio (molnupiravir) (263 KB) (reissued November 15, 2023, August 5, October 27, 2022, February 1, 2023, and October 3, 2023); ASPR and FDA Statement on Shelf-Life Extension Evaluation of Lagevrio (https://aspr.hhs.gov/COVID-19/Therapeutics/updates/Pages/important-update-21October2022.aspx) (October 21, 2022) | Lagevrio is authorized for the treatment of mild-to-moderate coronavirus disease 2019 (COVID-19) in certain adults who are at high risk for progressing to severe COVID-19, including hospitalization or death, and for whom alternative COVID-19 treatment options approved or authorized by FDA are not accessible or clinically appropriate. | Healthcare Providers (590 KB) (updated February 1, 2023, July 17, 2023, October 3, 2023 and June 18, 2024); Spanish (573 KB); Patients, Parents, and Caregivers (136 KB) (updated February 1, 2023, October 3, 2023 and June 18, 2024); Spanish (209 KB); COVID-19 Test to Treat locator (https://aspr.hhs.gov/testtotreat/Pages/default.aspx) (Find a treatment location near you, from ASPR); Dear Healthcare Provider Letter (162 KB) (February 1, 2023); Dear Healthcare Provider Letter (268 KB); Frequently Asked Questions on the Emergency Use Authorization of Lagevrio (308 KB) (updated February 7, 2023); Prescriber Checklist for Lagevrio (181 KB) (updated February 1, 2023); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | FRN EUA February 4, 2022 (https://www.federalregister.gov/documents/2022/02/04/2022-02359/authorizations-of-emergency-use-of-certain-drugs-and-biological-products-during-the-covid-19)
12/22/2021 | Paxlovid (nirmatrelvir tablets and ritonavir tablets, co-packaged for oral use) (215 KB) (reissued March 17, 2022, April 14, 2022, July 6, 2022, August 5, 2022, October 27, 2022, February 1, 2023, May 25, 2023, November 1, 2023, January 29, 2024, and March 13, 2024); Letter Granting EUA Amendment (March 18, 2022) (161 KB); Letter Granting EUA Amendment (September 26, 2022) (255 KB); FDA Authorizes Pharmacists to Prescribe Paxlovid with Certain Limitations (https://www.fda.gov/news-events/press-announcements/coronavirus-covid-19-update-fda-authorizes-pharmacists-prescribe-paxlovid-certain-limitations) (July 6, 2022); ASPR and FDA Statement on Shelf-Life Extension of Paxlovid (https://aspr.hhs.gov/COVID-19/Therapeutics/updates/Pages/important-update-18January2023.aspx) (January 18, 2023) | Paxlovid is authorized for the treatment of mild-to-moderate COVID-19 in certain adults and pediatric patients (12 years of age and older weighing at least 40 kg) who are at high risk for progression to severe COVID-19, including hospitalization or death.; On May 25, 2023, Paxlovid was approved for the treatment of mild-to-moderate COVID-19 in adults who are at high risk for progression to severe COVID-19, including hospitalization or death.; As of March 9, 2024, the presentation of Paxlovid in EUA packaging may not be dispensed. | Healthcare Providers (711 KB) (updated September 12, 2024); Paxlovid Patient Eligibility Screening Checklist and Drug Interaction Tool (310 KB) (updated September 12, 2024); Patients, Parents, and Caregivers (693 KB) (updated March 13, 2024); COVID-19 Test to Treat locator (https://aspr.hhs.gov/testtotreat/Pages/default.aspx) (Find a treatment location near you, from ASPR); Dear Healthcare Provider Letter (343 KB) (updated March 13, 2024); Dosing Card for Healthcare Provider (https://paxlovid.pfizerpro.com/files/PAXLOVIDnirmatrelvirritonavir_BoxedWarning_SafetyInfo_PrescribingInfo_PP-C1D-USA-0485.pdf) (1 MB) (updated March 13, 2024); Dosing Card for Patients, Parents, and Caregivers (https://paxlovid.pfizerpro.com/files/PAXLOVIDnirmatrelvirritonavir_BoxedWarning_SafetyInfo_PrescribingInfo_PP-C1D-USA-0473.pdf)(2.6 MB) (updated March 13, 2024); Important Dispensing Information for Patients with Moderate Renal Impairment (476 KB); Frequently Asked Questions on the Emergency Use Authorization for Paxlovid (227 KB) (updated March 13, 2024); CDER Conversation on Paxlovid for Health Care Providers (https://www.fda.gov/drugs/news-events-human-drugs/fda-updates-paxlovid-health-care-providers); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | FRN EUA February 4, 2022 (https://www.federalregister.gov/documents/2022/02/04/2022-02359/authorizations-of-emergency-use-of-certain-drugs-and-biological-products-during-the-covid-19)
12/08/2021 | Evusheld (tixagevimab co-packaged with cilgavimab) (286KB) (reissued December 20, 2021, February 24, 2022, May 17, 2022, October 27, December 8, 2022, and January 26, 2023); FDA announces Evusheld is not currently authorized for emergency use in the U.S. (https://www.fda.gov/drugs/drug-safety-and-availability/fda-announces-evusheld-not-currently-authorized-emergency-use-us) (updated January 26, 2023); ASPR and FDA Statement on Shelf-Life Extension of Evusheld (https://aspr.hhs.gov/COVID-19/Therapeutics/updates/Pages/important-update-05December2022.aspx) (December 5, 2022); Letter Granting EUA Amendment (June 29, 2022) (168KB); Letter Granting EUA Amendment (November 18, 2022) (197KB); Letter Granting EUA Amendment (December 21, 2022) (188KB) | Evusheld is not currently authorized in any U.S. region due to the high frequency of circulating SARS-CoV-2 variants that are non-susceptible to Evusheld. Therefore, Evusheld may not be administered for pre-exposure prophylaxis for prevention of COVID-19 under the Emergency Use Authorization until further notice by the Agency.; For emergency use as pre-exposure prophylaxis for prevention of COVID-19 in adults and pediatric individuals (12 years of age and older weighing at least 40 kg):; Who are not currently infected with SARS-CoV-2 and who have not had a known recent exposure to an individual infected with SARS-CoV-2 and; • Who have moderate to severe immune compromise due to a medical condition or receipt of immunosuppressive medications or treatments and may not mount an adequate immune response to COVID-19 vaccination or; • For whom vaccination with any available COVID-19 vaccine, according to the approved or authorized schedule, is not recommended due to a history of severe adverse reaction to a COVID-19 vaccine(s) and/or COVID-19 vaccine component(s). | Healthcare Providers (769 KB) (updated January 26, 2023); • Spanish (1 MB) (updated December 21, 2022); Patients, Parents, and Caregivers (178KB) (updated January 26, 2023); • Spanish (342KB) (updated October 3, 2022); Dear Healthcare Provider Letter (135 KB) (January 26, 2023); Dear Healthcare Provider Letter (439 KB) (June 29, 2022)New Repeat Dosage Recommendations; • Spanish (207 KB) (June 29, 2022); Dear Healthcare Provider Letter (196 KB) (October 3, 2022) Updated EVUSHELD EUA Warnings and Precautions; • Spanish (278KB) (October 3, 2022); Dear Healthcare Provider Letter (226 KB) (May 17, 2022)Addition of EVUSHELD EUA Warning and Precaution for Risk of Cross-Hypersensitivity with COVID-19 Vaccines; Dear Healthcare Provider Letter (144 KB) (March 22, 2022) Updated EVUSHELD EUA Dosage Recommendations for Patients Who Received an Initial Dose of 150 mg tixagevimab and 150 mg cilgavimab; • Spanish (227KB) (April 1, 2022); Frequently Asked Questions on the Emergency Use Authorization for Evusheld (942 KB) (updated October 20, 2022); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | FRN EUA February 4, 2022 (https://www.federalregister.gov/documents/2022/02/04/2022-02359/authorizations-of-emergency-use-of-certain-drugs-and-biological-products-during-the-covid-19)
06/24/2021 | Actemra (Tocilizumab) (249KB) (reissued December 21, 2022) | For the treatment of COVID-19 in hospitalized pediatric patients (2 years of age and older) who are receiving systemic corticosteroids and require supplemental oxygen, non-invasive or invasive mechanical ventilation, or extracorporeal membrane oxygenation (ECMO).; On December 21, 2022, Actemra was approved for the treatment of COVID-19 in hospitalized adults who are receiving systemic corticosteroids and require supplemental oxygen, non-invasive or invasive mechanical ventilation, or ECMO. | Healthcare Providers (428 KB) (updated December 21, 2022); Patients, Parents, and Caregivers (136 KB) (updated December 21, 2022); Frequently Asked Questions on the Emergency Use Authorization of Actemra (Tocilizumab) (173 KB) (updated December 21, 2022); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | FRN EUA August 5, 2021 (https://www.federalregister.gov/documents/2021/08/05/2021-16705/authorizations-of-emergency-use-of-certain-biological-products-during-the-covid-19-pandemic)
05/26/2021 | Sotrovimab (375KB) (reissued October 8, 2021, December 16, 2021 and February 23, 2022); Letter Granting EUA Amendment (December 22, 2021) (161KB); FDA updates Sotrovimab emergency use authorization (https://www.fda.gov/drugs/drug-safety-and-availability/fda-updates-sotrovimab-emergency-use-authorization) (April 5, 2022); ASPR and FDA Statement of additional Shelf-Life Extension of Strovimab (https://aspr.hhs.gov/COVID-19/Therapeutics/updates/Pages/important-update-15February2023.aspx) (February 15, 2023); ASPR and FDA Statement on Shelf-Life Extension of Sotrovimab (https://aspr.hhs.gov/COVID-19/Therapeutics/updates/Pages/important-update-03August2022.aspx) (August 3, 2022); Important updates about sotrovimab (https://www.phe.gov/emergency/events/COVID19/investigation-MCM/Sotrovimab/Pages/default.aspx) (ASPR) | Sotrovimab is not currently authorized in any U.S. region due to the high frequency of circulating SARS-CoV-2 variants that are non-susceptible to sotrovimab. Therefore, sotrovimab may not be administered for treatment of COVID-19 under the Emergency Use Authorization until further notice by the Agency.; For the treatment of mild-to-moderate COVID-19 in adults and pediatric patients (12 years of age and older weighing at least 40 kg) with positive results of direct SARS-CoV-2 viral testing, and who are at high risk for progression to severe COVID-19, including hospitalization or death. | Healthcare Providers (579 KB) (updated March 17, 2023); • Spanish (426KB) (updated April 28, 2023); Patients, Parents, and Caregivers (199 KB) (updated March 17, 2023); • Spanish (178KB) (updated April 28, 2023); Frequently Asked Questions on the Emergency Use Authorization of Sotrovimab (257 KB) (updated March 25, 2022); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | FRN EUA August 5, 2021 (https://www.federalregister.gov/documents/2021/08/05/2021-16705/authorizations-of-emergency-use-of-certain-biological-products-during-the-covid-19-pandemic)
02/09/2021 | Bamlanivimab and Etesevimab (900KB) (Reissued February 25, 2021, August 27, 2021, September 16, 2021, December 3, 2021, December 22, 2021 and January 24, 2022); ASPR and FDA Statement on Shelf-Life Extension of Bamlanivimab and Etesevimab (https://aspr.hhs.gov/COVID-19/Therapeutics/updates/Pages/important-update-04May2022.aspx) (May 4, 2022); Important updates about bamlanivimab/etesevimab (https://aspr.hhs.gov/COVID-19/Therapeutics/Products/Bamlanivimab-etesevimab/Pages/default.aspx) (ASPR) | Bamlanivimab and etesevimab are not currently authorized in any U.S. region due to the high frequency of circulating SARS-CoV-2 variants that are non-susceptible to bamlanivimab and etesevimab. Therefore, these drugs may not be administered for treatment or post-exposure prevention of COVID-19 under the Emergency Use Authorization until further notice by the Agency.; Bamlanivimab and etesevimab administered together for the treatment of mild-to-moderate COVID-19 in adults and pediatric patients with positive results of direct SARS-CoV-2 viral testing, and who are at high risk for progression to severe COVID-19, including hospitalization or death. | Healthcare Providers (2 MB) (updated January 24, 2022); Patients, Parents, and Caregivers (157KB) (updated December 3, 2021); • Spanish (158 KB) (updated September 16, 2021); Frequently Asked Questions on the Emergency Use Authorization for Bamlanivimab and Etesevimab (312 KB) (updated January 31, 2022); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | FRN EUA February 19, 2021 (https://www.federalregister.gov/documents/2021/02/19/2021-03429/authorizations-of-emergency-use-of-certain-drug-and-biological-products-during-the-covid-19-pandemic)
11/21/2020 | REGEN-COV (Casirivimab and Imdevimab) (1.03MB) (Reissued February 3, 2021, February 25, 2021, June 3, 2021, July 30, 2021, September 9, 2021, November 17, 2021 and January 24, 2022); ASPR and FDA Statement on Shelf-Life Extension of REGEN-COV (https://aspr.hhs.gov/COVID-19/Therapeutics/updates/Pages/important-update-27June2022.aspx) (June 27, 2022) | REGEN-COV (casirivimab and imdevimab) is not currently authorized in any U.S. region due to the high frequency of circulating SARS-CoV-2 variants that are non-susceptible to REGEN-COV. Therefore, REGEN-COV may not be administered for treatment of COVID-19 under the Emergency Use Authorization until further notice by the Agency.; Casirivimab and imdevimab to be administered together for the treatment of mild to moderate COVID-19 in adults and pediatric patients (12 years of age and older weighing at least 40 kg) with positive results of direct SARS-CoV-2 viral testing, and who are at high risk for progression to severe COVID-19, including hospitalization or death. | Healthcare Providers (2 MB) (updated January 24, 2022); • Spanish (1 MB); Patients, Parents, and Caregivers (147KB) (updated July 30, 2021); • Spanish (247 KB); Dear Healthcare Provider Letter (435KB) (updated September 16, 2021); Statement on Post-Exposure Prophylaxis (https://www.fda.gov/drugs/drug-safety-and-availability/fda-authorizes-regen-cov-monoclonal-antibody-therapy-post-exposure-prophylaxis-prevention-covid-19) (July 30, 2021); Frequently Asked Questions on the Emergency Use Authorization of REGEN-COV (Casirivimab and Imdevimab) (311KB) (updated January 31, 2022); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological); Quick Reference Guide for Co-Packaged REGEN-COV (38KB) (September 16, 2021) | FRN EUA February 19, 2021 (https://www.federalregister.gov/documents/2021/02/19/2021-03429/authorizations-of-emergency-use-of-certain-drug-and-biological-products-during-the-covid-19-pandemic)
11/19/2020 | Baricitinib (Olumiant) (624KB) (Reissued May 10, 2022 and October 27, 2022) | For emergency use by healthcare providers for the treatment COVID-19 in hospitalized pediatric patients 2 to less than 18 years of age requiring supplemental oxygen, non-invasive or invasive mechanical ventilation, or extracorporeal membrane oxygenation (ECMO).; On May 10, 2022, Olumiant was approved for the treatment of COVID-19 in hospitalized adults requiring supplemental oxygen, non-invasive or invasive mechanical ventilation, or ECMO. | Healthcare Providers (Updated May 10, 2022) (272 KB); Patients, Parents, and Caregivers (Updated May 10, 2022) (128 KB); Frequently Asked Questions on the Emergency Use Authorization for Olumiant (baricitinib) for Treatment COVID-19 (270 KB) (Updated May 10, 2022); CDER Scientific Review Documents Supporting EUA (https://www.fda.gov/drugs/coronavirus-covid-19-drugs/cder-scientific-review-documents-supporting-emergency-use-authorizations-drug-and-biological) | FRN EUA February 19, 2021 (https://www.federalregister.gov/documents/2021/02/19/2021-03429/authorizations-of-emergency-use-of-certain-drug-and-biological-products-during-the-covid-19-pandemic)
08/13/2020 | REGIOCIT replacement solution that contains citrate for regional citrate anticoagulation (RCA) of the extracorporeal circuit (92 KB) | To be used as a replacement solution only in adult patients treated with continuous renal replacement therapy (CRRT), and for whom regional citrate anticoagulation is appropriate, in a critical care setting | Healthcare Providers (108 KB)Patients and Caregivers (52 KB)REGIOCIT package insert for EUA (140 KB) | FRN February 19, 2021 (https://www.federalregister.gov/documents/2021/02/19/2021-03429/authorizations-of-emergency-use-of-certain-drug-and-biological-products-during-the-covid-19-pandemic)
04/30/2020 | Fresenius Medical, multiFiltrate PRO System and multiBic/multiPlus Solutions (171 KB) ^3^[also listed under Medical Device EUAs] | To provide continuous renal replacement therapy (CRRT) to treat patients in an acute care environment during the COVID-19 pandemic. | Healthcare Providers (135 KB); Patients (125 KB); Instructions for Use, Bloodline/ Tubing (83 KB); Instructions for Use, UltraFlux (147 KB); Instructions for Use, multiFiltratePRO (15 MB); Summary of Product Characteristics (SmPC) (308 KB); Instructions for Use, MultiPlus (110 KB) | FRN EUA September 11, 2020 (https://www.federalregister.gov/documents/2020/09/11/2020-20041/authorizations-and-revocation-of-emergency-use-of-drugs-during-the-covid-19-pandemic-availability)
04/11/2017 | Atropine Auto-Injector (Rafa Laboratories Ltd.); Letter of Authorization (https://www.fda.gov/media/104550/download) (514 KB); Letter granting EUA amendment(s) (https://www.fda.gov/media/105590/download) (28 KB); 2nd letter granting EUA amendment(s) (https://www.fda.gov/media/110881/download) (33 KB); 3rd letter granting EUA amendment(s) (https://www.fda.gov/media/111656/download) (85 KB); 4th letter granting EUA amendment(s) (https://www.fda.gov/media/113102/download) (42 KB) | For the treatment of poisoning by susceptible organophosphorous nerve agents having cholinesterase activity as well as organophosphorous or carbamate insecticides in adults and pediatric patients weighing over 90 lbs [41 kg] (generally over 10 years of age). | • Healthcare (https://www.fda.gov/media/104559/download) (PDF, 531 KB); • Patients and Caregivers (https://www.fda.gov/media/104564/download) (PDF, 675 KB) | FRN EUA June 30, 2017 (https://www.federalregister.gov/documents/2017/06/30/2017-13664/authorization-of-emergency-use-of-an-injectable-treatment-for-nerve-agent-or-certain-insecticide); May 10, 2017 Nerve Agents and Certain Insecticides (Organophosphorus and/or Carbamate) Countermeasures (https://www.federalregister.gov/documents/2017/05/10/2017-09455/nerve-agents-and-certain-insecticides-organophosphorus-andor-carbamate-countermeasures); April 17, 2017 FRN Determination and Declaration Regarding Emergency Use of Injectable Treatments for Nerve Agent or Certain Insecticide (Organophosphorus and/or Carbamate) Poisoning (https://www.federalregister.gov/documents/2017/04/17/2017-07685/determination-and-declaration-regarding-emergency-use-of-injectable-treatments-for-nerve-agent-or)

^1^ The virus that causes COVID-19 has led to an increased number of patients requiring critical care, such as with severe respiratory illness. As a result, there is a shortage of adequate, FDA-approved drugs used for their treatment, such as propofol for sedation of mechanically ventilated patients.

^3^ The multiBic/multiPlus Solutions include multiBic dialysate and replacement fluid and multiPlus dialysate. The multiBic replacement fluid is regulated as a drug by CDER. The multiFiltrate PRO System, multiBic dialysate and the multiPlus dialysate solutions are regulated as devices by CDRH.

## COVID-19 Convalescent Plasma Clinical Memorandum December 27, 2021 – References

1 Li, L., et al., Effect of Convalescent Plasma Therapy on Time to Clinical Improvement in Patients With Severe and Life-threatening COVID-19: A Randomized Clinical Trial. JAMA, 2020. 324(5): p. 460-470.32492084
2 Gharbharan, A., et al., Convalescent Plasma for COVID-19. A randomized clinical trial. medRxiv, 2020: p. 2020.07.01.20139857.
3 Gharbharan, A., et al., Effects of potent neutralizing antibodies from convalescent plasma in patients hospitalized for severe SARS-CoV-2 infection. Nature Communications, 2021. 12(1): p. 3189.
4 Agarwal, A., et al., Convalescent plasma in the management of moderate covid-19 in adults in India: open label phase II multicentre randomised controlled trial (PLACID Trial). BMJ, 2020. 371: p. m3939.33093056
5 Simonovich, V.A., et al., A Randomized Trial of Convalescent Plasma in Covid-19 Severe Pneumonia. N Engl J Med, 2021. 384(7): p. 619-629.33232588
6 Ray, Y., et al., Clinical and immunological benefits of convalescent plasma therapy in severe COVID-19: insights from a single center open label randomised control trial. medRxiv, 2020: p. 2020.11.25.20237883.
7 AlQahtani, M., et al., Randomized controlled trial of convalescent plasma therapy against standard therapy in patients with severe COVID-19 disease. medRxiv, 2020: p. 2020.11.02.20224303.
8 Avendaño-Solà, C., et al., Convalescent Plasma for COVID-19: A multicenter, randomized clinical trial. medRxiv, 2020: p. 2020.08.26.20182444.
9 Avendano-Sola, C., et al., A multicenter randomized open-label clinical trial for convalescent plasma in patients hospitalized with COVID-19 pneumonia. J Clin Invest, 2021. 131(20).
10 Normand, S.T., The RECOVERY Platform. N Engl J Med, 2021. 384(8): p. 757-758.32706531
11 Abani, O., et al., Convalescent plasma in patients admitted to hospital with COVID-19 (RECOVERY): a randomised controlled, open-label, platform trial. The Lancet, 2021. 397(10289): p. 2049-2059.
12 Writing Committee for the REMAP-CAP Investigators, Effect of Convalescent Plasma on Organ Support–Free Days in Critically Ill Patients With COVID-19: A Randomized Clinical Trial. JAMA, 2021. 326(17): p. 1690-1702.34606578
13 Begin, P., et al., Convalescent plasma for hospitalized patients with COVID-19: an openlabel, randomized controlled trial. Nat Med, 2021. 27(11): p. 2012-2024.34504336
14 Menichetti, F., et al., Effect of High-Titer Convalescent Plasma on Progression to Severe Respiratory Failure or Death in Hospitalized Patients With COVID-19 Pneumonia: A Randomized Clinical Trial. JAMA network open, 2021. 4(11): p. e2136246-e2136246.34842924
15 O'Donnell, M.R., et al., A randomized double-blind controlled trial of convalescent plasma in adults with severe COVID-19. J Clin Invest, 2021. 131(13).
16 Korper, S., et al., Results of the CAPSID randomized trial for high-dose convalescent plasma in patients with severe COVID-19. J Clin Invest, 2021. 131(20).
17 Bar, K.J., et al., A randomized controlled study of convalescent plasma for individuals hospitalized with COVID-19 pneumonia. J Clin Invest, 2021. 131(24).
18 Ortigoza, M.B., et al., Efficacy and Safety of COVID-19 Convalescent Plasma in Hospitalized Patients: A Randomized Clinical Trial. JAMA Intern Med, 2021.
19 Devos, T., et al., Early high antibody-titre convalescent plasma for hospitalised COVID19 patients: DAWn-plasma. Eur Respir J, 2021: p. 2101724.
20 Bennett-Guerrero, E., et al., Severe Acute Respiratory Syndrome Coronavirus 2 Convalescent Plasma Versus Standard Plasma in Coronavirus Disease 2019 Infected Hospitalized Patients in New York: A Double-Blind Randomized Trial. Crit Care Med, 2021. 49(7): p. 1015-1025.33870923
21 Libster, R., et al., Early High-Titer Plasma Therapy to Prevent Severe Covid-19 in Older Adults. N Engl J Med, 2021. 384(7): p. 610-618.33406353
22 Korley, F.K., et al., Early Convalescent Plasma for High-Risk Outpatients with Covid-19. N Engl J Med, 2021. 385(21): p. 1951-1960.34407339
23 Sullivan, D.J., et al., Randomized Controlled Trial of Early Outpatient COVID-19 Treatment with High-Titer Convalescent Plasma. medRxiv, 2021: p. 2021.12.10.21267485.
24 Millat-Martinez, P., et al., Convalescent plasma for outpatients with early COVID-19. medRxiv, 2021: p. 2021.11.30.21266810.
25 Piechotta, V., et al., Convalescent plasma or hyperimmune immunoglobulin for people with COVID-19: a living systematic review. Cochrane Database Syst Rev, 2021. 5(5): p. CD013600.34013969
26 Ling, R.R., et al., Convalescent Plasma for Patients Hospitalized With Coronavirus Disease 2019: A Meta-Analysis With Trial Sequential Analysis of Randomized Controlled Trials. Transfus Med Rev, 2021.
27 Janiaud, P., et al., Association of Convalescent Plasma Treatment With Clinical Outcomes in Patients With COVID-19: A Systematic Review and Meta-analysis. JAMA, 2021. 325(12): p. 1185-1195.33635310
28 Snow, T.A.C., et al., Convalescent plasma for COVID-19: a meta-analysis, trial sequential analysis, and meta-regression. Br J Anaesth, 2021. 127(6): p. 834-844.34579942
29 Axfors, C., et al., Association between convalescent plasma treatment and mortality in COVID-19: a collaborative systematic review and meta-analysis of randomized clinical trials. BMC Infectious Diseases, 2021. 21(1): p. 1170.34800996
30 Senefeld, J.W., et al., Access to and safety of COVID-19 convalescent plasma in the United States Expanded Access Program: A national registry study. PLOS Medicine, 2021. 18(12): p. e1003872.34928960
31 Arnold Egloff, S.A., et al., Convalescent plasma associates with reduced mortality and improved clinical trajectory in patients hospitalized with COVID-19. J Clin Invest, 2021. 131(20).
32 Cho, K., et al., Early Convalescent Plasma Therapy and Mortality Among US Veterans Hospitalized With Nonsevere COVID-19: An Observational Analysis Emulating a Target Trial. J Infect Dis, 2021. 224(6): p. 967-975.34153099
33 Chauhan, L., et al., A Multi-center, Prospective, Observational-cohort controlled study of Clinical Outcomes following COVID-19 Convalescent plasma therapy in hospitalized COVID-19 patients. Clin Infect Dis, 2021.
34 (b) (4)
35 Senefeld, J.W., et al., Use of convalescent plasma in COVID-19 patients with immunosuppression. Transfusion, 2021. 61(8): p. 2503-2511.34036587
36 Fung, M., et al., Treatment of immunocompromised COVID-19 patients with convalescent plasma. Transpl Infect Dis, 2021. 23(2): p. e13477-e13477.32989856
37 Ljungquist, O., et al., Convalescent plasma treatment in severely immunosuppressed patients hospitalized with COVID-19: an observational study of 28 cases. Infect Dis (Lond), 2021: p. 1-9.
38 Jin, H., et al., Three patients with X-linked agammaglobulinemia hospitalized for COVID19 improved with convalescent plasma. J Allergy Clin Immunol Pract, 2020. 8(10): p. 3594-3596.e3.32947026
39 Mira, E., et al., Rapid recovery of a SARS-CoV-2-infected X-linked agammaglobulinemia patient after infusion of COVID-19 convalescent plasma. J Allergy Clin Immunol Pract, 2020. 8(8): p. 2793-2795.32652231
40 Luetkens, T., et al., Successful transfer of anti-SARS-CoV-2 immunity using convalescent plasma in an MM patient with hypogammaglobulinemia and COVID-19. Blood Adv, 2020. 4(19): p. 4864-4868.33031540
41 Furlan, A., et al., Dramatic Response to Convalescent Hyperimmune Plasma in Association With an Extended Course of Remdesivir in 4 B Cell-Depleted Non-Hodgkin Lymphoma Patients With SARS-Cov-2 Pneumonia After Rituximab Therapy. Clin Lymphoma Myeloma Leuk, 2021. 21(9): p. e731-e735.34217677
42 Zimmerli, A., et al., Case Report: Stepwise Anti-Inflammatory and Anti-SARS-CoV-2 Effects Following Convalescent Plasma Therapy With Full Clinical Recovery. Front Immunol, 2021. 12: p. 613502.33968017
43 Tremblay, D., et al., Convalescent Plasma for the Treatment of Severe COVID-19 Infection in Cancer Patients. Cancer Med, 2020. 9(22): p. 8571-8578.32945149
44 Ferrari, S., et al., Convalescent hyperimmune plasma for chemo-immunotherapy induced immunodeficiency in COVID-19 patients with hematological malignancies. Leuk Lymphoma, 2021. 62(6): p. 1490-1496.33461387
45 Balashov, D., et al., SARS-CoV-2 convalescent plasma therapy in pediatric patient after hematopoietic stem cell transplantation. Transfus Apher Sci, 2021. 60(1): p. 102983.33153902
46 Niu, A., et al., COVID-19 in allogeneic stem cell transplant: high false-negative probability and role of CRISPR and convalescent plasma. Bone Marrow Transplantation, 2020. 55(12): p. 2354-2356.32541689
47 Rahman, F., et al., Treatment with convalescent plasma in solid organ transplant recipients with COVID-19: Experience at large transplant center in New York City. Clinical Transplantation, 2020. 34(12): p. e14089.32918761
48 Adedoyin, O., et al., Undetectable SARS-CoV-2 active adaptive immunity-postvaccination or post-COVID-19 severe disease-after immunosuppressants use. BMJ Case Rep, 2021. 14(11).
49 Apostolidis, S.A., et al., Cellular and humoral immune responses following SARS-CoV-2 mRNA vaccination in patients with multiple sclerosis on anti-CD20 therapy. Nat Med, 2021. 27(11): p. 1990-2001.34522051
50 Gavriatopoulou, M., et al., Poor neutralizing antibody responses in 106 patients with WM after vaccination against SARS-CoV-2: a prospective study. Blood Adv, 2021. 5(21): p. 4398-4405.34529762
51 Avanzato, V.A., et al., Case Study: Prolonged Infectious SARS-CoV-2 Shedding from an Asymptomatic Immunocompromised Individual with Cancer. Cell, 2020. 183(7): p. 1901-1912.e9.33248470
52 Corey, L., et al., SARS-CoV-2 Variants in Patients with Immunosuppression. New England Journal of Medicine, 2021. 385(6): p. 562-566.34347959
53 Collier, A.Y., et al., COVID-19 mRNA Vaccine Immunogenicity in Immunosuppressed Individuals. J Infect Dis, 2021.
54 Tepasse, P.R., et al., Persisting SARS-CoV-2 viraemia after rituximab therapy: two cases with fatal outcome and a review of the literature. Br J Haematol, 2020. 190(2): p.185-188.32557623
55 Cusi, M.G., et al., Hyperimmune plasma in three immuno-deficient patients affected by non-severe, prolonged COVID-19: a single-center experience. BMC Infectious Diseases, 2021. 21(1): p. 630.34210259
56 Thompson, M.A., et al., Association of Convalescent Plasma Therapy With Survival in Patients With Hematologic Cancers and COVID-19. JAMA Oncol, 2021. 7(8): p. 1167-1175.34137799
57 Kemp, S.A., et al., SARS-CoV-2 evolution during treatment of chronic infection. Nature, 2021. 592(7853): p. 277-282.33545711
58 Choi, B., et al., Persistence and Evolution of SARS-CoV-2 in an Immunocompromised Host. The New England journal of medicine, 2020. 383(23): p. 2291-2293.33176080
59 Pommeret, F., et al., Bamlanivimab + etesevimab therapy induces SARS-CoV-2 immune escape mutations and secondary clinical deterioration in COVID-19 patients with B-cell malignancies. Ann Oncol, 2021. 32(11): p. 1445-1447.34352377
60 Cross, R.W., et al., Use of convalescent serum reduces severity of COVID-19 in nonhuman primates. Cell Reports, 2021. 34(10): p. 108837.33662255
61 Dougan, M., et al., Bamlanivimab plus Etesevimab in Mild or Moderate Covid-19. New England Journal of Medicine, 2021. 385(15): p. 1382-1392.34260849
62 Weinreich, D.M., et al., REGEN-COV Antibody Combination and Outcomes in Outpatients with Covid-19. New England Journal of Medicine, 2021. 385(23): p. e81.34587383
63 Gupta, A., et al., Early Treatment for Covid-19 with SARS-CoV-2 Neutralizing Antibody Sotrovimab. New England Journal of Medicine, 2021. 385(21): p. 1941-1950.34706189
64 ACTIV-3/TICO LY-CoV555 Study Group, et al., A Neutralizing Monoclonal Antibody for Hospitalized Patients with Covid-19. New England Journal of Medicine, 2020. 384(10): p. 905-914.
65 RECOVERY Collaborative Group, et al., Casirivimab and imdevimab in patients admitted to hospital with COVID-19 (RECOVERY): a randomised, controlled, open-label, platform trial. medRxiv, 2021: p. 2021.06.15.21258542.
66 ACTIV-3/TICO Bamlanivimab Study Group, et al., Clinical and Virological Response to a Neutralizing Monoclonal Antibody for Hospitalized Patients with COVID-19. medRxiv, 2021: p. 2021.07.19.21260559.
67 Stein, D., et al., Compassionate Use of REGEN-COV® in Patients with COVID-19 and Immunodeficiency-Associated Antibody Disorders. medRxiv, 2021: p.2021.11.05.21265911.
68 Vandeberg, P., et al., Production of anti-SARS-CoV-2 hyperimmune globulin from convalescent plasma. Transfusion, 2021. 61(6): p. 1705-1709.33715160
69 Casadevall, A., E. Dadachova, and L.-a. Pirofski, Passive antibody therapy for infectious diseases. Nature Reviews Microbiology, 2004. 2(9): p. 695-703.15372080
70 Sette, A. and S. Crotty, Adaptive immunity to SARS-CoV-2 and COVID-19. Cell.
71 Israelow, B., et al., Adaptive immune determinants of viral clearance and protection in mouse models of SARS-CoV-2. Sci Immunol, 2021. 6(64): p. eabl4509.34623900
72 Wajnberg, A., et al., Humoral response and PCR positivity in patients with COVID-19 in the New York City region, USA: an observational study. Lancet Microbe, 2020. 1(7): p.e283-e289.33015652
73 Röltgen, K., et al., Defining the features and duration of antibody responses to SARSCoV-2 infection associated with disease severity and outcome. Science Immunology, 2020. 5(54): p. eabe0240.33288645
74 Long, Q.-X., et al., Antibody responses to SARS-CoV-2 in patients with COVID-19. Nature Medicine, 2020. 26(6): p. 845-848.
75 Lucas, C., et al., Kinetics of antibody responses dictate COVID-19 outcome. medRxiv, 2020: p. 2020.12.18.20248331.
76 Hamilton, F.W., et al., Is convalescent plasma futile in COVID-19? A Bayesian reanalysis of the RECOVERY randomized controlled trial. International Journal of Infectious Diseases, 2021. 109: p. 114-117.34157385
77 Farnsworth, C.W., et al., Assessment of serological assays for identifying high titer convalescent plasma. Transfusion, 2021. 61(9): p. 2658-2667.34216156
78 Patel, E.U., et al., Comparative Performance of Five Commercially Available Serologic Assays To Detect Antibodies to SARS-CoV-2 and Identify Individuals with High Neutralizing Titers. J Clin Microbiol, 2021. 59(2).
79 Di Germanio, C., et al., SARS-CoV-2 antibody persistence in COVID-19 convalescent plasma donors: Dependency on assay format and applicability to serosurveillance. Transfusion, 2021. 61(9): p. 2677-2687.34121205
80 Bradley, B.T., et al., Anti-SARS-CoV-2 Antibody Levels Measured by the AdviseDx SARS-CoV-2 Assay Are Concordant with Previously Available Serologic Assays but Are Not Fully Predictive of Sterilizing Immunity. Journal of Clinical Microbiology, 2021. 59(9):p. e00989-21.34165323
81 Kunze, K.L., et al., Mortality in individuals treated with COVID-19 convalescent plasma varies with the geographic provenance of donors. Nat Commun, 2021. 12(1): p. 4864.34381030
82 Vickers, M.A., et al., Exponential increase in neutralizing and spike specific antibodies following vaccination of COVID-19 convalescent plasma donors. Transfusion, 2021.61(7): p. 2099-2106.
83 Stamatatos, L., et al., mRNA vaccination boosts cross-variant neutralizing antibodies elicited by SARS-CoV-2 infection. Science, 2021.
84 Romon, I., et al., High-titre anti-SARS-CoV-2 convalescent plasma donation after donors' vaccination. Vox sanguinis, 2021. 116(8): p. 930-931.33745163
85 Jabal, K.A., K.B. Wiegler, and M. Edelstein, Convalescent plasma from people vaccinated after COVID-19 infection. Lancet Microbe, 2021. 2(5): p. e171-e172.33778791
86 Wang, Z., et al., Naturally enhanced neutralizing breadth against SARS-CoV-2 one year after infection. Nature, 2021. 595(7867): p. 426-431.34126625
87 Gallian, P., et al., COVID-19 convalescent plasma: Evolving strategies for serological screening in France. Vox Sang, 2021. n/a(n/a).
88 AABB ABC ARC ASBP, Circular of Information for the Use of Human Blood and Blood Components. 2017.
89 Roubinian, N.H. and D.J. Triulzi, Transfusion-Associated Circulatory Overload and Transfusion-Related Acute Lung Injury: Etiology and Prevention. Hematology/Oncology Clinics of North America, 2019. 33(5): p. 767-779.31466603
90 Kuldanek, S.A., M. Kelher, and C.C. Silliman, Risk factors, management and prevention of transfusion-related acute lung injury: a comprehensive update. Expert Rev Hematol, 2019. 12(9): p. 773-785.31282773
91 Saadah, N.H., et al., Comparing transfusion reaction risks for various plasma products – an analysis of 7 years of ISTARE haemovigilance data. British Journal of Haematology, 2018. 180(5): p. 727-734.29318576
92 Pandey, S. and G.N. Vyas, Adverse effects of plasma transfusion. Transfusion, 2012. 52 Suppl 1(Suppl 1): p. 65s-79s.
93 Buckland, M.S., et al., Treatment of COVID-19 with remdesivir in the absence of humoral immunity: a case report. Nature communications, 2020. 11(1): p. 6385-6385.
94 Helleberg, M., et al., Persistent COVID-19 in an Immunocompromised Patient Temporarily Responsive to Two Courses of Remdesivir Therapy. The Journal of infectious diseases, 2020. 222(7): p. 1103-1107.32702095
95 Camprubí, D., et al., Persistent replication of SARS-CoV-2 in a severely immunocompromised patient treated with several courses of remdesivir. Int J Infect Dis, 2021. 104: p. 379-381.33359065
96 Malsy, J., et al., Sustained Response After Remdesivir and Convalescent Plasma Therapy in a B-Cell-Depleted Patient With Protracted Coronavirus Disease 2019 (COVID-19). Clin Infect Dis, 2021. 73(11): p. e4020-e4024.33103195
97 Bloch, E.M., et al., Deployment of convalescent plasma for the prevention and treatment of COVID-19. J Clin Invest, 2020. 130(6): p. 2757-2765.32254064

## COVID-19 convalescent plasma Decision Memorandum References

1 Li, L., et al., Effect of Convalescent Plasma Therapy on Time to Clinical Improvement in Patients With Severe and Life-threatening COVID-19: A Randomized Clinical Trial. JAMA, 2020.
2 Gharbharan, A., et al., Convalescent Plasma for COVID-19. A randomized clinical trial. medRxiv, 2020: p. 2020.07.01.20139857.
3 Agarwal, A., et al., Convalescent plasma in the management of moderate covid-19 in adults in India: open label phase II multicentre randomised controlled trial (PLACID Trial). BMJ, 2020. 371: p. m3939.33093056
4 Simonovich, V.A., et al., A Randomized Trial of Convalescent Plasma in Covid-19 Severe Pneumonia. New England Journal of Medicine, 2020.
5 Avendano-Sola, C., et al., Convalescent Plasma for COVID-19: A multicenter, randomized clinical trial. medRxiv, 2020: p. 2020.08.26.20182444.
6 Ray, Y., et al., Clinical and immunological benefits of convalescent plasma therapy in severe COVID-19: insights from a single center open label randomised control trial. medRxiv, 2020: p. 2020.11.25.20237883.
7 AlQahtani, M., et al., Randomized controlled trial of convalescent plasma therapy against standard therapy in patients with severe COVID-19 disease. medRxiv, 2020: p. 2020.11.02.20224303.
8 Normand, S.-L.T., The RECOVERY Platform. New England Journal of Medicine, 2020.
9 Statement from RECOVERY trial chief investigators. 2021. Available from: https://www.recoverytrial.net/news/statement-from-the-recovery-trial-chief-investigators15-january-2021-recovery-trial-closes-recruitment-to-convalescent-plasma-treatment-forpatients-hospitalised-with-covid-19.
10 Libster, R., et al., Early High-Titer Plasma Therapy to Prevent Severe Covid-19 in Older Adults. New England Journal of Medicine, 2021.
11 Salazar, E., et al., Significantly Decreased Mortality in a Large Cohort of Coronavirus Disease 2019 (COVID-19) Patients Transfused Early with Convalescent Plasma Containing High-Titer Anti-Severe Acute Respiratory Syndrome Coronavirus 2 (SARSCoV-2) Spike Protein IgG. The American journal of pathology, 2021. 191(1): p. 90-107.33157066
12 Shenoy, A.G., et al., Early mortality benefit with COVID-19 convalescent plasma: a matched control study. British Journal of Haematology. n/a(n/a).
13 Alsharidah, S., et al., COVID-19 Convalescent Plasma Treatment of Moderate and Severe Cases of SARS-CoV-2 Infection: A Multicenter Interventional Study. International Journal of Infectious Diseases, 2020.
14 Rogers, R., et al., Convalescent plasma for patients with severe COVID-19: a matched cohort study. Clinical Infectious Diseases, 2020.
15 Yoon, H.a., et al., Treatment of Severe COVID-19 with Convalescent Plasma in the Bronx, NYC. medRxiv, 2020: p. 2020.12.02.20242909.
16 Klein, M.N., et al., Kinetics of SARS-CoV-2 antibody responses pre- and post- COVID-19 convalescent plasma transfusion in patients with severe respiratory failure: an observational case-control study. medRxiv, 2020: p. 2020.12.10.20247007.
17 Joyner, M.J., et al., Effect of Convalescent Plasma on Mortality among Hospitalized Patients with COVID-19: Initial Three-Month Experience. medRxiv, 2020.
18 Joyner, M.J., et al., Convalescent Plasma Antibody Levels and the Risk of Death from Covid-19. New England Journal of Medicine, 2021.
19 Senefeld, J.W., et al., Therapeutic use of convalescent plasma in COVID-19 patients with immunodeficiency. medRxiv, 2020: p. 2020.11.08.20224790.
20 Clark, E., et al., Convalescent plasma for persisting COVID-19 following therapeutic lymphocyte depletion: a report of rapid recovery. British Journal of Haematology, 2020. 190(3): p. e154-e156.32593180
21 Ferrari, S., et al., Convalescent hyperimmune plasma for chemo-immunotherapy induced immunodeficiency in COVID-19 patients with hematological malignancies. Leuk Lymphoma, 2021: p. 1-9.
22 McMahan, K., et al., Correlates of protection against SARS-CoV-2 in rhesus macaques. Nature, 2020.
23 Sette, A. and S. Crotty, Adaptive immunity to SARS-CoV-2 and COVID-19. Cell.
24 Wajnberg, A., et al., Humoral response and PCR positivity in patients with COVID-19 in the New York City region, USA: an observational study. Lancet Microbe, 2020. 1(7): p. e283-e289.33015652
25 Röltgen, K., et al., Defining the features and duration of antibody responses to SARSCoV-2 infection associated with disease severity and outcome. Science Immunology, 2020. 5(54): p. eabe0240.33288645
26 Long, Q.-X., et al., Antibody responses to SARS-CoV-2 in patients with COVID-19. Nature Medicine, 2020. 26(6): p. 845-848.
27 Lucas, C., et al., Kinetics of antibody responses dictate COVID-19 outcome. medRxiv, 2020: p. 2020.12.18.20248331.
28 Gaebler, C., et al., Evolution of antibody immunity to SARS-CoV-2. Nature, 2021.
29 Wajnberg, A., et al., Robust neutralizing antibodies to SARS-CoV-2 infection persist for months. Science, 2020. 370(6521): p. 1227-1230.33115920
30 Lumley, S.F., et al., Antibody Status and Incidence of SARS-CoV-2 Infection in Health Care Workers. New England Journal of Medicine, 2020.
31 Letizia, A.G., et al., SARS-CoV-2 seropositivity and subsequent infection risk in healthy young adults: a prospective cohort study. medRxiv, 2021: p. 2021.01.26.21250535.
32 Ren, L., et al., The kinetics of humoral response and its relationship with the disease severity in COVID-19. Communications Biology, 2020. 3(1): p. 780.33311543
33 Robbiani, D.F., et al., Convergent antibody responses to SARS-CoV-2 in convalescent individuals. Nature, 2020. 584(7821): p. 437-442.32555388
34 Casadevall, A., E. Dadachova, and L.-a. Pirofski, Passive antibody therapy for infectious diseases. Nature Reviews Microbiology, 2004. 2(9): p. 695-703.15372080
35 Weinreich, D.M., et al., REGN-COV2, a Neutralizing Antibody Cocktail, in Outpatients with Covid-19. New England Journal of Medicine, 2020.
36 Chen, P., et al., SARS-CoV-2 Neutralizing Antibody LY-CoV555 in Outpatients with Covid-19. New England Journal of Medicine, 2020.
37 A Neutralizing Monoclonal Antibody for Hospitalized Patients with Covid-19. New England Journal of Medicine, 2020.
38 Wang, D., et al., Clinical Characteristics of 138 Hospitalized Patients With 2019 Novel Coronavirus–Infected Pneumonia in Wuhan, China. JAMA, 2020. 323(11): p. 1061-1069.32031570
39 Huang, C., et al., Clinical features of patients infected with 2019 novel coronavirus in Wuhan, China. Lancet, 2020. 395(10223): p. 497-506.31986264
40 Berlin, D.A., R.M. Gulick, and F.J. Martinez, Severe Covid-19. New England Journal of Medicine, 2020. 383(25): p. 2451-2460.32412710
41 Wu, Z. and J.M. McGoogan, Characteristics of and Important Lessons From the Coronavirus Disease 2019 (COVID-19) Outbreak in China: Summary of a Report of 72 314 Cases From the Chinese Center for Disease Control and Prevention. JAMA, 2020. 323(13): p. 1239-1242.32091533
42 Sanche, S., et al., High Contagiousness and Rapid Spread of Severe Acute Respiratory Syndrome Coronavirus 2. Emerg Infect Dis, 2020. 26(7): p. 1470-1477.32255761
43 Bhatraju, P.K., et al., Covid-19 in Critically Ill Patients in the Seattle Region — Case Series. New England Journal of Medicine, 2020. 382(21): p. 2012-2022.32227758
44 Suleyman, G., et al., Clinical Characteristics and Morbidity Associated With Coronavirus Disease 2019 in a Series of Patients in Metropolitan Detroit. JAMA Netw Open, 2020. 3(6): p. e2012270.32543702
45 Faes, C., et al., Time between Symptom Onset, Hospitalisation and Recovery or Death: Statistical Analysis of Belgian COVID-19 Patients. Int J Environ Res Public Health, 2020. 17(20).
46 Argenziano, M.G., et al., Characterization and clinical course of 1000 patients with coronavirus disease 2019 in New York: retrospective case series. BMJ (Clinical research ed.), 2020. 369: p. m1996-m1996.
47 AABB, A., ARC, ASBP, Circular of Information for the Use of Human Blood and Blood Components. 2017.
48 Roubinian, N.H. and D.J. Triulzi, Transfusion-Associated Circulatory Overload and Transfusion-Related Acute Lung Injury: Etiology and Prevention. Hematology/Oncology Clinics of North America, 2019. 33(5): p. 767-779.31466603
49 Kuldanek, S.A., M. Kelher, and C.C. Silliman, Risk factors, management and prevention of transfusion-related acute lung injury: a comprehensive update. Expert Rev Hematol, 2019. 12(9): p. 773-785.31282773
50 Saadah, N.H., et al., Comparing transfusion reaction risks for various plasma products – an analysis of 7 years of ISTARE haemovigilance data. British Journal of Haematology, 2018. 180(5): p. 727-734.29318576
51 Eroshenko, N., et al., Implications of antibody-dependent enhancement of infection for SARS-CoV-2 countermeasures. Nature Biotechnology, 2020. 38(7): p. 789-791.