# Erratum

In Table 1 and Appendix E1, patient characteristics, number analyzed, and pain scores were edited to reflect 24 month followup data for one trial publication.1 In Table 1 and Appendix E1, a correction was made to note that imaging correlation was required for one trial (with two publications).2, 3 The quality rating for this same trial was changed from fair to good in Table 1 to match the rating in Appendix E1.^2, 3^ These edits do not affect the report conclusions.

## References

1 Manchikanti L, Singh V, Cash KA, Pampati V, Falco FJ. A randomized, double-blind, active-control trial of the effectiveness of lumbar interlaminar epidural injections in disc herniation. Pain Physician. 2014;17(1):E61-74. [pmid: 24452658].
2 Ghahreman A, Ferch R, Bogduk N. The efficacy of transforaminal injection of steroids for the treatment of lumbar radicular pain. Pain Med. Aug. 2010;11(8):1149-68. [pmid: 20704666].
3 Ghahreman A, Bogduk N. Predictors of a favorable response to transforaminal injection of steroids in patients with lumbar radicular pain due to disc herniation. Pain Med. 2011;12(6):871-9. [pmid: 21539702].