# Addendum (Submitted July 10, 2015)

Searches were updated through May 2015 for the Annals of Internal Medicine publication (Epidural Corticosteroid Injections for Radiculopathy and Spinal Stenosis: Systematic Review and Meta-analysis).

One new trial1 of transforaminal epidural corticosteroid injections versus a placebo intervention for radiculopathy was identified, abstracted (Table 1), quality-rated (Table 2) and added to the meta-analyses. Updated results for the meta-analysis are shown in Tables 3 and 4.

Table 1 Data Abstraction

Author, Year | Study Design | Country Setting | Inclusion Criteria | Exclusion Criteria | Number of Treatment and Control Subjects (number approached, number eligible, number enrolled) | Type of Intervention (experimental & control groups, dose, duration of treatment) | Subject Characteristics | Other Patient Characteristics (expectations of treatment benefit, confidence in clinician, worker's compensation status, ongoing litigation, smoking status, other treatments received)
Manchikanti 2014^1^ | RCT | US Single center Pain clinic | ≥18 years of age; disc herniation and radiculitis; function-limiting low back and lower extremity pain for ≥6 months and NRS pain score >5 on 0 to 10 scale; disc herniation at L4-L5 or L5-S1 | Previous lumbar surgery; radiculitis secondary to spinal stenosis (foraminal or central); radiculitis without disc herniation; bilateral radiculitis; uncontrolled medical illnesses; unstable psychiatric disorders; extremely high dose opioid use; pregnant or lactating; patients with history of or potential for adverse reaction to study medications | Approached: 182 Eligible: 146 Randomized: 120 (60 vs. 60) Analyzed: 120 at 2 years, including 31 (15 vs. 16) with missing data | A: Transforaminal epidural injection with 3 mg betamethasone (0.5 ml) plus 0.5% lidocaine (1.5 ml), with fluoroscopic guidance (n=60) B: Transforaminal epidural injection with 0.5% lidocaine (1.5 ml) and normal saline (0.5 ml), with fluoroscopic guidance (n=60) | A vs. B: Age (mean): 43 vs. 43 years Male: 45% vs. 17% Duration of symptoms (months): 104 vs. 98 Baseline pain (0 to 10 NRS): 8.2 vs. 8.3 Baseline ODI (0–50): 28 vs. 30 | A vs. B: Treatments prior to intervention: Not specified Treatments following intervention: Structured exercise (timing and content not described) L4/5: 50% vs. 48% L5/S1: 65% vs. 72% Other patient characteristics: Not reported

Number and Frequency of Injections Number of Levels Provider Experience | Imaging Guidance | Type of Comparison | Results | Duration of Followup | Loss to Followup | Compliance to Treatment | Adverse Events and Withdrawal due to Adverse Events | Sponsor | Quality Rating
Number and frequency of injections: Mean 4.8 vs. 5.2 over 2 years, frequency not specified Number of levels: Single level Provider experience: Not reported | Fluoroscopic guidance with contrast verification in epidural space | Transforaminal epidural injection with local anesthetic | A vs. B Pain Pain scores (0–10): at baseline 8.2 vs. 8.3; at 3 months 4.0 vs. 4.1; at 6 months 4.1 vs. 3.9; at 12 months 4.1 vs. 3.9; at 24 months 4.2 vs. 4.0 (p>0.05 at all time points) Function ODI (0–50): at baseline 28 vs. 30, at 3 months 15 vs. 16; at 6 months 14 vs. 15; at 12 months 14 vs. 15; at 24 months 14 vs. 15 (p>0.05 at all time points) ODI improved >=50%: at 3 months 67% (40/60) vs. 75% (45/60), RR 0.89 (95% CI 0.71 to 1.12); at 6 months 67% (40/60) vs. 73% (44/60), RR 0.91 (95% CI 0.72 to 1.15); at 12 months 57% (34/60) vs. 75% (45/60), RR 0.76 (95% CI 0.58 to 0.98); at 24 months 57% (34/60 ) vs. 65% (39/60), RR 0.87 (95% CI 0.65 to 1.16) Other outcomes Opioid use (mg MED/day): at baseline 69 vs. 63; at 3 months 41 vs. 49; at 6 months 39 vs. 45; at 12 months 38 vs. 45; at 24 months 37 vs. 43 (p>0.05 at all time points) | 24 months | A vs. B 25% (15/60) vs. 27% (16/60) at 24 months | Appears complete | 4.6% (28/601 injections) intravascular infiltrations and 1.5% (9/601) nerve root irritation, not reported by group; otherwise not reported | None | Poor

Table 2 Quality Rating

Author, Year | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked (injection/ post- injection) | Patient Masked? | Attrition and Withdrawals Reported? | Attrition Acceptable and Comparable? | Analyze People in the Groups in Which They Were Randomized? | Primary Outcome Specified and Reported? | Quality Rating
Manchikanti 2014^1^ | Yes | Unclear | No (large differences on multiple characteristics) | Yes | Unclear | Yes | Yes | Yes | No | Yes | Yes | Poor

Table 3 Pooled Results of Epidural Corticosteroid Injections Versus Placebo Interventions for Radiculopathy

Outcome | Estimate (95% CI) | Number of Trials | I^2^
Pain, mean improvement (WMD)^*^
• Immediate follow-up | −7.55 (−11.4 to −3.74) | 6 2−7 | 30%
• Short-term follow-up | −3.61 (−8.45 to 1.23) | 15 1−3,5–16 | 83%
• Intermediate-term follow-up | 0.71 (−5.50 to 6.92) | 5 1,2,5,14,15 | 7%
• Long-term follow-up | 0.13 (−2.39 to 2.65) | 7 1,5,8,9,13–15 | 0%
Pain, successful composite outcomes (RR)
• Short-term follow-up | 1.21 (0.98 to 1.49) | 8 4,8,11,14,15,17–19 | 67%
• Intermediate-term follow-up | 1.12 (0.93 to 1.36) | 3 11,14,15 | 41%
• Long-term follow-up | 1.10 (0.94 to 1.28) | 4 8,14,15,20 | 0%
Function, mean improvement (SMD)
• Immediate follow-up | −0.75 (−1.62 to 0.11) | 4 2,5,7,21 | 94%
• Short-term follow-up | −0.14 (−0.43 to 0.15) | 13 1,2,5,7–11,13–16,21 | 87%
• Intermediate-term follow-up | −0.22 (−0.61 to 0.18) | 6 1,2,5,14,15,21 | 85%
• Long-term follow-up | −0.17 (−0.47 to 0.12) | 8 1,5,8,9,13–15,21 | 82%
Function, successful composite outcomes (RR)
• Short-term follow-up | 0.98 (0.77 to 1.26) | 7 1,3,8,10,14,15,19 | 73%
• Intermediate-term follow-up | 1.09 (0.86 to 1.38) | 3 1,14,15 | 71%
• Long-term follow-up | 1.07 (0.93 to 1.24) | 4 1,8,14,15 | 0%
Surgery (RR)
• Short-term follow-up | 0.62 (0.41 to 0.92) | 8 3,6,7,17,19,21,22,† | 0%
• Intermediate-term follow-up | 0.56 (0.12 to 2.68) | 1 2 | --
• Long-term follow-up | 0.97 (0.75 to 1.25) | 14 4,5,8,9,11,13,16,18,20,23–27 | 23%
Successful composite outcomes (RR)
• Immediate follow-up | 1.05 (0.87 to 1.27) | 2 14,28 | 0%
• Short-term follow-up | 1.13 (0.98 to 1.32) | 9 2,6,7,10–12,22,24,† | 3.5%
• Intermediate-term follow-up | 0.71 (0.34 to 1.48) | 1 11 | --
• Long-term follow-up | 1.04 (0.81 to 1.34) | 2 14,27 | 0%

Abbreviations: RR=relative risk; SMD=standardized mean difference; WMD=weighted mean difference.

* 0 to 100 scale.

† One publication reported two trials.22

Table 4 Epidural Corticosteroid Injections Versus Placebo Interventions, Stratified by Approach

Outcome | Transforaminal
Pain, mean improvement (WMD)^*^
• Immediate follow-up | −13.3 (−19.9 to −6.77), I^2^=5.8%, 2 trials 4,5
• Short-term follow-up | −0.56 (−4.52 to 3.41), I^2^=0%, 4 trials 1,5,11,16
• Intermediate-term follow-up | 7.72 (−2.34 to 17.8); I^2^=79%, 2 trials 1,5
• Long-term follow-up | 3.29 (−0.82 to 7.39), I^2^=0%, 2 trials 1,5
Pain, successful composite outcomes (RR)
• Short-term follow-up | 1.52 (0.68 to 3.41), I^2^=86%, 3 trials 4,11,19
• Intermediate-term follow-up | 0.71 (0.34 to 1.48), 1 trial 11
• Long-term follow-up | No studies
Function, mean improvement (SMD)
• Immediate follow-up | −0.33 (−0.64 to −0.02), 1 trial 5
• Short-term follow-up | 0.08 (−0.28 to 0.44), I^2^=72%, 4 trials 1,5,11,16
• Intermediate-term follow-up | 0.21 (−0.02 to 0.45), I^2^=0%, 2 trials 1,5
• Long-term follow-up | 0.08 (−0.15 to 0.32), I^2^=0%, 2 trials 1,5
Function, successful composite outcomes (RR)
• Short-term follow-up | 0.79 (0.56 to 1.11), I^2^=45%, 2 trials 1,19
• Intermediate-term follow-up | 0.91 (0.72 to 1.15), 1 trial 1
• Long-term follow-up | 0.87 (0.65 to 1.16), 1 trial 1
Surgery (RR)
• Short-term follow-up | 0.82 (0.29 to 2.32), I^2^=0%, 3 trials 19,22,†
• Long-term follow-up | 0.89 (0.55 to 1.43), I^2^=56%, 5 trials 4,5,11,16,23
Successful composite outcomes (RR)
• Immediate follow-up | No studies
• Short-term follow-up | 1.16 (0.79 to 1.71), I^2^=0%, 3 trials 11,22,†
• Intermediate-term follow-up | 0.71 (0.34 to 1.48), 1 trial 11
• Long-term follow-up | No studies

Abbreviations: RR=relative risk; SMD=standardized mean difference; WMD=weighted mean difference.

* 0 to 100 scale

† One publication reported two trials.22

## References

1 Manchikanti L, Cash KA, Pampati V, Falco FJE. Transforaminal epidural injections in chronic lumbar disc herniation: a randomized, double-blind, active-control trial. Pain Physician. 2014;17(4):E489-E501. [pmid: 25054399].
2 Buchner M, Zeifang F, Brocai DR, Schiltenwolf M. Epidural corticosteroid injection in the conservative management of sciatica. Clin Orthop Relat Res. 2000;(375):149-156. [pmid: 10853164].
3 Datta R, Upadhyay KK. A randomized clinical trial of three different steroid agents for treatment of low backache through the caudal route. Med J Armed Forces India. 2011;67(1):25-33.
4 Ghahreman A, Ferch R, Bogduk N. The efficacy of transforaminal injection of steroids for the treatment of lumbar radicular pain. Pain Med. 2010;11(8):1149-1168. [pmid: 20704666].
5 Karppinen J, Malmivaara A, Kurunlahti M, et al. Periradicular infiltration for sciatica: a randomized controlled trial. Spine (Phila Pa 1976). 2001;26(9):1059-1067. [pmid: 11337625].
6 Klenerman L, Greenwood R, Davenport HT, White DC, Peskett S. Lumbar epidural injections in the treatment of sciatica. Br J Rheumatol. 1984;23(1):35-38. [pmid: 6697071].
7 Valat JP, Giraudeau B, Rozenberg S, et al. Epidural corticosteroid injections for sciatica: a randomised, double blind, controlled clinical trial. Ann Rheum Dis. 2003;62(7):639-643. [pmid: 12810426].
8 Arden NK, Price C, Reading I, et al. A multicentre randomized controlled trial of epidural corticosteroid injections for sciatica: the WEST study. Rheumatology (Oxford). 2005;44(11):1399-1406. [pmid: 16030082].
9 Bush K, Hillier S. A controlled study of caudal epidural injections of triamcinolone plus procaine for the management of intractable sciatica. Spine (Phila Pa 1976). 1991;16(5):572-575. [pmid: 2053000].
10 Carette S, Leclaire R, Marcoux S, et al. Epidural corticosteroid injections for sciatica due to herniated nucleus pulposus. N Engl J Med. 1997;336(23):1634-1640. [pmid: 9171065].
11 Cohen SP, White RL, Kurihara C, et al. Epidural steroids, etanercept, or saline in subacute sciatica: a multicenter, randomized trial. Ann Intern Med. 2012;156(8):551-559. [pmid: 22508732].
12 Helliwell M, Robertson J, Ellis R. Outpatient treatment of low-back pain and sciatica by a single extradural corticosteroid injection. British Journal of Clinical Practice. 1985;39(6):228-231.
13 Iversen T, Solberg TK, Romner B, et al. Effect of caudal epidural steroid or saline injection in chronic lumbar radiculopathy: multicentre, blinded, randomised controlled trial. BMJ. 2011;343:d5278. [pmid: 21914755].
14 Manchikanti L, Singh V, Cash KA, Pampati V, Damron KS, Boswell MV. Effect of fluoroscopically guided caudal epidural steroid or local anesthetic injections in the treatment of lumbar disc herniation and radiculitis: a randomized, controlled, double blind trial with a two-year follow-up. Pain Physician. 2012;15(4):273-286. [pmid: 22828681].
15 Manchikanti L, Singh V, Cash KA, Pampati V, Falco FJ. A randomized, double-blind, active-control trial of the effectiveness of lumbar interlaminar epidural injections in disc herniation. Pain Physician. 2014;17(1):E61-E74. [pmid: 24452658].
16 Tafazal S, Ng L, Chaudhary N, Sell P. Corticosteroids in peri-radicular infiltration for radicular pain: a randomised double blind controlled trial. One year results and subgroup analysis. Eur Spine J. 2009;18(8):1220-1225. [pmid: 19387704].
17 Dilke TF, Burry HC, Grahame R. Extradural corticosteroid injection in management of lumbar nerve root compression. Br Med J. 1973;2(5867):635-637. [pmid: 4577015].
18 Matthews JA, Mills SB, Jenkins VM, et al. Back Pain and Sciatica: Controlled Trials of Manipulation, Traction, Sclerosant, and Epidural Injections. Br J Rheumatol. 1987;26(6):16-23. [pmid: 2961394].
19 Ng L, Chaudhary N, Sell P. The efficacy of corticosteroids in periradicular infiltration for chronic radicular pain: a randomized, double-blind, controlled trial. Spine (Phila Pa 1976). 2005;30(8):857-862. [pmid: 15834326].
20 Cuckler JM, Bernini PA, Wiesel SW, Booth RE Jr, Rothman RH, Pickens GT. The use of epidural steroids in the treatment of lumbar radicular pain. A prospective, randomized, double-blind study. J Bone Joint Surg Am. 1985;67(1):63-66. [pmid: 3155742].
21 Sayegh FE, Kenanidis EI, Papavasiliou KA, Potoupnis ME, Kirkos JM, Kapetanos GA. Efficacy of steroid and nonsteroid caudal epidural injections for low back pain and sciatica: a prospective, randomized, double-blind clinical trial. Spine (Phila Pa 1976). 2009;34(14):1441-1447. [pmid: 19525834].
22 Kraemer J, Ludwig J, Bickert U, Owczarek V, Traupe M. Lumbar epidural perineural injection: a new technique. Eur Spine J. 1997;6(5):357-361. [pmid: 9391811].
23 Riew KD, Park JB, Cho YS, et al. Nerve root blocks in the treatment of lumbar radicular pain. A minimum five-year follow-up. J Bone Joint Surg Am. 2006;88(8):1722-1725. [pmid: 16882893].
24 Rogers P, Nash T, Schiller D, Norman J. Epidural steroids for sciatica. Pain Clinic. 1992;5:67-72.
25 Snoek W, Weber H, Jorgensen B. Double blind evaluation of extradural methyl prednisolone for herniated lumbar discs. Acta Orthop Scand. 1977;48(6):635-641. [pmid: 343479].
26 Wilson-MacDonald J, Burt G, Griffin D, Glynn C. Epidural steroid injection for nerve root compression. A randomised, controlled trial. J Bone Joint Surg Br. 2005;87(3):352-355. [pmid: 15773645].
27 el Zahaar MS. The value of caudal epidural steroids in the treatment of lumbar neural compression syndromes. J Neurol Orthop Med Surg. 1991;12:181-184.
28 Beliveau P. A comparison between epidural anaesthesia with and without corticosteroid in the treatment of sciatica. Rheumatol Phys Med. 1971;11(1):40-43. [pmid: 5551095].