# Executive Summary

## Background

Low back pain is one of the most frequently encountered conditions in clinical practice. Up to 84 percent of adults have low back pain at some time in their lives, and a national survey of U.S. adults in 2002 found that over one-quarter reported low back pain lasting at least a whole day in the previous 3 months.1, 2 Although low back pain affects individuals of all ages, its prevalence peaks at 55 to 64 years of age and remains common in those 65 years of age and older.3 Low back pain can have major adverse impacts on quality of life and function and is frequently associated with depression or anxiety. Low back pain is also costly. In 1998, total U.S. health care expenditures for low back pain were estimated at $90 billion.4 Since that time, costs of low back pain care have risen substantially, at a rate higher than observed for overall health expenditures.5 Low back pain is one of the most common reasons for missed work or reduced productivity while at work, resulting in high indirect costs; this makes the total costs associated with low back pain substantially higher than the direct health care costs.6

The prognosis of acute low back pain (an episode lasting less than 4 weeks) is generally favorable. Following onset of low back pain, most patients experience a rapid improvement in (and often a complete resolution of) pain and disability and are able to return to work.7 In those with persistent symptoms, continued improvement is often seen in the subacute phase between 4 and 12 weeks, though at a slower rate than observed in the acute phase. In a minority of patients, low back pain lasts longer than 12 weeks, at which point it is considered chronic, and levels of pain and disability often remain relatively constant.8 Such patients appear to account for the bulk of the burdens and costs associated with low back pain.9, 10

In the majority (>85%) of patients with low back pain, symptoms cannot be attributed to a specific disease or spinal pathology.11 Spinal imaging abnormalities such as degenerative disc disease, facet joint arthropathy, and bulging or herniated intervertebral discs are extremely common in patients with low back pain, particularly in older adults. However, such findings poorly predict the presence or severity of low back pain.12 Radiculopathy from nerve root impingement and spinal stenosis (narrowing of the spinal canal) each occur in about 4 to 5 percent of patients with low back pain and can cause neurological symptoms such as lower extremity pain, paresthesias, and weakness.13, 14

Multiple treatment options for subacute and chronic low back pain are available. Broadly, these can be classified as pharmacological treatments,15 nonpharmacological treatments (e.g., exercise therapy, cognitive behavioral therapy, spinal manipulation, acupuncture, and others),16 injection therapies,17 and surgical treatments.18 Injection therapies, the topic of this evidence review, include injections of medications to various structures in and around the spine (such as the epidural space, facet joints, intervertebral discs, and soft tissues).17 The most commonly used medications in back injections are corticosteroids to reduce inflammation and local anesthetics for analgesia, though others (such as anti-tumor necrosis factor agents, clonidine, methylene blue, and ozone) have also been studied. Corticosteroid injections can be administered into the epidural space or in and around the facet joints. Other interventional therapies involve the application of various types of energy to ablate pain-generating nerves, without the injection of medications.17 Ablative therapies include radiofrequency denervation, intradiscal electrothermal therapy, percutaneous intradiscal radiofrequency thermocoagulation, and other procedures.

Between 1994 and 2001, use of epidural injections increased by 271 percent and facet joint injections by 231 percent among Medicare beneficiaries.19 Total inflation-adjusted reimbursed costs (based on professional fees only) increased from $24 million to over $175 million over this time period. More recent data indicate continued rapid growth in use of spinal injection therapies among Medicare beneficiaries, with an increase of 187 percent in use between 2000 and 2008.^19^

Despite these dramatic increases, use of injection therapies for low back pain remains controversial. Systematic reviews of injection therapies have come to conflicting conclusions regarding the benefits of injection therapies,17, 20–27 and clinical practice guidelines provide discordant recommendations regarding their use.28–34 An important challenge in interpreting the evidence on injection therapies is the inconsistency of results across trials. Some of this inconsistency could be due to variability across studies in the methods used to select patients for inclusion, the specific injection techniques used, the comparisons evaluated, and the outcomes assessed.17 For example, trials of epidural corticosteroid injections for radiculopathy differ in how they define radiculopathy, whether imaging correlation with symptoms is required to be eligible for inclusion, the specific findings on imaging required for eligibility, the duration of pain, and other factors. All of these factors, which impact how patients are selected for study inclusion, could affect outcomes related to the injection therapy. There has also been variability in methods used to approach the epidural space (e.g., interlaminar [via the interlaminar space in the spine], transforaminal [through the neuroforamen of the exiting nerve root], or caudal [through the sacral hiatus at the sacral canal]), the use of fluoroscopic guidance, the volume of injectate administered, the specific corticosteroid and dose used, the local anesthetic used, and the number of injections and levels injected.23 In addition, trials have compared an epidural corticosteroid injection to an epidural saline injection, epidural injection of local anesthetic without corticosteroid, a soft tissue injection with local anesthetic and/or saline, no injection, or noninjection comparators.35 Similarly, for trials of facet joint injections, diagnostic methods for identifying patients with presumed facet joint pain vary across studies, including use of single or double facet joint blocks, the type and dose of corticosteroid injected, and the location of the injection (e.g., intra-articular [into the facet joint] or peri-articular [around the facet joint]).28 Although medial branch blocks, which are performed at the medial branch of the primary dorsal ramus nerves that innervate the facet joints were originally developed as a diagnostic test to determine presence of facet joint, they have also been evaluated as therapeutic facet joint injections using corticosteroid and/or local anesthetic.

All of these factors could introduce heterogeneity and make it difficult to determine whether negative results in a given trial are due to suboptimal patient selection, an ineffective therapy, or some combination of both factors.17 Another challenge is that trials of injection therapies have frequently focused on short-term outcomes related to pain, rather than longer-term functional outcomes.

Given the continued growth in use of epidural, facet joint, and sacroiliac injections for low back pain and continued uncertainty regarding their role and optimal use, the purpose of this systematic review is to summarize the current state of evidence, identify and evaluate inconsistencies in the evidence on these therapies, and identify important research gaps.

## Scope of Review and Key Questions

The Key Questions used to guide this report are shown below. The analytic framework (Figure A) shows the target populations, interventions, and outcomes that we examined.

Figure A Analytic framework for pain management injection therapies for low back pain

^a^ Patients with nonradicular low back pain, low back pain with radiculopathy, and low back pain with spinal stenosis.

Injections_AF.jpg

Key Question 1. In patients with low back pain, what is the effectiveness of epidural corticosteroid injections, facet joint corticosteroid injections, medial branch blocks, and sacroiliac joint corticosteroid injections versus epidural nonsteroid injection, nonepidural injection, no injection, surgery or nonsurgical therapies on outcomes related to pain, function and quality of life?

Key Question 1a. How does effectiveness vary according to the medication (corticosteroid, local anesthetic) used, the dose or frequency of injections, the number of levels treated, or degree of provider experience?

Key Question 1b. How does effectiveness vary according to use of imaging guidance or route of administration (e.g., for epidural injections interlaminar, transforaminal, caudal for epidural injections and for facet joint injections intra-articular, extra-articular [peri-capsular] or medial branch injections)?

Key Question 2. In patients with low back pain, what patient characteristics predict responsiveness to injection therapies on outcomes related to pain, function, and quality of life?

Key Question 3. In randomized trials of low back pain injection therapies, how does effectiveness vary according to the control therapy used (e.g., epidural nonsteroid injection, nonepidural injection, no injection)?

Key Question 3a. How do response rates vary according to the specific comparator evaluated (e.g., saline epidural, epidural with local anesthetic, nonepidural injection, no injection, surgery, nonsurgical therapies)?

Key Question 4. What are the harms of epidural corticosteroid, facet joint corticosteroid injections, medial branch blocks, and sacroiliac joint corticosteroid injection compared to epidural nonsteroid injection, nonepidural injection, no injection, surgery, or nonsurgical therapies?

## Objectives

Low back pain is common and injections with corticosteroids are a commonly used treatment option. This report reviews the current evidence on effectiveness and harms of epidural, facet joint, and sacroiliac corticosteroid injections for low back pain conditions.

## Methods

The methods for this Technology Assessment follow the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.36 All methods were determined a priori.

### Input From Stakeholders

This topic was selected for review based on a nomination from the Centers for Medicare and Medicaid Services (CMS). The initial Key Questions for this Technology Assessment were developed with input from CMS staff. The Key Questions and scope were further developed with input from a group of stakeholders (Key Informants) convened for this report to provide diverse stakeholder perspectives and content and methodological expertise. The Key Informants consisted of experts in internal medicine, health services research, pain medicine, radiology, neurology, occupational medicine, and physical medicine and rehabilitation, as well as those representing the patient perspective. Key Informants disclosed financial and other conflicts of interest prior to participation. The AHRQ Task Order Officer and the investigators reviewed the disclosures and determined that the Key Informants had no conflicts of interest that precluded participation. A topic refinement document was then posted for public comment from December 17, 2013, through January 17, 2014 with the Key Questions and inclusion criteria. Based on public comments, we further revised the scope. The protocol for this Technology Assessment was finalized prior to initiation of the review, and was posted on the AHRQ Web site.

### Literature Search Strategy

A research librarian conducted searches in Ovid MEDLINE, the Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, and the National Guideline Clearinghouse from 2008 through October, 2014 (see Appendix A for full search strategy). We restricted search start dates to January 2008, as there are multiple recent systematic evidence reviews directly addressing the Key Questions in the current review, including a good-quality review conducted by the same investigators of the current review that was commissioned by the American Pain Society (APS) and conducted searches through July 2008.^17^ The APS review included all of the interventions addressed in the current review. We used the APS review and other systematic reviews37 to identify studies published prior to 2008.

We also hand searched the reference lists of relevant studies and searched for unpublished studies in ClinicalTrials.gov. We did not solicit Scientific Information Packets for published and unpublished studies because the corticosteroid and local anesthetic drugs examined in this review are generic and the injections do not involve use of proprietary devices.

Literature searches will be updated while the draft report is posted for public comment and undergoing peer review to identify any new publications. Literature identified during the update search will be assessed by following the same process of dual review as all other studies considered for inclusion in the report. If any pertinent new literature is identified for inclusion in the report, it will be incorporated before the final submission of the report.

### Study Selection

We developed criteria for inclusion and exclusion of articles based on the Key Questions and the populations, interventions, comparators, outcomes, timing, setting approach (Appendix B), in accordance with the AHRQ Methods Guide.38 Articles were selected for full-text review if they were about epidural injections, facet joint injections, therapeutic medial branch injections, or sacroiliac injections with corticosteroids for radicular low back pain, spinal stenosis, or nonradicular low back pain, were relevant to a Key Question, and met the predefined inclusion criteria as described below. We excluded studies published only as conference abstracts, restricted inclusion to English-language articles, and excluded studies of nonhuman subjects. Studies had to report original data to be included.

To ensure accuracy, all excluded abstracts were dual reviewed. All citations deemed appropriate for inclusion by at least one of the reviewers were retrieved. Each full-text article was independently reviewed for eligibility for final inclusion by two team members. Discrepancies were resolved through discussion and consensus. A list of the included studies is available in Appendix C; excluded studies are shown Appendix D, with primary reasons for exclusion. Members of the review team were not involved in inclusion decisions for studies that they were authors on.

For epidural injections, we selected studies of adults undergoing epidural corticosteroid injections with radicular low back pain, spinal stenosis, nonradicular low back pain, or chronic postsurgical pain. We defined radiculopathy as presence of leg pain (typically worse than back pain), with or without sensory deficits or weakness, in a nerve root distribution. A number of studies used the term “sciatica,” which we classified as radiculopathy. We included epidural injections performed via any approach, including the transforaminal, interlaminar, or caudal techniques. We also included studies of injections performed via the transforaminal approach that targeted the affected nerve root but did not necessarily enter the epidural space (“periradicular” injections).

For facet joint and sacroiliac injections, we selected studies of adults undergoing corticosteroid injections in or around the facet or sacroiliac joints for nonradicular low back pain presumed to originate from the facet joints (facet injections) or sacroiliac joints (sacroiliac injections). We included injections into the joint (intra-articular) or around the joint (extra-articular [peri-articular]), as well as therapeutic medial branch blocks (injections at the site of the medial branch of the dorsal ramus nerves innervating the facet joints).

We excluded studies of patients younger than 18 years of age, pregnant women, and patients with back pain due to fracture, high-impact trauma, cancer, infection, or spondyloarthropathy. We excluded studies of noninjection ablative therapies such as intradiscal electrothermal therapy or radiofrequency denervation, other noninjection therapies such as nucleoplasty, and studies that involved injection of noncorticosteroid medications (such as ozone, antitumor necrosis factor medications, methylene blue, or clonidine) unless they were compared to a corticosteroid injection. Studies on the diagnostic accuracy of diagnostic blocks was outside the scope of the review, but we evaluated how use of diagnostic blocks to select patients impacted estimates of effectiveness.

We included studies of patients with symptoms of any duration prior to enrollment. We included studies that compared the injections of interest versus epidural nonsteroid injections, soft tissue injections, no injection, surgery, or noninjection, nonsurgical therapies. We classified epidural injections with local anesthetics or saline, soft tissue injections with local anesthetics or saline, and no injections as “placebo” interventions to distinguish them from “active” interventions such as epidural injections of other medications, other interventional procedures, surgery, or nonsurgical, noninterventional therapies. We also included studies that compared different injection techniques and corticosteroid doses.

Outcomes were pain, function, quality of life, opioid use, subsequent surgery, health care utilization, and harms, including bleeding, infection, neurological events, and systemic complications such as weight gain, diabetes, osteoporosis, and other endocrinological effects. We included outcomes measured 1 week or later after the injection.

We included randomized trials for all Key Questions. For harms, we also included large (sample size >1000 patients) treatment series of patients who underwent the injections of interest. We excluded case series and case reports. We reviewed reference lists of systematic reviews for potentially relevant references.

### Data Extraction

We extracted the following information from included studies into evidence tables using Excel spreadsheets: study design, year, setting, country, sample size, inclusion and exclusion criteria (including age, sex, race, back pain condition, duration of pain, baseline pain, baseline function, prior therapies, imaging and diagnostic findings, and psychosocial factors), intervention characteristics (including type and dose of corticosteroid and local anesthetic, volume of injectate, number and frequency of injections, levels injected, injection approach, use of imaging guidance, and experience of the person performing the injection), characteristics of the control intervention, and results.

For studies of interventions, we calculated relative risks and associated 95 percent confidence intervals (CI) based on the information provided (sample sizes and incidence of outcomes of interest in each intervention group). We noted discrepancies between calculated and reported results when present.

Data extraction for each study was performed by two investigators. The first investigator extracted the data, and the second investigator independently reviewed the extracted data for accuracy and completeness.

### Assessing Quality

We assessed quality (risk of bias) for each study using predefined criteria. We used the term “quality” rather than the alternate term “risk of bias;” both refer to internal validity. Randomized trials were evaluated with criteria and methods developed by the Cochrane Back Review Group.39 These criteria were applied in conjunction with the approach recommended in the chapter, Assessing the Risk of Bias of Individual Studies When Comparing Medical Interventions,38 in the AHRQ Methods Guide. Two investigators independently assessed the quality of each study. Discrepancies were resolved through discussion and consensus. Members of the review team who were authors on included studies were not involved in quality rating of those studies.

Individual studies were rated as having “poor,” “fair,” or “good” quality. We rated the quality of each randomized trial based on the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; whether attrition was adequately reported and acceptable; similarity in use of cointerventions; compliance to allocated treatments; the use of intent-to-treat analysis; and avoidance of selective outcomes reporting.39, 40

Studies rated “good quality” are considered to have low risk of bias and their results are likely to be valid. Studies rated “fair quality” have some methodological shortcomings, but no flaw or combination of flaws judged likely to cause major bias. In some cases, the article did not report important information, making it difficult to assess its methods or potential limitations. The “fair-quality” (moderate risk of bias) category is broad and studies with this rating vary in their strengths and weaknesses; the results of some studies assessed to have moderate risk of bias are likely to be valid, while others may be only possibly valid. Studies rated “poor quality” (high risk of bias) have significant flaws that may invalidate the results. They have a serious or “fatal” flaw or combination of flaws in design, analysis, or reporting; large amounts of missing information (including publication of only preliminary results in a subgroup of patients randomized); or serious discrepancies in reporting. The results of these studies are at least as likely to reflect flaws in the study design as the differences between the compared interventions. We did not exclude poor quality studies a priori, but they were considered the least reliable when synthesizing the evidence, particularly when discrepancies between studies were present.

Treatment series of patients undergoing injection therapies were not formally rated because they already are known to have serious limitations due to the lack of a control group of patients who did not undergo injections.

### Assessing Research Applicability

We recorded factors important for understanding the applicability of studies, such as whether the publication adequately described the study sample, the country in which the study was conducted, the characteristics of the patient sample (e.g., age, sex, race, type of back pain, imaging findings, duration or severity of pain, medical comorbidities, and psychosocial factors), the characteristics of the interventions used (e.g., specific corticosteroid, dose, technique, number or frequency of injections, and use of imaging guidance), and the magnitude of effects on clinical outcomes.41 We also recorded the funding source and role of the sponsor. We did not assign a rating of applicability (such as high or low) because applicability may differ based on the user of the report.

For interpreting the clinical importance of mean changes in outcome scores, we defined a minimum clinically important difference as an improvement in 15 points on a 0 to 100 pain scale, 10 points on the Oswestry Disability Index (ODI), and 5 points on the Roland Morris Disability Questionnaire (RDQ).42 These thresholds were recommended in a report from a panel of 36 experts in the low back pain field following a review of the evidence.42

### Evidence Synthesis and Rating the Body of Evidence

We constructed evidence tables summarizing study characteristics, results, and quality ratings for all included studies. We summarized evidence for each Key Question qualitatively using a hierarchy-of-evidence approach, where the best evidence was the focus of our synthesis for each Key Question.

We conducted meta-analyses to summarize data and obtain more precise estimates for outcomes and comparisons for which studies were homogeneous enough to provide a meaningful combined estimate.43 Comparisons for which evidence was suitable for pooling were epidural corticosteroid injection versus placebo (epidural local anesthetic injection, epidural saline injection, soft tissue local anesthetic injection, soft tissue saline injection, needling with no injection, or no injection) for radiculopathy, epidural corticosteroid injection versus placebo for spinal stenosis, and transforaminal versus interlaminar epidural injections with corticosteroid for radiculopathy.

Outcomes were extracted and stratified by duration of followup as immediate (≤2 weeks), short term (2 weeks to ≤3 months), intermediate term (3 months to <1 year), and long term (>1 year). For each category, we used the longest duration data available. We analyzed two continuous outcomes: pain and function. For pain, we used pain as measured on a 0 to 10 or 0 to 100 visual analogue or numerical rating scale and converted all scores to 0 (no pain) to 100 (worst possible pain). We used data for leg pain when available; if leg pain was not specifically reported we used overall pain (leg pain is typically worse than back pain in patients with radiculopathy). For studies that assessed function using more than one measure, we prioritized the outcome used for pooling in the following order: the ODI (range 0 to 100), the RDQ (range 0 to 24), and other function scales. In the primary analyses, we combined weighted mean difference (WMD) for pain and standardized mean difference (SMD) for function. The mean difference was calculated using the change between the followup and baseline scores. We also conducted sensitivity analysis based on differences in scores at followup and estimates from analysis of covariance or other results that adjusted for other covariates if available; results were similar to the primary analyses and not reported further. When the standard deviation was missing, we imputed the missing value using the mean standard deviation from other studies in that analysis. For binary outcomes, we combined relative risks (RR) for pain and function “success” (e.g., ≥50% improvement in pain scores or ODI, or as otherwise defined in the trials), composite or overall measures of success (e.g., ≥50% improvement in pain and ≥50% function, or as otherwise defined in the trials), and rates of subsequent surgery. In addition, we pooled placebo response rates for the binary pain and function and mean difference in change scores for pain and function in the placebo group (as a measure of placebo response), stratified by the comparator used.

The studies were combined using the Dersimonian-Laird random effects method. We assessed the presence of statistical heterogeneity among the studies by using the standard Cochran’s chi-square test, and the magnitude of heterogeneity by using the I^2^ statistic.44 When statistical heterogeneity was present, we performed sensitivity analyses by conducting meta-analysis using the profile likelihood method.45 For the primary analyses of epidural injections versus placebo, we pooled across approaches (transforaminal, interlaminar, or caudal), but also stratified the results by approach. We performed sensitivity analyses by excluding poor quality studies and outlier studies. When the number of studies was relatively large (8 to 10),43 we performed additional subgroup analyses and meta-regression based on the specific corticosteroid used, the corticosteroid dose (converted into prednisolone equivalents, for transforaminal ≥50 mg vs. <50 mg; for interlaminar and caudal, ≥100 mg vs. <100 mg), the local anesthetic used, the specific comparator (epidural injection with local anesthetic, epidural injection with saline, soft tissue injection with local anesthetic, soft tissue injection with saline, needling without injection, or no injection), the volume of injected (for transforaminal, >3 ml vs. ≤3 ml; for interlaminar, ≥10 ml vs. <10 ml; for caudal, ≥20 ml vs. <20 ml), the duration of symptoms (restricted to acute [symptoms ≤4 weeks]), whether imaging correlation was required for patient enrollment, whether enrollment was restricted to patients with herniated disc on imaging, use of fluoroscopic guidance, whether the intervention was limited to a single injection, whether patients with prior surgery were excluded, overall quality rating (good, fair, poor), whether the person performing the injection was blinded, and blinding of outcomes assessors and patients. For transforaminal injections, we also stratified studies according to whether the injection clearly entered the epidural space or targeted the nerve root (“periradicular”) without clearly entering the epidural space. Similar analyses were performed for the analysis of transforaminal versus interlaminar injections when data allowed. A funnel plot was created and the Egger test performed for primary analyses across approaches (transforaminal, interlaminar, or caudal) with 10 studies to assess for small study effects.46 All analyses were conducted using Stata/IC 13.0 (StataCorp LP, College Station, TX).

We assessed the strength of evidence (SOE) for each Key Question and outcome using the approach described in the AHRQ Methods Guide,38 based on the overall quality of each body of evidence, based on the risk of bias (graded low, moderate, or high); the consistency of results across studies (graded consistent, inconsistent, or unable to determine when only one study was available); the directness of the evidence linking the intervention and health outcomes (graded direct or indirect); and the precision of the estimate of effect, based on the number and size of studies and confidence intervals for the estimates (graded precise or imprecise).

We graded the SOE for each Key Question using the four categories recommended in the AHRQ Methods Guide.38 A “high” grade indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect. A “moderate” grade indicates moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate. A “low” grade indicates low confidence that the evidence reflects the true effect and further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. An “insufficient” grade indicates evidence either is unavailable or is too limited to permit any conclusion, due to the availability of only poor quality studies, extreme inconsistency, or extreme imprecision.

### Peer Review and Public Commentary

Experts in low back pain and injection therapies, as well as individuals representing important stakeholder groups, have been invited to provide external peer review of this Technology Assessment. The AHRQ Task Order Officer will also provide comments and editorial review. To obtain public comment, the draft report was posted on the AHRQ Web site for 2 weeks. A disposition of comments report detailing the authors' responses to the peer and public review comments will be made available after AHRQ posts the final report on the public Web site.

## Results

We included a total of 92 randomized trials (reported in 107 publications): 78 randomized trials of epidural corticosteroid injections, 13 trials of facet joint injections, and 1 trial of sacroiliac injections were included (Figure B).

Figure B Literature flow diagram

^a^ Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

^b^ Other sources include reference lists of relevant articles, systematic reviews, etc.

^c^ Some studies are included for more than one Key Question.

This figure is a literature flow diagram depicting the search and selection of articles for the present review. The diagram shows that 600 abstracts of potentially relevant articles were identified through MEDLINE, and Cochrane, other sources, while 200 articles were reviewed at the full-text level after excluding 400 non-relevant abstracts and background articles. From the 200 articles reviewed for inclusion, 93 were excluded due to: wrong population (13), wrong intervention (8), wrong outcome (5), wrong study design for key question (32), not a study (letter, editorial, non-systematic review article (8), using original study instead (1), not relevant (26). After excluding these studies, 92 trials in 107 publications are included that provide evidence for any of the Key Questions. The following numbers of studies were included: Key Question 1: 40 for radiculopathy, 10 for spinal stenosis, 2 for non-radicular, 5 for post-surgical, 9 for facet joint and 1 for sacroiliac joint. Key Question 1a: 10 for radiculopathy and 1 for spinal stenosis. Key Question 1b: 11 for radiculopathy, 1 for spinal stenosis, 1 for post-surgical and 4 for facet joint. Key Question 2: 10 for radiculopathy and 2 for spinal stenosis. Key Question 3: 16 for radiculopathy and 2 for spinal stenosis. Key Question 3a: 12 for radiculopathy. Key Question 4: 57 for radiculopathy, 12 for spinal stenosis, 2 for non-radicular, 4 for post-surgical, 10 for facet joint and 1 for sacroiliac joint.

For epidural corticosteroid injections versus placebo interventions for radiculopathy, the only statistically significant effects were on mean improvement in pain at immediate-term followup (WMD −7.55 on a 0 to 100 scale, 95% CI −11.4 to −3.74) (SOE: moderate), mean improvement in function at immediate-term followup when an outlier trial was excluded (SMD −0.33, 95% CI −0.56 to −0.09) (SOE: low), and risk of surgery at short-term followup (RR 0.62, 95% CI 0.41 to 0.92) (SOE: low). The magnitude of effects on pain and function was small, did not meet predefined thresholds for minimum clinically important differences, and there were no differences on outcomes at longer-term followup. Evidence on effects of different injection techniques, patient characteristics, or comparator interventions estimates was limited and did not show clear effects. Trials of epidural corticosteroid injections for radiculopathy versus nonplacebo interventions did not clearly demonstrate effectiveness (SOE: insufficient to low).

Evidence was limited for epidural corticosteroid injections versus placebo interventions for spinal stenosis (SOE: low to moderate) or nonradicular back pain (SOE: low), but showed no differences in pain, function, or likelihood of surgery.

Studies found no clear differences between various facet joint corticosteroid injections (intra-articular, extra-articular [peri-capsular], or medial branch) and placebo interventions (SOE: low to moderate). There was insufficient evidence from one very small trial to determine effects of periarticular sacroiliac joint corticosteroid injections injection (SOE: insufficient).

Serious harms from injections were rare in randomized trials and observational studies, but harms reporting was suboptimal (SOE: low).

## Discussion

### Key Findings and Strength of Evidence Summary

The key findings of this review are summarized in the summary of evidence table (Table A) below.

Table A Summary of evidence

Key Question Outcome | Strength of Evidence Grade | Conclusion
Key Question 1. In patients with low back pain, what is the effectiveness of epidural corticosteroid injections, facet joint corticosteroid injections, medial branch blocks, and sacroiliac joint corticosteroid injections vs. epidural nonsteroid injection, nonepidural injection, no injection, surgery or nonsurgical therapies on outcomes related to pain, function and quality of life?
Epidural injections for radiculopathy
Epidural corticosteroid injections vs. placebo interventions
Mean improvement in pain, immediate-term followup | Moderate | Epidural corticosteroid injections associated with greater improvement vs. placebo interventions (6 trials, WMD −7.55 on 0 to 100 scale, 95% CI −11.4 to −3.74, I2=30%)
Mean improvement in pain, short-term followup | Low | No difference (14 trials, WMD −3.94, 95% CI −9.11 to 1.24, I2=82%)
Mean improvement in pain, intermediate-term followup | Low | No difference (4 trials, WMD −0.07, 95% CI −8.41 to 8.26, I2=82%)
Mean improvement in pain, long-term followup | Moderate | No difference (6 trials, WMD −0.86, 95% CI −3.78 to 2.06, I2=0%)
Successful pain outcome, short-term followup | Low | No difference (8 trials, RR 1.21, 95% CI 0.98 to 1.49, I2=67%)
Successful pain outcome, intermediate-term followup | Low | No difference (3 trials, RR 1.12, 95% CI 0.93 to 1.36, I2=41%)
Successful pain outcome, long-term followup | Moderate | No difference (4 trials, RR 1.10, 95% CI 0.94 to 1.28, I2=0% )
Mean improvement in function, immediate-term followup | Low | No difference, based on all trials (4 trials, SMD −0.75, 95% CI −1.62 to 0.11, I2=94%). Excluding an outlier trial eliminated statistical heterogeneity and resulted in a statistically significant effect favoring epidural corticosteroid injections (3 trials, SMD −0.33, 95% CI −0.56 to −0.09, I2=0%)
Mean improvement in function, short-term followup | Moderate | No difference (11 trials, SMD −0.03, 95% CI −0.20 to 0.15, I2=53%)
Mean improvement in function, intermediate-term followup | Low | No difference (5 trials, SMD −0.30, 95% CI −0.74 to 0.15, I2=86%)
Mean improvement in function, long-term followup | Low | No difference (7 trials, SMD −0.23, 95% CI −0.55 to 0.10, I2=82%)
Successful functional outcome, short-term followup | Low | No difference (6 trials, RR 1.01, 95% CI 0.74 to 1.38, I2=76%)
Successful functional outcome, intermediate-term followup | Low | No difference (2 trials, RR 1.18, 95% CI 0.89 to 1.57, I2=71%)
Successful functional outcome, long-term followup | Low | No difference (3 trials, RR 1.15, 95% CI 0.97 to 1.35, I2=0%)
Risk of surgery, short-term followup | Low | Epidural corticosteroid injections were associated with lower risk vs. placebo interventions (8 trials, RR 0.62, 95% CI 0.41 to 0.92, I2=0%), but the estimate was no longer statistically significant after exclusion of poor-quality trials (5 trials, RR 0.69, 95% CI 0.42 to 1.13, I2=0%)
Risk of surgery, intermediate-term followup | Low | No difference (1 trial, RR 0.56, 95% CI 0.12 to 2.68)
Risk of surgery, long-term followup | Moderate | No difference (14 trials, RR 0.97, 95% CI 0.75 to 1.25, I2=23%)
Successful composite outcome, short-term followup | Moderate | No difference (9 trials, RR 1.13, 95% CI 0.98 to 1.32, I2=3.5%)
Successful composite outcome, intermediate-term followup | Low | No difference (1 trial, RR 0.71, 95% CI 0.34 to 1.48)
Successful composite outcome, long-term followup | Low | No difference (2 trials, 1.04, 95% CI 0.81 to 1.34, I2=0%)
Epidural corticosteroid injections vs. other interventions
Pain, function, surgery | Insufficient | There was insufficient evidence from two trials to determine effects of epidural corticosteroid injections vs. discectomy, due to methodological shortcomings in the trials
Pain function, surgery | Low | One trial found epidural corticosteroid injections associated with lower likelihood than MILD of achieving ≥ 25 point improvement in leg pain (RR 0.49, 95% CI 0.24 to 1.0), ≥13 point improvement in ODI (RR 0.34, 95% CI 0.34 to 0.95), and ≥5 point improvement in SF-36 (RR 0.34, 95% CI 0.12 to 0.95) through 2 years. There was no difference in risk of undergoing surgery (RR 0.45, 95% CI 0.09 to 2.19)
Pain, function, surgery | Insufficient | There was insufficient evidence from one small (n=26), fair-quality trial to determine effects of epidural corticosteroid injections vs. epidural clonidine injection
Pain, function, analgesic use | Low | One trial found transforaminal epidural corticosteroid injection superior to etanercept on the ODI at 1 month (difference −16 on 0 to 100 scale, 95% CI −26.0 to −6.27). There were no differences on other outcomes, including pain and analgesic use
Pain, function | Low | One trial found no differences between epidural corticosteroid vs. autologous conditioned serum administered via the oblique interlaminar approach in improvement in pain or ODI scores after 22 weeks
Pain, function, surgery | Insufficient | There was insufficient evidence from two trials to determine effects of epidural corticosteroid injections vs. nonsurgical, noninterventional therapies due to methodological shortcomings in the trials and differences in the nonsurgical, noninterventional therapies evaluated
Pain, function | Low | One trial found transforaminal epidural corticosteroid injection with corticosteroid plus hypertonic saline associated with greater decrease in pain intensity through 4 months than a corticosteroid injection alone (difference from baseline −2.78 vs. −1.50 on 0 to 10 NRS, p=0.05), though the effect was smaller and no longer statistically significant at 6 months. There were no differences in global assessment or the ODI
Pain, function | Low | One trial found no difference between transforaminal epidural injection with corticosteroid versus corticosteroid plus low-dose clonidine in pain scores through 12 weeks in patients with subacute low back pain
Epidural injections for spinal stenosis
Epidural corticosteroid injections vs. placebo interventions
Mean improvement in pain, immediate-term followup | Low | Epidural corticosteroid injection was superior to placebo at intermediate-term followup (1 trial, WMD −22.0, 95 % −36.0 to −8.0)
Mean improvement in pain, short-term followup | Moderate | No difference (5 trials, WMD 0.62, 95% CI −2.87 to 4.11, I2=0%)
Mean improvement in pain, intermediate-term followup | Low | No difference (3 trials, WMD 3.73, 95% CI −0.81 to 8.26, I2=0%)
Mean improvement in pain, long-term followup | Low | No difference (1 trial, mean difference 4.00, 95% CI −2.87 to 10.9)
Successful pain outcome, short-term followup | Low | No difference (3 trials, RR 0.98, 95% CI 0.84 to 1.15, I2=0%)
Successful pain outcome, intermediate-term followup | Low | No difference (2 trials, RR 0.98, 95% CI 0.78 to 1.24, I2=0%)
Successful pain outcome, long-term followup | Low | No difference (3 trials, RR 0.97, 95% CI 0.74 to 1.28, I2=0%)
Mean improvement in function, immediate-term followup | Low | No difference (2 trials, SMD −0.32, 95% CI −0.85 to 0.22, I2=0%)
Mean improvement in function, short-term followup | Moderate | No difference (5 trials, SMD −0.03, 95% CI −0.31 to 0.26, I2=60%)
Mean improvement in function, intermediate-term followup | Low | No difference (3 trials, WMD 2.81, 95% CI −0.44 to 6.06, I2=0%)
Mean improvement in function, long-term followup | Low | No difference (2 trials, WMD 2.78, 95% CI −1.24 to 6.79, I2=0%)
Successful functional outcome, short-term followup | Low | No difference (3 trials, RR 0.91, 95% CI 0.70 to 1.18, I2=37%)
Successful functional outcome, intermediate-term followup | Low | No difference (2 trials, RR 0.96, 95% CI 0.74 to 1.25, I2=0%)
Successful functional outcome, long-term followup | Low | No difference (2 trials, RR 0.95, 95% CI 0.71 to 1.26, I2=0%)
Successful composite outcome, short-term followup | Low | No difference (2 trials, RR 1.18, 95% CI 0.55 to 2.55, I2=80%)
Successful composite outcome, intermediate-term followup | Low | No difference (1 trial, RR 0.93, 95% CI 0.63 to 1.35)
Successful composite outcome, long-term followup | Low | No difference (2 trials, RR 1.16, 95% CI 0.76 to 1.78, I2=0%)
Risk of surgery, long-term followup | Low | No difference (1 trial, RR 0.76, 95% CI 0.38 to 1.54)
Epidural corticosteroid injections vs. other interventions
Pain, function | Low | One trial found an epidural corticosteroid injection associated with lower likelihood of experiencing ≥2 point improvement in pain at 2 weeks vs. the MILD procedure, but the difference was no longer present at 6 weeks. There was no difference in function
Pain, function | Low | One trial found no differences between and epidural corticosteroid injection vs. intense physical therapy in pain intensity or functional outcomes at 2 weeks through 6 months
Pain, function | Low | One trial found epidural corticosteroid injection associated with worse leg pain than epidural etanercept injection at 1 month, with no difference in functional outcomes
Pain, function | Insufficient | There was insufficient evidence from one poor-quality trial to determine effects of epidural corticosteroid injections vs. epidural adhesiolysis
Epidural corticosteroid injections vs. placebo interventions for nonradicular low back pain
Pain, function, opioid use | Low | Two trials found no differences between epidural corticosteroid injections and epidural local anesthetic injections in pain, function, or opioid use
Epidural injections for chronic postsurgical pain
All outcomes | Insufficient | No trial compared an epidural injection with corticosteroid vs. a placebo intervention
All outcomes | Insufficient | Evidence from 4 trials was insufficient to determine effects of epidural corticosteroid injections vs. other interventions, due to methodological limitations, differences in the comparators evaluated, and small sample sizes
Facet joint injections
Pain, function | Low | Two trials found no clear differences between an intra-articular facet joint injection with corticosteroid vs. saline in pain or function at 1 to 3 months
All outcomes | Insufficient | Evidence from one small, poor-quality trial was insufficient to determine effects of an intra-articular corticosteroid facet joint injection vs. medial branch local anesthetic injection
All outcomes | Insufficient | Evidence from one poor-quality trial was insufficient to determine effects of an extra-articular facet joint corticosteroid injection vs. intra-articular saline injection
Pain, function, opioid use | Low | Two trials found no differences between medial branch corticosteroid injection vs. medial branch local anesthetic injection in pain, function, or opioid use through 12 to 24 months
Pain, function, quality of life | Low | One trial found no clear differences between an intra-articular facet joint versus an intramuscular corticosteroid injection in pain, function, or quality of life through 6 months
Pain, function, quality of life | Low | One trial found no differences between intra-articular facet injection with triamcinolone acetonide vs. hyaluronic acid in pain or function at 1 month or in health-related quality of life at 1 week
Pain, function, analgesic use | Low | One trial found no differences between intra-articular corticosteroid injection plus sham neurotomy vs. medial branch radiofrequency facet neurotomy plus local anesthetic injection in pain, function, or analgesic use at 6 months
Pain, quality of life | Low | One fair-quality trial found medial branch corticosteroid injection inferior to radiofrequency facet denervation on pain at 1, 6, and 12 months, with no differences in quality of life (1, 6, and 12 months), but results may have been confounded by differential use of diagnostic blocks to select patients for inclusion
Sacroiliac joint injections
All outcomes | Insufficient | There was insufficient evidence from one small (n=24) trial to determine effects of peri-articular sacroiliac corticosteroid injection vs. local anesthetic injection
Key Question 1a. How does effectiveness vary according to the medication (corticosteroid, local anesthetic) used, the dose or frequency of injections, the number of levels treated, or degree of provider experience?
Epidural injections
Epidural corticosteroid injections for radiculopathy
Effects of different corticosteroids: all outcomes | Low | Four trials that directly compared epidural corticosteroid injections for radiculopathy with different corticosteroids found few differences in outcomes including pain and function, but conclusions were limited by differences in the corticosteroids compared, doses, and some inconsistency
Effects of different local anesthetics: all outcomes | Insufficient | No trial directly compared effects of epidural corticosteroid injections with one local anesthetic vs. another
Effects of corticosteroid dose: all outcomes | Low | Six trials that directly compared epidural injections for radiculopathy using different corticosteroid doses found no clear differences in outcomes including pain and function
Effects of number of injections, number of levels injected, or provider experience: all outcomes | Low for number of injections, insufficient for number of levels and provider experience | No trial directly compared the effectiveness of epidural corticosteroid injections based on the number of injections, number of levels injected, or provider experience. Two trials found no association between receipt of more injections and better outcomes
Epidural corticosteroid injections for spinal stenosis
Effects of corticosteroids: pain, claudication distance | Low | One trial found no clear differences between caudal epidural injection for spinal stenosis with methylprednisolone vs. triamcinolone in pain or claudication distance through 6 months, though results favored methylprednisolone
Facet joint injections
Effects of different corticosteroids, local anesthetics, doses, frequency or number of injections, or degree of provider experience | Insufficient | No trial of facet joint injections directly compared effects of different corticosteroids, different local anesthetics, different doses, different frequency or number of injections, or degree of provider experience. Indirect evidence was too limited to reach reliable conclusions
Key Question 1b. How does effectiveness vary according to use of imaging guidance or route of administration (e.g., for epidural injections interlaminar, transforaminal, caudal for epidural injections and for facet joint injections intra-articular, extra-articular [peri-capsular] or medial branch injections)?
Epidural injections
Use of imaging
Effects of imaging guidance vs. no imaging guidance: All outcomes | Insufficient | No trial directly compared the effectiveness of epidural injections for radiculopathy performed with or without imaging guidance. Indirect evidence was not useful for evaluating effects of imaging guidance on estimates of effects because use of imaging guidance was highly associated with the epidural technique used
Effects of fluoroscopic plus Doppler vs. fluoroscopic imaging guidance: Pain, function | Low | One trial of caudal epidural corticosteroid injections for radiculopathy found no difference between fluoroscopic plus Doppler guidance vs. fluoroscopic guidance alone in pain or ODI scores through 12 weeks
Effects of imaging to guide epidural injection targets: Pain, function, medication use | Low | One trial found no difference between use of MRI vs. history and physical examination without MRI to guide epidural corticosteroid injection treatment and targets on pain, function, or medication use
Transforaminal vs. interlaminar corticosteroid injections
Mean improvement in pain, immediate-term followup | Low | No difference (5 trials, WMD −10.1, 95% CI −24.8 to 4.6, I2=83%)
Mean improvement in pain, short-term followup | Low | No difference (3 trials, WMD −1.29, 95% CI −12.6 to 10.1, I2=54%)
Mean improvement in pain, intermediate-term followup | Low | No difference (2 trials, WMD −11.3, 95% CI −44.8 to 22.2, I2=87%)
Mean improvement in function, immediate-term followup | Low | No difference (4 trials, SMD 0.03, 95% CI −0.48 to 0.53, I2=68%)
Mean improvement in function, short-term followup | Low | No difference (3 trials, SMD 0.39, 95% CI −0.36 to 1.13, I2=74%)
Mean improvement in function, long-term followup | Low | No difference (1 trial, WMD −2.00, 95% CI −8.77 to 4.77)
Likelihood of undergoing surgery, intermediate-term followup | Low | There were no differences between transforaminal vs. interlaminar epidural corticosteroid injections for radiculopathy in risk of undergoing surgery at intermediate-term followup in two trials (RR 0.76, 95% CI 0.18 to 3.19 and RR 1.33, 95% CI 0.44 to 4.05)
Comparisons of other approaches
Epidural injections for radiculopathy
Caudal vs. other approaches: Pain, function, depression | Low | One trial found the transforaminal epidural corticosteroid injections for radiculopathy associated with better pain outcomes than the caudal approach, with no differences in measures of function or depression, but no differences between the interlaminar vs. caudal approaches in measures of pain or depression
Oblique vs. standard interlaminar approaches: Successful composite outcome, surgery | Low | One trial found no differences between epidural corticosteroid injections for radiculopathy using the oblique interlaminar vs. standard interlaminar approaches in likelihood of achieving a successful outcome or undergoing surgery
Lateral parasagittal vs. standard interlaminar approaches: Pain, function | Low | One trial of epidural corticosteroid injections for radiculopathy found the lateral parasagittal interlaminar approach associated with greater likelihood of achieving >50% pain relief (RR 4.1, 95% CI 1.4 to 12) and greater improvement in pain and function than the standard interlaminar approach through 6 months; a second trial also reported results that favored the lateral parasagittal approach, but differences were smaller and not statistically significant
Lateral parasagittal vs. transforaminal approaches: Pain | Low | Two trials found no differences between epidural corticosteroid injections for radiculopathy using the lateral parasagittal vs. transforaminal approaches in pain or function through 6 or 12 months
Ganglionic vs. preganglionic transforaminal injections: Successful composite outcome | Low | One trial found transforaminal epidural corticosteroid injections for radiculopathy at the ganglionic vs. preganglionic approaches associated with a lower likelihood of a successful outcome at 1 month (RR 0.80, 95% CI 0.70 to 0.91), though differences were no longer present after 5 months
Epidural injections for spinal stenosis
Transforaminal vs. interlaminar: Leg pain, function | Low | No trial randomized patients with spinal stenosis to different approaches for performing epidural corticosteroid injections. One trial in which epidural corticosteroid injections could be performed by the interlaminar or transforaminal approaches found that interlaminar corticosteroid injections were associated with greater improvement in leg pain and function vs. local anesthetic injections at 3 weeks, but there were no differences between transforaminal corticosteroid vs. local anesthetic injections
Facet joint injections
Intra-articular facet joint corticosteroid injection: Pain | Low | One trial found intra-articular facet joint corticosteroid injection in patients with subacute low back pain selected on the basis of positive facet joint SPECT findings associated with lower pain intensity (3.2 vs. 5.4 on 0 to 10 NRS, p<0.05), greater likelihood of ≥50% pain relief (61% vs. 26%, RR 2.33, 95% CI 1.09 to 5.00), and better ODI score (12 vs. 23, p<0.05). versus medial branch injection at 12 weeks
Intra-articular facet joint vs. medial branch corticosteroid injection for chronic low back pain (imaging findings not required): Pain | Low | One trial found intra-articular facet joint corticosteroid injection associated with higher likelihood of pain relief vs. medial branch injection at 1 month (RR 1.68, 95% CI 1.03 to 2.73), but results were no longer statistically significant at 3 months, and there was no difference in likelihood of experiencing good or excellent pain relief
Intra-articular vs. extra-articular (peri-capsular) facet joint corticosteroid injection: All outcomes | Insufficient | There was insufficient evidence from one poor-quality trial to determine effectiveness of intra- vs. extra-articular (peri-capsular) facet joint corticosteroid injections
Effects of imaging guidance vs. no imaging guidance: All outcomes | Insufficient | No trial directly compared the effectiveness of epidural injections for radiculopathy performed with or without imaging guidance
Effects of CT- vs. ultrasound imaging guidance: Pain | Low | One trial found no difference between CT- vs. ultrasound-guided intra-articular facet joint corticosteroid injections with betamethasone and local anesthetic in pain at 6 weeks
Key Question 2. In patients with low back pain, what patient characteristics predict responsiveness to injection therapies on outcomes related to pain, function, and quality of life?
Epidural injections
Effects of duration: Pain, function | Low | Five of six trials of patients with radiculopathy found no association between duration of symptoms and responsiveness to epidural corticosteroid injections
Effects of age, sex, anxiety/depression, opioid use, baseline function, presence of neurological abnormalities, previous episodes, or work status: Pain, function | Low | Trials or patients with radiculopathy found no association between age, sex, anxiety/depression, opioid use, baseline function, presence of neurological abnormalities, previous episodes, or work status and responsiveness to epidural corticosteroid injections
Effects of cause of radicular symptoms: Pain, function | Insufficient | There was insufficient evidence from 4 trials to determine effects of the cause of radicular symptoms on responsiveness to epidural corticosteroid injections for radiculopathy, due to inconsistent results
Effects of smoking status, body mass index, use of opioid therapies or other concomitant therapies: Pain, function | Insufficient | No study evaluated the association between smoking status, body mass index, opioid therapies, or other concomitant therapies on responsiveness to epidural corticosteroid injection therapies for radiculopathy
Effects of pain, function | Low | Based on meta-regression analyses of trials of epidural corticosteroid injections vs. placebo interventions for radiculopathy, there was no clear association between prior lumbar surgery, requirement for imaging correlation with symptoms, or requirement for presence of herniated disc on imaging and estimates of treatment effect
Effects of race: All outcomes | Low | One trial of patients with spinal stenosis found no interaction between race and responsiveness to epidural corticosteroid injections
Effects of pain, patient satisfaction | Low | One trial of patients with nonradicular low back pain found no differences between transforaminal versus interlaminar epidural corticosteroid injection in pain or a patient satisfaction index in the subgroup of patient with imaging findings of a herniated disc, but in patients with spinal stenosis effects on pain favored the transforaminal approach (1.79 vs. 2.19 on the 0 to 5 Roland pain score, p<0.05; likelihood of improving ≥2 points 51% vs. 31%, RR 1.64, 95% CI 0.98 to 2.76 )
Facet joint injections
Effects of use of SPECT vs. no SPECT to identify targets for facet joint injections: Pain | Low | One trial found no difference between use of SPECT bone scans vs. no SPECT to identify targets for intra- and extra-articular facet joint corticosteroid injections in pain outcomes through 6 months
Sacroiliac joint injections | Insufficient | No evidence
Key Question 3. In randomized trials of low back pain injection therapies, how does effectiveness vary according to the control therapy used (e.g., epidural nonsteroid injection, nonepidural injection, no injection)?
Epidural injections
Effects of type of placebo intervention in patients with radiculopathy: Pain, function | Low | In trials of epidural corticosteroid injections vs. placebo injections for radiculopathy, there were no clear differences in estimates for improvement in pain or function, likelihood of a successful pain or functional outcome, or likelihood of undergoing surgery when trials were stratified according to the type of placebo intervention
Effects of type of control intervention in patients with radiculopathy: All outcomes | Insufficient | Trials of epidural corticosteroid injections vs. other interventions were too limited to determine effects on outcome estimates, due to variability in the interventions evaluated, small numbers of trials, and methodological limitations
Effects of type of placebo intervention in patients with other back conditions: All outcomes | Insufficient | There was insufficient evidence from trials of epidural corticosteroid injections for spinal stenosis, nonradicular back pain, or chronic postsurgical pain, to determine effects of comparators on estimates of effect, due to small numbers of trials for specific comparisons
Facet joint injections
Effects of type of placebo therapy: | Insufficient | There was insufficient evidence from trials facet joint injections to determine effects of comparators on estimates of effect, due to small numbers of trials for specific comparisons
Key Question 3a. How do response rates vary according to the specific comparator evaluated (e.g., saline epidural, epidural with local anesthetic, nonepidural injection, no injection, surgery, nonsurgical therapies)?
Epidural injections for radiculopathy
Epidural corticosteroid injections vs. placebo interventions (direct comparisons): Pain, function, successful outcome | Low | Three trials found no differences between epidural local anesthetic vs. epidural saline injections (3 trials) or soft tissue injections (2 trials) in mean improvements in pain or function or the proportion experiencing pain relief or a successful outcome
Epidural corticosteroid injections vs. placebo interventions (indirect comparisons): Pain function | Low | In trials of epidural corticosteroid injections for radiculopathy, improvement in pain was smaller in patients who received epidural local anesthetic injections (3 trials, WMD −6.51, 95% CI −11.9 to −1.16, I2=45%) than epidural saline injections (4 trials, WMD −19.8, 95% CI −25.1 to −14.3, I2=56%) at immediate-term followup; there were no clear differences at other time points, but analyses were limited by small numbers of trials and statistical heterogeneity
Epidural corticosteroid injections vs. other interventions: Pain, function | Insufficient | Trials were too limited to determine effects on response rates, due to variability in the interventions evaluated, small numbers of trials, and methodological limitations
Key Question 4. What are the harms of epidural corticosteroid, facet joint corticosteroid injections, medial branch blocks, and sacroiliac joint corticosteroid injection compared to epidural nonsteroid injection, nonepidural injection, no injection, surgery, or nonsurgical therapies?
Epidural injections
Harms | Moderate | 29 trials of epidural corticosteroid injections vs. placebo for radiculopathy reported no serious adverse events and few harms, but methods for assessing harms were not well reported and harms data were sparse. Observational studies were consistent with the trials in showing a low risk of serious adverse events
Harms | Moderate | Nine trials of epidural corticosteroid injections vs. other therapies for radiculopathy reported no serious adverse events and few harms
Harms | Low | Two trials of transforaminal vs. interlaminar epidural corticosteroid injections for radiculopathy reported no serious adverse events
Harms | Insufficient | There was insufficient evidence from four trials that compared epidural injections for radiculopathy with different corticosteroids to determine effects on harms
Harms | Insufficient | There was insufficient evidence from six trials of epidural corticosteroid injections for radiculopathy that compared different doses to determine effects on harms
Harms | Low | Eight trials of epidural corticosteroid injections vs. placebo injections for spinal stenosis reported no serious harms and few adverse events, but methods for assessing harms were not well reported and harms data were sparse
Harms | Low | Two trials of epidural corticosteroid injections for nonradicular back pain reported no serious harms
Harms | Insufficient | There was insufficient evidence from four trials of epidural corticosteroid injections for chronic postsurgical back pain to determine effects on harms
Facet joint injections
Harms | Low | Ten trials of facet joint corticosteroid injections reported no serious harms and few adverse events, but methods for assessing harms were not well reported and harms data sparse
Sacroiliac joint injections
Harms | Insufficient | Harms were not reported in one small trial of peri-articular sacroiliac joint injections

CI = confidence interval; MILD = minimally invasive lumbar decompression; ODI = Oswestry Disability Index; RR = relative risk; SF-36 = Short Form-36; SMD = standardized mean difference; SPECT = single photon electronic computed tomography; WMD = weighted mean difference

Strengths of our review are inclusion of additional trials compared with prior reviews, evaluation of epidural corticosteroid injections for back pain conditions other than radiculopathy, evaluation of continuous as well as dichotomous outcomes, evaluation of outcomes at defined time points, evaluation of the effectiveness of epidural corticosteroids versus other active interventions, conduction of additional analyses to evaluate effects of methodological limitations, patient characteristics, and injection techniques on findings.

Evidence was most robust for epidural corticosteroid injections in patients with radiculopathy. In trials of epidural corticosteroid injections versus placebo interventions, the only statistically significant effects were on mean improvement in pain at immediate-term (5 days to ≤2 week) followup (WMD −7.55 on a 0 to 100 scale, 95% CI −11.4 to −3.74), mean improvement in function at immediate-term (SMD −0.33, 95% CI −0.56 to −0.09) followup, and risk of surgery at short-term (>2 weeks to ≤3 months) followup (RR 0.62, 95% CI 0.41 to 0.92). However, the magnitude of the effect on pain was small (WMD −7.55 on 0 to 100 scale) and did not meet our predefined minimum clinically important differences of 15 points.42 The effect on immediate-term function was of only statistically significant when an outlier trial47 was excluded. Differences were also small in the nonoutlier trials (5.1 and 7.6 points on the 0 to 100 ODI)48, 49 and 1.3 points on the 0 to 24 RDQ) and did not meet predefined thresholds for minimum clinically important differences (10 points for the ODI and 5 points for the RDQ).42 Differences were not present for either outcome at longer-term followup. There were also no differences at any time point between epidural corticosteroid injections and placebo interventions in likelihood of experiencing a successful pain, function, or composite outcome; or likelihood of undergoing surgery. Direct evidence from randomized trials on effects of performing epidural corticosteroid injections for radiculopathy using different approaches, different corticosteroids, or different doses was limited, but indicated no clear effects on outcomes. There were also no clear differential effects of the epidural approach used, different corticosteroids, different doses, use of imaging correlation, restriction to patients with herniated disc, duration of symptoms, or exclusion of patients with prior surgery, primarily based on meta-regression and subgroup analyses.

Although comparator interventions such as epidural local anesthetic injection, epidural saline injection, soft tissue injections, and no injection have traditionally been considered placebo interventions, it is possible that they may have some therapeutic effects.35 However, placebo response rates were high in trials of epidural corticosteroid injections regardless of the comparator used and there were no clear differences in estimates of effectiveness based on the specific comparator, suggesting that observed improvements represent the natural history of radiculopathy or a general placebo response.

Trials of epidural corticosteroid injections for radiculopathy versus nonplacebo interventions did not clearly demonstrate effectiveness, but were limited by small numbers of trials for specific comparisons and methodological limitations, resulting in low or insufficient strength of evidence ratings.

Evidence was limited for epidural corticosteroid injections versus placebo interventions for spinal stenosis or nonradicular back pain, but showed no differences in outcomes related to pain or function. The evidence on epidural corticosteroid injections for spinal stenosis included a recent, well-conducted multicenter trial that was also the largest trial (n=386) to date in this population.50 Although epidural injections could be performed by either the interlaminar or transforaminal approach in this trial, there was also no evidence of an effect when results were stratified according to the approach used. Another potential issue in interpreting this trial is that the corticosteroids and doses varied, which could have attenuated effects if certain corticosteroids or lower doses are associated with decreased effectiveness. For chronic postsurgical pain, evidence was very limited. No trial compared epidural corticosteroid injections versus placebo, and trials of epidural corticosteroid injections versus various other interventions found no clear differences.

Evidence was also limited for facet joint corticosteroid injections versus placebo interventions. Studies found no clear differences between various facet joint corticosteroid injections (intra-articular, extra-articular [peri-capsular], or medial branch) and placebo interventions. Although one trial found an intra-articular corticosteroid injection associated with better outcomes than a saline injection at 6 months, results are difficult to interpret because there were no differences at 1 month, the corticosteroid group received more cointerventions, and there was no difference in the likelihood of sustained improvement (improvement at 6 months in patients with improvement at 1 month).51 Trials of facet joint injections versus radiofrequency denervation were difficult to interpret because they reported inconsistent outcomes, evaluation of different types of injections (intra-articular or medial branch corticosteroid injection), and differential use of diagnostic blocks to select patients, depending on which intervention they were randomized to.52, 53

There was insufficient evidence from one very small (n=24) trial to determine effects of peri-articular sacroiliac joint corticosteroid injections versus a placebo (local anesthetic) injection.53

Methods for assessing harms in randomized trials were generally not well reported and data sparsely reported, but evidence from trials and observational studies were consistent in suggesting a low risk of serious harms following epidural injections such as neurological complications or infection. However, cases of serious neurological complications have been reported following lumbar epidural injections, and there was a recent outbreak of serious fungal infections due to contaminated methylprednisolone injections.17, 54, 55

### Findings in Relationship to What is Already Known

Our findings were consistent with a previous qualitative review17 conducted by our team and funded by the APS that found fair evidence that epidural corticosteroid injections for radiculopathy are more effective than placebo interventions for short-term symptom relief, but not for long-term symptom relief, and limited evidence of ineffectiveness for spinal stenosis and nonradicular low back pain. Unlike the current review, which found that short-term effects on pain did not meet the threshold for minimum clinically important differences, the APS review classified the magnitude of short-term benefit for pain relief as “moderate” (equivalent to a 10- to 20-point difference on a 100-point pain scale). However, it noted inconsistency between trials, did not perform meta-analysis, and based some conclusions on prior reviews with small numbers of studies. Our findings were also consistent with more recent qualitative and quantitative systematic reviews, despite variability in the studies included and methods used for data synthesis and meta-analysis.20, 21, 23, 37, 56, 57 Our review was also concordant with other reviews in finding limited evidence that lumbar epidural corticosteroid injections are associated with a low risk of serious harms.17, 20, 54 Like a prior review, we also found no evidence on effectiveness of multiple versus single injections.58 Although one systematic review found an association between volume differences (higher volume relative to control interventions) and effectiveness of epidural corticosteroid injections, results may have been confounded by differences in epidural approaches (e.g., caudal injections typically used higher volumes) and inclusion of comparators that did not involve epidural injections (e.g., soft tissue injections or noninjection therapies).59 We were unable to determine effects of differences in injectate volume on effectiveness, as only three trials that compared epidural corticosteroid injections versus epidural local anesthetic or saline injections reported a volume difference.47, 60, 61

With regard to effects of control interventions on effect estimates, our findings were similar to a recent systematic review that found limited direct evidence showing no differences between epidural nonsteroid and nonepidural injections.35 Although the prior systematic review found some evidence that epidural nonsteroid injections might be more effective than nonepidural injections, its conclusions were based on indirect comparisons that were highly discrepant with direct comparisons. We did not perform indirect comparisons, as the presence of such discrepancies may result in misleading findings.62 Although the prior APS review found some evidence that effects of epidural corticosteroid injections were more likely to be positive in studies that used epidural nonsteroid injection controls than in studies that used nonepidural injection controls, these findings were based on a qualitative evaluation based on counts of positive and negative studies.17

Our findings of limited evidence on facet joint corticosteroid injections versus placebo interventions, without clear demonstration of beneficial effects, were also consistent with prior systematic reviews.17, 63, 64

Some systematic reviews reported more positive conclusions regarding the effectiveness of epidural corticosteroid and facet joint injections.24–26, 65–67 Differences between the methods used in these reviews and ours that may explain the discrepant findings included reliance on qualitative synthesis, inclusion of observational studies, categorization of improvement from baseline following an epidural corticosteroid injection as demonstrating effectiveness (even when there was no difference versus a placebo intervention), and failure to consider inconsistency between trials.

### Applicability

Some issues could impact the applicability of our findings. Results are most applicable to patients with chronic back pain, as few trials enrolled patients with acute or subacute symptoms. Although studies were typically performed in the United States or Europe in specialty settings, they varied in how the injections were performed, including the use of imaging guidance, the specific epidural or facet injection technique used, the methods used to select patients (e.g., use of imaging, the imaging findings required for inclusion, or the use of diagnostic blocks), the types and doses of corticosteroid used, and the number and frequency of injections. Although we found no clear evidence of an association between these factors and estimates of treatment effectiveness, direct evidence from head-to-head trials on these factors was limited. The effectiveness of injection therapies is also likely to depend in part on the skill and experience of the person performing the injection, but we were unable to determine effects of provider experience on treatment effects, as studies did not report this information or reported it in a nonstandardized manner. Because most trials excluded patients with prior lumbar surgery, results may not be applicable to this patient population. The applicability of findings to patients with important medical and psychiatric comorbidities was also uncertain, and there was insufficient evidence to determine how effectiveness might vary based on the receipt of concomitant interventions such as supervised exercise therapy or cognitive behavioral therapy. Trials also differed in methods used to select patients for inclusion. For example, trials of radiculopathy and spinal stenosis differed in the clinical symptoms required for enrolment as well as in whether concordant imaging findings were required, and trials of presumed facet joint pain varied in whether a positive response to diagnostic blocks were required as well as methods for performing blocks (e.g., single or double block).

In order to facilitate interpretation of findings, we stratified outcomes by followup duration. We also compared observed effects on continuous outcomes to previously proposed thresholds for minimum clinically important changes. Although immediate-term effects of epidural corticosteroid injections versus placebo interventions on improvement in pain scores were statistically significant, they did not meet the predefined threshold for a minimum clinically important difference.42 We also evaluated effects of injection therapies on the likelihood of experiencing a clinically meaningful outcome, which might be more clinically interpretable than mean effects on continuous scales.68 Although trials varied in how they defined clinically meaningful outcomes related to pain, function, or overall success, analyses were consistent in showing no effects at different time points.

### Implications for Clinical and Policy Decisionmaking

Our review has implications for clinical and policy decisionmaking. Epidural corticosteroid injections are the most commonly used interventional procedure for low back pain, but evidence indicates that benefits are limited to pain relief and reduced risk of surgery shortly after the procedure in patients with radiculopathy, without long-term benefits on these outcomes and no effect on functional outcomes. Some clinical practice guidelines recommend epidural corticosteroid injections for short-term benefits in patients with persistent radicular symptoms, particularly for patients who are not candidates for or interested in undergoing surgery.28 Factors that may influence decisions about performing epidural corticosteroid injections include how highly patients value short-term symptom improvement of small magnitude, preferences regarding alternative therapies (including surgery), the severity of symptoms, and costs and other burdens. Decisions should also consider the risk of serious harms with epidural injections, which have been reported in case series and other uncontrolled observational studies.69

Potential strategies to enhance the effectiveness of epidural injections would be to perform them using techniques shown to be more effective, or to selectively perform injections in patients more likely to benefit. However, our review found no clear evidence of greater benefits based on technical factors such as the specific epidural technique used, use of fluoroscopic guidance, the specific corticosteroid, the dose, or the number or frequency of injections. Evidence on patient factors was also too limited to identify subgroups of patients more likely to benefit.

Other findings of our review that have implications for clinical and policy decisionmaking included limited evidence of no effectiveness of epidural corticosteroid injections for spinal stenosis or nonradicular low back pain, or for facet joint corticosteroid injections for presumed facet joint pain. Although prior guidelines found insufficient evidence to develop recommendations on use of epidural corticosteroid injections for spinal stenosis and nonradicular low back pain,28 the strength of evidence has improved, particularly for spinal stenosis,50 suggesting that re-evaluation may be appropriate. Guidelines are inconsistent with regard to use of facet joint corticosteroid injections,28, 70, 71 but recent trials have not provided additional evidence to support effectiveness.

### Limitations of the Comparative Effectiveness Review Process

An important limitation of our review is that substantial statistical heterogeneity was present in several pooled analyses. To address this, we used the Dersimonian-Laird random effects model to pool studies. The Dersimonian-Laird random effects model may result in confidence intervals that are too narrow when heterogeneity is present, particularly when the number of studies is small.45 Therefore, we repeated analyses using the profile likelihood method, which resulted in similar findings. Regardless of the method used, meta-analyses based on small numbers of trials can underestimate statistical heterogeneity and must be interpreted with caution.45 We also stratified trials according to the epidural technique used, and further explored heterogeneity by performing additional analyses stratified based on the comparator used, exclusion of poor-quality and outlier studies, and meta-regression (when sufficient numbers of studies were available) on use of blinding, patient selection methods, and methods used to perform the injections (e.g., the corticosteroid or local anesthetic used and the dose). Although statistical heterogeneity remained present in some analyses, with some unexplained outlier trials, results were generally robust in sensitivity and stratified analyses.

Another limitation of our review is that we used indirect comparisons to supplement limited direct evidence on the effects of technical and patient factors on estimates. Although findings based on indirect comparisons were generally consistent with available evidence from head-to-head trials (e.g., showing no clear effects of different corticosteroids, different epidural approaches, or different doses), results based on indirect comparisons should also be interpreted with caution.72

We excluded non-English language articles and did not search for studies published only as abstracts. We only formally assessed for publication bias using statistical and graphical methods to assess for small sample effects when there were at least 10 studies, as research indicates that such methods can be misleading with smaller numbers of studies.46 We found no evidence of small sample effects based on analyses of short-term improvement in pain, short-term improvement in function, or long-term risk of surgery. Finally, we restricted evidence on serious harms to randomized controlled trials and large cohorts of patients undergoing injections, in order to be able to estimate rates of events. Although serious neurological events with epidural corticosteroid injections have been reported in case series and other uncontrolled studies, it is not possible to estimate the rates of events from such data.69

### Limitations of the Evidence Base

An important limitation of the evidence base is the small number of trials available on epidural corticosteroid injections for conditions other than radiculopathy and the small number on effectiveness of facet joint or sacroiliac corticosteroid injections. The lack of evidence made it difficult to reach strong conclusions regarding the effectiveness of these interventions versus placebo interventions or to evaluate effects of methodological, technical, or patient factors on outcomes. Although more trials were available for epidural corticosteroid injections for radiculopathy, there were fewer trials when results were stratified by specific outcomes and time points, and subgroup analyses were limited by the variability in techniques used on a number of factors.

In addition to the small number of trials, the evidence base was limited by methodological limitations in the available studies. Only eight trials were rated good quality. Of the 92 included trials, only 27 trials reported blinding of the person performing the injection, 57 trials blinding of patients, and 47 trials blinding of outcome assessors. Conclusions were generally not impacted by exclusion of poor-quality trials or assessments based on blinding status, but would be stronger if more high-quality trials were available.

Other limitations include the relatively limited number of trials that directly compared different injection techniques, corticosteroids, doses, and comparators. No trials directly compared use of imaging guidance versus no guidance, use of a single injection versus multiple injections, or effects of different injectate volumes. Few trials reported how effectiveness varied according to patient characteristics such as age, sex, race, medical or psychological comorbidities, duration of symptoms, imaging findings, cause of low back pain, use of concomitant therapies, or other factors.

### Research Gaps

Research gaps limit the full understanding of the comparative effectiveness of low back injections. For radiculopathy, additional research could help determine whether patient characteristics such as severity or duration of symptoms, presence of specific imaging findings, or presence of psychiatric comorbidities are associated with responsiveness to injections. If such characteristics are identified, future trials could be designed to focus on more specific target populations that might experience greater benefits. Trials are also needed to understand whether injections may be more effective when given in the context of a more comprehensive approach that includes the delivery of concomitant treatments such as supervised exercise therapy or cognitive behavioral therapy. Additional research would also help confirm whether there are differences in outcomes associated with different epidural injection approaches, corticosteroids, doses, use of imaging guidance, and number and frequency of injections. Ideally such studies would include a placebo intervention group to aid in interpretability of findings.

For spinal stenosis and nonradicular low back pain, evidence was limited but indicated that epidural corticosteroid injections are not effective compared to placebo interventions. Because spinal stenosis is usually degenerative and the etiology of nonradicular low back pain may be difficult to determine, the rationale for performing epidural corticosteroid injections may not be as strong as for radiculopathy due to herniated disc. Additional research on the effectiveness of epidural corticosteroid injections for these conditions may only be warranted if specific subgroups of patients who have more of an inflammatory component can be identified. Limited evidence also indicates that facet joint corticosteroid injections are not effective compared with placebo interventions. The lack of effectiveness could be due to the ineffectiveness of the procedure or suboptimal accuracy methods for identifying patients with facet joint pain.17 A randomized trial found that use of dual or single diagnostic facet joint blocks to select patients for radiofrequency denervation (an intervention not included in this report) was associated with lower rates of successful outcomes than selection of patients without a diagnostic block.73 Therefore, additional research on accurate methods for identifying patients with facet joint pain is needed to inform the design of future intervention studies.

## Conclusions

Epidural corticosteroid injections for radiculopathy are associated with immediate improvements in pain and might be associated with immediate improvements in function, but benefits are small and not sustained, and there is no effect on the long-term risk of surgery. Evidence did not suggest that effectiveness varies based on injection technique, corticosteroid, dose, or comparator. Limited evidence suggested that epidural corticosteroid injections are not effective for spinal stenosis or nonradicular back pain, and that facet joint corticosteroid injections are not effective for presumed facet joint pain. There was insufficient evidence to evaluate the effectiveness of sacroiliac joint corticosteroid injections.

## References

1 Deyo RA, Mirza SK, Martin BI. Back pain prevalence and visit rates: estimates from U.S. national surveys, 2002. Spine (Phila Pa 1976). Nov. 1. 2006;31(23):2724-2727. [pmid: 17077742].
2 Walker BF. The prevalence of low back pain: a systematic review of the literature from 1966 to 1998. J Spinal Disord. Jun. 2000;13(3):205-217. [pmid: 10872758].
3 Freburger JK, Holmes GM, Agans RP, et al. The rising prevalence of chronic low back pain. Arch Intern Med. Feb. 9. 2009;169(3):251-258. [pmid: 19204216].
4 Luo X, Pietrobon R, Sun SX, et al. Estimates and patterns of direct health care expenditures among individuals with back pain in the United States. Spine (Phila Pa 1976). Jan. 1. 2004;29(1):79-86. [pmid: 14699281].
5 Martin BI, Deyo RA, Mirza SK, et al. Expenditures and health status among adults with back and neck problems. JAMA. Feb. 13. 2008;299(6):656-664. [pmid: 18270354].
6 Stewart WF, Ricci JA, Chee E, et al. Lost productive time and cost due to common pain conditions in the US workforce. JAMA. Nov. 12. 2003;290(18):2443-2454. [pmid: 14612481].
7 Pengel LH, Herbert RD, Maher CG, et al. Acute low back pain: systematic review of its prognosis. BMJ. Aug. 9. 2003;327(7410):323. [pmid: 12907487].
8 Chou R, Shekelle P. Will this patient develop persistent disabling low back pain?. JAMA. Apr. 7. 2010;303(13):1295-1302. [pmid: 20371789].
9 Frymoyer JW, Cats-Baril W. Predictors of low back pain disability. Clin Orthop Relat Res. Aug. 1987;221:89-98. [pmid: 2955993].
10 Engel CC, von Korff M, Katon WJ. Back pain in primary care: predictors of high health-care costs. Pain. May-Jun. 1996;5(2–3):197-204. [pmid: 8826507].
11 Chou R, Qaseem A, Owens DK, et al. Diagnostic imaging for low back pain: advice for high-value health care from the American College of Physicians. Ann Intern Med. 2011;154(3):181-189. [pmid: 21282698].
12 van Tulder MW, Assendelft WJ, Koes BW, et al. Spinal radiographic findings and nonspecific low back pain. A systematic review of observational studies. Spine (Phila Pa 1976). Feb. 15. 1997;22(4):427-434. [pmid: 9055372].
13 Chou R, Qaseem A, Snow V, et al. Diagnosis and treatment of low back pain: a joint clinical practice guideline from the American College of Physicians and the American Pain Society.[Erratum appears in Ann Intern Med. 2008 Feb 5;148(3):247-8; PMID: 18257154], [Summary for patients in Ann Intern Med. 2007 Oct 2; 147(7):I45; PMID: 17909203]. Annals of Internal Medicine. Oct. 2. 2007;147(7):478-491. [pmid: 17909209].
14 Chou R, Shekelle P, Qaseem A, et al. Correction: Diagnosis and treatment of low back pain. Ann Intern Med. Feb. 5. 2008;148(3):247-248. [pmid: 18257154].
15 Chou R, Huffman LH. Medications for acute and chronic low back pain: a review of the evidence for an American Pain Society/American College of Physicians clinical practice guideline. Ann Intern Med. Oct. 2. 2007;147(7):505-514. [pmid: 17909211].
16 Chou R, Huffman LH. Nonpharmacologic therapies for acute and chronic low back pain: a review of the evidence for an American Pain Society/American College of Physicians clinical practice guideline. Ann Intern Med. Oct. 2. 2007;147(7):492-504. [pmid: 17909210].
17 Chou R, Atlas SJ, Stanos SP, et al. Nonsurgical interventional therapies for low back pain: a review of the evidence for an American Pain Society clinical practice guideline. Spine (Phila Pa 1976). May. 1. 2009;34(10):1078-1093. [pmid: 19363456].
18 Chou R, Baisden J, Carragee EJ, et al. Surgery for low back pain: a review of the evidence for an American Pain Society Clinical Practice Guideline. Spine (Phila Pa 1976). May. 1. 2009;34(10):1094-1109. [pmid: 19363455].
19 Friedly J, Chan L, Deyo R. Increases in lumbosacral injections in the Medicare population: 1994 to 2001. Spine (Phila Pa 1976). Jul. 15. 2007;32(16):1754-1760. [pmid: 17632396].
20 Benoist M, Boulu P, Hayem G. Epidural steroid injections in the management of low-back pain with radiculopathy: an update of their efficacy and safety. Eur Spine J. Feb. 2012;21(2):204-213. [pmid: 21922288].
21 Quraishi NA. Transforaminal injection of corticosteroids for lumbar radiculopathy: systematic review and meta-analysis. Eur Spine J. Feb. 2012;21(2):214-219. [pmid: 21892774].
22 Staal JB, de Bie RA, de Vet HCW, et al. Injection therapy for subacute and chronic low back pain: an updated Cochrane review. Spine. Jan. 1. 2009;34(1):49-59. [pmid: 19127161].
23 Pinto RZ, Maher CG, Ferreira ML, et al. Epidural corticosteroid injections in the management of sciatica: a systematic review and meta-analysis. Ann Intern Med. Dec. 18. 2012;157(12):865-877. [pmid: 23362516].
24 Benyamin RM, Manchikanti L, Parr AT, et al. The effectiveness of lumbar interlaminar epidural injections in managing chronic low back and lower extremity pain. Pain Physician. Jul-Aug. 2012;15(4):E363-E404. [pmid: 22828691].
25 Manchikanti L, Buenaventura RM, Manchikanti KN, et al. Effectiveness of therapeutic lumbar transforaminal epidural steroid injections in managing lumbar spinal pain. Pain Physician. May-Jun. 2012;15(3):E199-E245. [pmid: 22622912].
26 Parr AT, Manchikanti L, Hameed H, et al. Caudal epidural injections in the management of chronic low back pain: a systematic appraisal of the literature. Pain Physician. May-Jun. 2012;15(3):E159-E198. [pmid: 22622911].
27 Niemisto L, Kalso E, Malmivaara A, et al. Radiofrequency denervation for neck and back pain: a systematic review within the framework of the cochrane collaboration back review group. Spine (Phila Pa 1976). Aug. 15. 2003;28(16):1877-1888. [pmid: 12923479].
28 Chou R, Loeser JD, Owens DK, et al. Interventional therapies, surgery, and interdisciplinary rehabilitation for low back pain: an evidence-based clinical practice guideline from the American Pain Society. Spine (Phila Pa 1976). May. 1. 2009;34(10):1066-1077. [pmid: 19363457].
29 Abrishamkar S, Karimi M, Safavi M, et al. Effects of intraoperative-intrathecal sufentanil injection on postoperative pain management after single level lumbar discectomy. Middle East Journal of Anesthesiology. Oct. 2010;20(6):839-844. [pmid: 21526670].
30 Airaksinen O, Brox JI, Cedraschi C, et al. Chapter 4. European guidelines for the management of chronic nonspecific low back pain. Eur Spine J. 2006:S192-S300. [pmid: 16550448].
31 Savigny P, Watson P, Underwood M. Early management of persistent non-specific low back pain: summary of NICE guidance. BMJ. 2009;338:b1805. [pmid: 19502217].
32 Resnick DK, Choudhri TF, Dailey AT, et al. Guidelines for the performance of fusion procedures for degenerative disease of the lumbar spine. Part 15: electrophysiological monitoring and lumbar fusion. J Neurosurg Spine. Jun. 2005;2(6):725-732. [pmid: 16028743].
33 Resnick DK, Choudhri TF, Dailey AT, et al. Guidelines for the performance of fusion procedures for degenerative disease of the lumbar spine. Part 13: injection therapies, low-back pain, and lumbar fusion. J Neurosurg Spine. Jun. 2005;2(6):707-715. [pmid: 16028741].
34 American Academy of Neurology. AAN Summary of Evidence-based Guideline for Clinicians: Use of Epidural Steroid Injections to Treat Radicular Lumbosacral Pain American Academy of Neurology. St. Paul, MN. 2007.
35 Bicket MC, Gupta A, Brown CHI, et al. Epidural injections for spinal pain: a systematic review and meta-analysis evaluating the"control" injections in randomized controlled trials. Anesthesiology. 2013;119(4):907-931. [pmid: 24195874].
36 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. Journal of Clinical Epidemiology. May. 2010;63(5):513-523. [pmid: 19595577].
37 Hashimoto, Raich, Ecker, et al. Health Technology Assessment: Spinal Injections. Washington State Health Care Authority. 2011.
38 Agency for Healthcare Research and Quality. Methods guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(13)-EHC063-EF. Rockville MD. 2013.
39 Furlan AD, Pennick V, Bombardier C, et al. 2009 updated method guidelines for systematic reviews in the Cochrane Back Review Group. Spine. Aug. 15. 2009;34(18):1929-1941. [pmid: 19680101].
40 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. 2008. Available at: http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.
41 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. Journal of Clinical Epidemiology. 2011;64(11):1198-1207. [pmid: 21463926].
42 Ostelo RW, Deyo RA, Stratford P, et al. Interpreting change scores for pain and functional status in low back pain: towards international consensus regarding minimal important change. Spine (Phila Pa 1976). Jan. 1. 2008;33(1):90-94. [pmid: 18165753].
43 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. Journal of Clinical Epidemiology. 2011;64(11):1187-1197. [pmid: 21477993].
44 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-560. [pmid: 12958120].
45 Cornell JE, Mulrow CD, Localio R, et al. Random-effects meta-analysis of inconsistent effects: a time for change. Annals of Internal Medicine. 2014;160(4):267-270. [pmid: 24727843].
46 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
47 Sayegh FE, Kenanidis EI, Papavasiliou KA, et al. Efficacy of steroid and nonsteroid caudal epidural injections for low back pain and sciatica: a prospective, randomized, double-blind clinical trial. Spine (Phila Pa 1976). Jun. 15. 2009;34(14):1441-1447. [pmid: 19525834].
48 Buchner M, Zeifang F, Brocai DR, et al. Epidural corticosteroid injection in the conservative management of sciatica. Clin Orthop Relat Res. Jun. 2000;(375):149-156. [pmid: 10853164].
49 Karppinen J, Malmivaara A, Kurunlahti M, et al. Periradicular infiltration for sciatica: a randomized controlled trial. Spine (Phila Pa 1976). May. 1. 2001;26(9):1059-1067. [pmid: 11337625].
50 Friedly JL, Comstock BA, Turner JA, et al. A randomized trial of epidural glucocorticoid injections for spinal stenosis. New Engl J Med. Jul. 3. 2014;371(1):11-21. [pmid: 24988555].
51 Carette S, Marcoux S, Truchon R, et al. A controlled trial of corticosteroid injections into facet joints for chronic low back pain. N Engl J Med. Oct. 3. 1991;325(14):1002-1007. [pmid: 1832209].
52 Civelek E, Cansever T, Kabatas S, et al. Comparison of effectiveness of facet joint injection and radiofrequency denervation in chronic low back pain. Turk Neurosurg. 2012;22(2):200-206. [pmid: 22437295].
53 Lakemeier S, Lind M, Schultz W, et al. A comparison of intraarticular lumbar facet joint steroid injections and lumbar facet joint radiofrequency denervation in the treatment of low back pain: a randomized, controlled, double-blind trial. Anesthesia & Analgesia. Jul. 2013;117(1):228-235. [pmid: 23632051].
54 Epstein NE. The risks of epidural and transforaminal steroid injections in the Spine: Commentary and a comprehensive review of the literature. Surg Neurol Int. 2013;4(Suppl 2):S74-S93. [pmid: 23646278].
55 Smith RM, Schaefer MK, Kainer MA, et al. Fungal infections associated with contaminated methylprednisolone injections. New Engl J Med. 2013;369(17):1598-1609. [pmid: 23252499].
56 Shamliyan TA, Staal JB, Goldmann D, et al. Epidural Steroid Injections for Radicular Lumbosacral Pain: A Systematic Review. Phys Med Rehabil Clin N Am. 2014;25(2):471-489.e50. [pmid: 24787344].
57 Choi HJ, Hahn S, Kim CH, et al. Epidural steroid injection therapy for low back pain: a meta-analysis. Int J Technol Assess Health Care. Jul. 2013;29(3):244-253. [pmid: 23769210].
58 Novak S, Nemeth WC. The basis for recommending repeating epidural steroid injections for radicular low back pain: a literature review. Archives of Physical Medicine & Rehabilitation. Mar. 2008;89(3):543-552. [pmid: 18295635].
59 Rabinovitch DL, Peliowski A, Furlan AD. Influence of lumbar epidural injection volume on pain relief for radicular leg pain and/or low back pain. Spine Journal: Official Journal of the North American Spine Society. Jun. 2009;9(6):509-517. [pmid: 19398387].
60 Carette S, Leclaire R, Marcoux S, et al. Epidural corticosteroid injections for sciatica due to herniated nucleus pulposus. N Engl J Med. Jun. 5. 1997;336(23):1634-1640. [pmid: 9171065].
61 Tafazal S, Ng L, Chaudhary N, et al. Corticosteroids in peri-radicular infiltration for radicular pain: a randomised double blind controlled trial. One year results and subgroup analysis. European Spine Journal. August. 1. 2009;18(8):1220-1225. [pmid: 19387704].
62 Edwards SJ, Clarke MJ, Wordsworth S, et al. Indirect comparisons of treatments based on systematic reviews of randomised controlled trials. Int J Clin Pract. 2009;63(6):841-854. [pmid: 19490195].
63 Staal JB, de Bie R, de Vet HC, et al. Injection therapy for subacute and chronic low-back pain. Cochrane Database of Systematic Reviews. 2008;(3):CD001824. [pmid: 18646078].
64 Henschke N, Kuijpers T, Rubinstein SM, et al. Injection therapy and denervation procedures for chronic low-back pain: a systematic review. European Spine Journal. Sep. 2010;19(9):1425-1449. [pmid: 20424870].
65 MacVicar J, King W, Landers MH, et al. The effectiveness of lumbar transforaminal injection of steroids: a comprehensive review with systematic analysis of the published data. Pain Medicine. Jan. 2013;14(1):14-28. [pmid: 23110347].
66 Roberts ST, Willick SE, Rho ME, et al. Efficacy of lumbosacral transforaminal epidural steroid injections: a systematic review. Pm & R. Jul. 2009;1(7):657-668. [pmid: 19627959].
67 Falco FJE, Manchikanti L, Datta S, et al. An update of the effectiveness of therapeutic lumbar facet joint interventions. Pain Physician. Nov-Dec. 2012;15(6):E909-E953. [pmid: 23159980].
68 Dworkin RH, Turk DC, Farrar JT, et al. Core outcome measures for chronic pain clinical trials: IMMPACT recommendations. Pain. 2005;113(1–2):9-19. [pmid: 15621359].
69 U.S. Food and Drug Administration. Slides for the November 24–25, 2014 Meeting of the Anesthetic and Analgesic Drug Products Advisory Committee (AADPAC). Accessed at: http://www.fda.gov/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/ucm425962.htm on February 13, 2015.
70 National Institute for Health and Care Excellence. Low back pain: Early management of persistent non-specific now back pain. 2009. 2010/08/13 ed.
71 Manchikanti L, Abdi S, Atluri S, et al. An update of comprehensive evidence-based guidelines for interventional techniques in chronic spinal pain. Part II: guidance and recommendations. Pain Physician. Apr. 2013;16(2 Suppl):S49-S283. [pmid: 23615883].
72 Song F, Loke YK, Walsh T, et al. Methodological problems in the use of indirect comparisons for evaluating healthcare interventions: survey of published systematic reviews. BMJ. 2009. 2009-04-03 11:14:19;338;b1147. [doi: 10.1136/bmj.b1147]. [pmid: 19346285].
73 Cohen SP, Williams KA, Kurihara C, et al. Multicenter, randomized, comparative cost-effectiveness study comparing 0, 1, and 2 diagnostic medial branch (facet joint nerve) block treatment paradigms before lumbar facet radiofrequency denervation. Anesthesiology. Aug. 2010;113(2):395-405. [pmid: 20613471].