# Peer Reviewers

Prior to publication of the final evidence report, the EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Charles Argoff, M.D.
  Professor of Neurology, Albany Medical College
  Director, Comprehensive Pain Center, Albany Medical Center
  Albany, NY
- Steven Cohen, M.D.
  Professor, Departments of Anesthesiology & Critical Care Medicine & Physical Medicine & Rehabilitation
  Director, Blaustein Pain Treatment Center
  Johns Hopkins School of Medicine
  Baltimore, MD
  Professor, Department of Anesthesiology & Physical Medicine & Rehabilitation
  Uniformed Services University of the Health Sciences
  Bethesda, MD
- Gilbert Fanciullo, M.D., M.S.
  Director, Section of Pain Medicine
  Dartmouth Hitchcock Medical Center
  Professor, Geisel School of Medicine at Dartmouth
  Hanover, NH
- Gary Franklin, M.D., M.P.H.
  Medical Director, Washington State Department of Labor and Industries
  Chair, Washington Agency Medical Director’s Group
  Research Professor, Departments of Environmental and Occupational Health Sciences,
  Neurology, and Health Services, University of Washington
  Seattle, Washington
- Martin Grabois, M.D.
  Professor for Physical Medicine and Rehabilitation
  Baylor College Medical Center
  Houston, TX
- Erin E. Krebs, M.D., M.P.H.
  Women's Health Medical Director, Minneapolis VA Health Care System; Associate Professor, Department of Medicine, University of Minnesota, Minneapolis, MN
- Timothy Maus, M.D.
  Associate Professor of Radiology
  Mayo Clinic
  Rochester, Minnesota, USA
- Mark Wallace, M.D.
  Chair, Division of Pain Medicine; Professor of Clinical Anesthesiology
  University of California, San Diego
  San Diego, CA