# Technical Expert Panel

In place of a Technical Expert Panel, CMS provided input to the Key Questions and scope of the report.