# Key Informants

In designing the study questions, the Evidence-based Practice Center (EPC) consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Charles Argoff, M.D.
  Professor of Neurology, Albany Medical College
  Director, Comprehensive Pain Center, Albany Medical Center
  Albany, NY
- John Carrino, M.D., M.P.H.
  Associate Professor, Russell H. Morgan Department of Radiology and Radiological Science ; Associate Professor, Department of Orthopaedic Surgery, Johns Hopkins University School of Medicine
  Section Chief, Musculoskeletal Radiology, Johns Hopkins Hospital
  Baltimore, M.D.
- Steven Cohen, M.D.
  Professor, Departments of Anesthesiology & Critical Care Medicine & Physical Medicine & Rehabilitation
  Director, Blaustein Pain Treatment Center
  Johns Hopkins School of Medicine
  Baltimore, MD
  Professor, Department of Anesthesiology & Physical Medicine & Rehabilitation
  Uniformed Services University of the Health Sciences
  Bethesda, MD
- Penney Cowan
  Executive Director, American Chronic Pain Association
  Rocklin, CA
- Richard Deyo, M.D., M.P.H.
  Professor, Family Medicine, Department of Medicine, Department of Public Health and Preventive Medicine, Center for Research in Occupational and Environmental Toxicology/School of Medicine, Oregon Health and Science University
  Portland, OR
- Gary Franklin, M.D., M.P.H.
  Medical Director, Washington State Department of Labor and Industries
  Chair, Washington Agency Medical Director’s Group
  Research Professor, Departments of Environmental and Occupational Health Sciences,
  Neurology, and Health Services, University of Washington
  Seattle, Washington
- Mary Scott, B.A.
  Patient Representative
  Thorp, WA
- Steven Stanos, D.O.
  Associate Professor, Department of Physical Medicine and Rehabilitation; Assistant Program Director, Multidisciplinary Pain Fellowship
  Northwestern University Medical School, Feinberg School of Medicine
  Chicago, IL