# Abbreviations

AAOS: American Academy of Orthopedic Surgeons Scale
AHRQ: Agency for Healthcare Research and Quality
ANCOVA: Analysis of covariance
APS: American Pain Society
CI: Confidence interval
CMS: Centers for Medicare and Medicaid Services
CT: Computerized tomography
EPC: Evidence-based Practice Center
I^2^: Heterogeneity estimate
L5-S1: The lumbosacral joint and the L5-S1 spine segment
MCMI-II: Millon Clinical Multiaxial Inventory-II
MED: Medical
MILD: Minimally invasive lumbar decompression
MRI: Magnetic resonance imaging
NASS: North American Spine Society
NRS: Numeric rating scale
ODI: Oswestry Disability Index
OR: Odds ratio
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing and Setting
RDQ: Roland Morris Disability Questionnaire
RR: Relative risk
S1: Lumbosacral joint severe back pain
SF-36: Short Form- 36 (Medical Outcomes Study)
SIP: Scientific information packet
SMD: Standardized mean difference
SOE: Strength of evidence
SPECT: Single photon electronic computed tomography
TENS: Transcutaneous electrical nerve stimulation
TEP: Technical Expert Panel
USPSTF: United States Preventive Services Task Force
VAS: Visual Analog Scale
WMD: Weighted mean difference