# References

1 Deyo RA, Mirza SK, Martin BI. Back pain prevalence and visit rates: estimates from U.S. national surveys, 2002. Spine (Phila Pa 1976). Nov. 1. 2006;31(23):2724-2727. [pmid: 17077742].
2 Walker BF. The prevalence of low back pain: a systematic review of the literature from 1966 to 1998. J Spinal Disord. Jun. 2000;13(3):205-217. [pmid: 10872758].
3 Freburger JK, Holmes GM, Agans RP, et al. The rising prevalence of chronic low back pain. Arch Intern Med. Feb. 9. 2009;169(3):251-258. [pmid: 19204216].
4 Luo X, Pietrobon R, Sun SX, et al. Estimates and patterns of direct health care expenditures among individuals with back pain in the United States. Spine (Phila Pa 1976). Jan. 1. 2004;29(1):79-86. [pmid: 14699281].
5 Martin BI, Deyo RA, Mirza SK, et al. Expenditures and health status among adults with back and neck problems. JAMA. Feb. 13. 2008;299(6):656-664. [pmid: 18270354].
6 Stewart WF, Ricci JA, Chee E, et al. Lost productive time and cost due to common pain conditions in the US workforce. JAMA. Nov. 12. 2003;290(18):2443-2454. [pmid: 14612481].
7 Pengel LH, Herbert RD, Maher CG, et al. Acute low back pain: systematic review of its prognosis. BMJ. Aug. 9. 2003;327(7410):323. [pmid: 12907487].
8 Chou R, Shekelle P. Will this patient develop persistent disabling low back pain?. JAMA. Apr. 7. 2010;303(13):1295-1302. [pmid: 20371789].
9 Frymoyer JW, Cats-Baril W. Predictors of low back pain disability. Clin Orthop Relat Res. Aug. 1987;221:89-98. [pmid: 2955993].
10 Engel CC, von Korff M, Katon WJ. Back pain in primary care: predictors of high health-care costs. Pain. May-Jun. 1996;5(2–3):197-204. [pmid: 8826507].
11 Chou R, Qaseem A, Owens DK, et al. Diagnostic imaging for low back pain: advice for high-value health care from the American College of Physicians. Ann Intern Med. 2011;154(3):181-189. [pmid: 21282698].
12 van Tulder MW, Assendelft WJ, Koes BW, et al. Spinal radiographic findings and nonspecific low back pain. A systematic review of observational studies. Spine (Phila Pa 1976). Feb. 15. 1997;22(4):427-434. [pmid: 9055372].
13 Chou R, Qaseem A, Snow V, et al. Diagnosis and treatment of low back pain: a joint clinical practice guideline from the American College of Physicians and the American Pain Society.[Erratum appears in Ann Intern Med. 2008 Feb 5;148(3)247-8; PMID: 18257154], [Summary for patients in Ann Intern Med. 2007 Oct 2;147(7):I45; PMID: 17909203]. Annals of Internal Medicine. Oct. 2. 2007;147(7):478-491. [pmid: 17909209].
14 Chou R, Shekelle P, Qaseem A, et al. Correction: Diagnosis and treatment of low back pain. Ann Intern Med. Feb. 5. 2008;148(3):247-248. [pmid: 18257154].
15 Chou R, Huffman LH. Medications for acute and chronic low back pain: a review of the evidence for an American Pain Society/American College of Physicians clinical practice guideline. Ann Intern Med. Oct. 2. 2007;147(7):505-514. [pmid: 17909211].
16 Chou R, Huffman LH. Nonpharmacologic therapies for acute and chronic low back pain: a review of the evidence for an American Pain Society/American College of Physicians clinical practice guideline. Ann Intern Med. Oct. 2. 2007;147(7):492-504. [pmid: 17909210].
17 Chou R, Atlas SJ, Stanos SP, et al. Nonsurgical interventional therapies for low back pain: a review of the evidence for an American Pain Society clinical practice guideline. Spine (Phila Pa 1976). May. 1. 2009;34(10):1078-1093. [pmid: 19363456].
18 Chou R, Baisden J, Carragee EJ, et al. Surgery for low back pain: a review of the evidence for an American Pain Society Clinical Practice Guideline. Spine (Phila Pa 1976). May. 1. 2009;34(10):1094-1109. [pmid: 19363455].
19 Friedly J, Chan L, Deyo R. Increases in lumbosacral injections in the Medicare population: 1994 to 2001. Spine (Phila Pa 1976). Jul. 15. 2007;32(16):1754-1760. [pmid: 17632396].
20 Benoist M, Boulu P, Hayem G. Epidural steroid injections in the management of low-back pain with radiculopathy: an update of their efficacy and safety. Eur Spine J. Feb. 2012;21(2):204-213. [pmid: 21922288].
21 Quraishi NA. Transforaminal injection of corticosteroids for lumbar radiculopathy: systematic review and meta-analysis. Eur Spine J. Feb. 2012;21(2):214-219. [pmid: 21892774].
22 Staal JB, de Bie RA, de Vet HCW, et al. Injection therapy for subacute and chronic low back pain: an updated Cochrane review. Spine. Jan. 1. 2009;34(1):49-59. [pmid: 19127161].
23 Pinto RZ, Maher CG, Ferreira ML, et al. Epidural corticosteroid injections in the management of sciatica: a systematic review and meta-analysis. Ann Intern Med. Dec. 18. 2012;157(12):865-877. [pmid: 23362516].
24 Benyamin RM, Manchikanti L, Parr AT, et al. The effectiveness of lumbar interlaminar epidural injections in managing chronic low back and lower extremity pain. Pain Physician. Jul-Aug. 2012;15(4):E363-E404. [pmid: 22828691].
25 Manchikanti L, Buenaventura RM, Manchikanti KN, et al. Effectiveness of therapeutic lumbar transforaminal epidural steroid injections in managing lumbar spinal pain. Pain Physician. May-Jun. 2012;15(3):E199-E245. [pmid: 22622912].
26 Parr AT, Manchikanti L, Hameed H, et al. Caudal epidural injections in the management of chronic low back pain: a systematic appraisal of the literature. Pain Physician. May-Jun. 2012;15(3):E159-E198. [pmid: 22622911].
27 Niemisto L, Kalso E, Malmivaara A, et al. Radiofrequency denervation for neck and back pain: a systematic review within the framework of the cochrane collaboration back review group. Spine (Phila Pa 1976). Aug. 15. 2003;28(16):1877-1888. [pmid: 12923479].
28 Chou R, Loeser JD, Owens DK, et al. Interventional therapies, surgery, and interdisciplinary rehabilitation for low back pain: an evidence-based clinical practice guideline from the American Pain Society. Spine (Phila Pa 1976). May. 1. 2009;34(10):1066-1077. [pmid: 19363457].
29 Abrishamkar S, Karimi M, Safavi M, et al. Effects of intraoperative-intrathecal sufentanil injection on postoperative pain management after single level lumbar discectomy. Middle East Journal of Anesthesiology. Oct. 2010;20(6):839-844. [pmid: 21526670].
30 Airaksinen O, Brox JI, Cedraschi C, et al. Chapter 4. European guidelines for the management of chronic nonspecific low back pain. Eur Spine J. 2006:S192-S300. [pmid: 16550448].
31 Savigny P, Watson P, Underwood M. Early management of persistent non-specific low back pain: summary of NICE guidance. BMJ. 2009;338:b1805. [pmid: 19502217].
32 Resnick DK, Choudhri TF, Dailey AT, et al. Guidelines for the performance of fusion procedures for degenerative disease of the lumbar spine. Part 15: electrophysiological monitoring and lumbar fusion. J Neurosurg Spine. Jun. 2005;2(6):725-732. [pmid: 16028743].
33 Resnick DK, Choudhri TF, Dailey AT, et al. Guidelines for the performance of fusion procedures for degenerative disease of the lumbar spine. Part 13: injection therapies, low-back pain, and lumbar fusion. J Neurosurg Spine. Jun. 2005;2(6):707-715. [pmid: 16028741].
34 American Academy of Neurology. AAN Summary of Evidence-based Guideline for Clinicians: Use of Epidural Steroid Injections to Treat Radicular Lumbosacral Pain American Academy of Neurology. St. Paul, MN. 2007.
35 Bicket MC, Gupta A, Brown CHI, et al. Epidural injections for spinal pain: a systematic review and meta-analysis evaluating the"control" injections in randomized controlled trials. Anesthesiology. 2013;119(4):907-931. [pmid: 24195874].
36 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. Journal of Clinical Epidemiology. May. 2010;63(5):513-523. [pmid: 19595577].
37 Hashimoto, Raich, Ecker, et al. Health Technology Assessment: Spinal Injections. Washington State Health Care Authority. 2011.
38 Agency for Healthcare Research and Quality. Methods guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(13)-EHC063-EF. Rockville MD. 2013.
39 Furlan AD, Pennick V, Bombardier C, et al. 2009 updated method guidelines for systematic reviews in the Cochrane Back Review Group. Spine. Aug. 15. 2009;34(18):1929-1941. [pmid: 19680101].
40 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. 2008. Available at: http://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual.
41 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. Journal of Clinical Epidemiology. 2011;64(11):1198-1207. [pmid: 21463926].
42 Ostelo RW, Deyo RA, Stratford P, et al. Interpreting change scores for pain and functional status in low back pain: towards international consensus regarding minimal important change. Spine (Phila Pa 1976). Jan. 1. 2008;33(1):90-94. [pmid: 18165753].
43 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. Journal of Clinical Epidemiology. 2011;64(11):1187-1197. [pmid: 21477993].
44 Deyo RA, Battie M, Beurskens AJ, et al. Outcome measures for low back pain research. A proposal for standardized use. Spine (Phila Pa 1976). Sep. 15. 1998;23(18):2003-2013. [pmid: 9779535].
45 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-560. [pmid: 12958120].
46 Cornell JE, Mulrow CD, Localio R, et al. Random-effects meta-analysis of inconsistent effects: a time for change. Annals of Internal Medicine. 2014;160(4):267-270. [pmid: 24727843].
47 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
48 Ackerman WE 3rd, Ahmad M. The efficacy of lumbar epidural steroid injections in patients with lumbar disc herniations. Anesth Analg. May. 2007;104(5):1217-1222. tables of contents. [pmid: 17456677].
49 Ahadian FM, McGreevy K, Schulteis G. Lumbar transforaminal epidural dexamethasone: a prospective, randomized, double-blind, dose-response trial. Regional Anesthesia & Pain Medicine. Nov-Dec. 2011;36(6):572-578. [pmid: 22005659].
50 Arden NK, Price C, Reading I, et al. A multicentre randomized controlled trial of epidural corticosteroid injections for sciatica: the WEST study. Rheumatology. Nov. 2005;44(11):1399-1406. [pmid: 16030082].
51 Price C, Arden N, Coglan L, et al. Cost-effectiveness and safety of epidural steroids in the management of sciatica. Health Technol Assess. Aug. 2005;9(33):1-58. iii. [pmid: 16095548].
52 Aronsohn J, Chapman K, Soliman M, et al. Percutaneous microdiscectomy versus epidural injection for management of chronic spinal pain. Proceedings of the Western Pharmacology Society. 2010;53:16-19. [pmid: 22128444].
53 Becker C, Heidersdorf S, Drewlo S, et al. Efficacy of epidural perineural injections with autologous conditioned serum for lumbar radicular compression: an investigator-initiated, prospective, double-blind, reference-controlled study. Spine (Phila Pa 1976). Aug. 1. 2007;32(17):1803-1808. [pmid: 17762286].
54 Beliveau P. A comparison between epidural anaesthesia with and without corticosteroid in the treatment of sciatica. Rheumatol Phys Med. Feb. 1971;11(1):40-43. [pmid: 5551095].
55 Breivik H, Hesla P, Molnar I, et al. Treatment of chronic low back pain and sciatica. Comparison of caudal epidural injections of bupivacaine and methylprednisolone with bupivacaine followed by saline. Adv Pain Res Ther. 1976;1:927-932.
56 Buchner M, Zeifang F, Brocai DR, et al. Epidural corticosteroid injection in the conservative management of sciatica. Clin Orthop Relat Res. Jun. 2000;(375):149-156. [pmid: 10853164].
57 Burgher AH, Hoelzer BC, Schroeder DR, et al. Transforaminal epidural clonidine versus corticosteroid for acute lumbosacral radiculopathy due to intervertebral disc herniation. Spine. Mar. 1. 2011;36(5):E293-E300. [pmid: 21192304].
58 Bush K, Hillier S. A controlled study of caudal epidural injections of triamcinolone plus procaine for the management of intractable sciatica. Spine (Phila Pa 1976). May. 1991;16(5):572-575. [pmid: 2053000].
59 Buttermann GR. Treatment of lumbar disc herniation: epidural steroid injection compared with discectomy. A prospective, randomized study. J Bone Joint Surg Am. Apr. 2004;86-A(4):670-679. [pmid: 15069129].
60 Candido KD, Rana MV, Sauer R, et al. Concordant pressure paresthesia during interlaminar lumbar epidural steroid injections correlates with pain relief in patients with unilateral radicular pain. Pain Physician. 2013;16(5):497-511. [pmid: 24077196].
61 Candido KD, Raghavendra MS, Chinthagada M, et al. A prospective evaluation of iodinated contrast flow patterns with fluoroscopically guided lumbar epidural steroid injections: the lateral parasagittal interlaminar epidural approach versus the transforaminal epidural approach. Anesthesia & Analgesia. 2008 of contents. Feb. 2008;106(2):638-644. [pmid: 18227326].
62 Carette S, Leclaire R, Marcoux S, et al. Epidural corticosteroid injections for sciatica due to herniated nucleus pulposus. N Engl J Med. Jun. 5. 1997;336(23):1634-1640. [pmid: 9171065].
63 Cocelli LP, Karakurum G, Cebesoy O, et al. Clinical comparison of effectiveness of epidural triamcinolone and betamethasone in discal radiculalgia: a prospective, randomized study. Journal of Musculoskeletal Pain. 2009;17(3):281-286.
64 Cohen SP, White RL, Kurihara C, et al. Epidural steroids, etanercept, or saline in subacute sciatica: a multicenter, randomized trial. Annals of Internal Medicine. Apr. 17. 2012;156(8):551-559. [pmid: 22508732].
65 Cohen SP, Gupta A, Strassels SA, et al. Effect of MRI on treatment results or decision making in patients with lumbosacral radiculopathy referred for epidural steroid injections: a multicenter, randomized controlled trial. Archives of Internal Medicine. Jan. 23. 2012;172(2):134-142. [pmid: 22157067].
66 Cuckler JM, Bernini PA, Wiesel SW, et al. The use of epidural steroids in the treatment of lumbar radicular pain. A prospective, randomized, double-blind study. J Bone Joint Surg Am. Jan. 1985;67(1):63-66. [pmid: 3155742].
67 Dashfield AK, Taylor MB, Cleaver JS, et al. Comparison of caudal steroid epidural with targeted steroid placement during spinal endoscopy for chronic sciatica: a prospective, randomized, double-blind trial. Br J Anaesth. Apr. 2005;94(4):514-519. [pmid: 15695544].
68 Datta R, Upadhyay KK. A randomized clinical trial of three different steroid agents for treatment of low backache through the caudal route. Med J Armed Forces India. 2011;67(1):25-33.
69 Dilke TF, Burry HC, Grahame R. Extradural corticosteroid injection in management of lumbar nerve root compression. Br Med J. Jun. 16. 1973;2(5867):635-637. [pmid: 4577015].
70 Gerszten PC, Smuck M, Rathmell JP, et al. Plasma disc decompression compared with fluoroscopy-guided transforaminal epidural steroid injections for symptomatic contained lumbar disc herniation: a prospective, randomized, controlled trial. Journal of Neurosurgery Spine. Apr. 2010;12(4):357-371. [pmid: 20201654].
71 Ghahreman A, Ferch R, Bogduk N. The efficacy of transforaminal injection of steroids for the treatment of lumbar radicular pain. Pain Medicine. Aug. 2010;11(8):1149-1168. [pmid: 20704666].
72 Ghahreman A, Bogduk N. Predictors of a favorable response to transforaminal injection of steroids in patients with lumbar radicular pain due to disc herniation. Pain Medicine. Jun. 2011;12(6):871-879. [pmid: 21539702].
73 Ghai B, Bansal D, Kay JP, et al. Transforaminal versus parasagittal interlaminar epidural steroid injection in low back pain with radicular pain: A randomized, double-blind, active-control trial. Pain Physician. 2014;17(4):277-290. [pmid: 25054387].
74 Ghai B, Vadaje KS, Wig J, et al. Lateral parasagittal versus midline interlaminar lumbar epidural steroid injection for management of low back pain with lumbosacral radicular pain: a double-blind, randomized study. Anesthesia & Analgesia. Jul. 2013;117(1):219-227. [pmid: 23632053].
75 Gharibo CG, Varlotta GP, Rhame EE, et al. Interlaminar versus transforaminal epidural steroids for the treatment of subacute lumbar radicular pain: a randomized, blinded, prospective outcome study. Pain Physician. Nov-Dec. 2011;14(6):499-511. [pmid: 22086091].
76 Helliwell M, Robertson J, Ellis R. Outpatient treatment of low-back pain and sciatica by a single extradural corticosteroid injection. British Journal of Clinical Practice. 1985;39(6):228-231.
77 Habib G, Jabbour A, Salman J, et al. The effect of epidural methylprednisolone acetate injection on the hypothalamic-pituitary-adrenal axis. Journal of Clinical Anesthesia. Dec. 2013;25(8):629-633. [pmid: 23988802].
78 Iversen T, Solberg TK, Romner B, et al. Effect of caudal epidural steroid or saline injection in chronic lumbar radiculopathy: multicentre, blinded, randomised controlled trial. BMJ. 2011;343:d5278. [pmid: 21914755].
79 Jeong HS, Lee JW, Kim SH, et al. Effectiveness of transforaminal epidural steroid injection by using a preganglionic approach: a prospective randomized controlled study. Radiology. Nov. 2007;245(2):584-590. [pmid: 17940309].
80 Kang S-S, Hwang B-M, Son H-J, et al. The dosages of corticosteroid in transforaminal epidural steroid injections for lumbar radicular pain due to a herniated disc. Pain Physician. Jul-Aug. 2011;14(4):361-370. [pmid: 21785479].
81 Karppinen J, Malmivaara A, Kurunlahti M, et al. Periradicular infiltration for sciatica: a randomized controlled trial. Spine (Phila Pa 1976). May. 1. 2001;26(9):1059-1067. [pmid: 11337625].
82 Karppinen J, Ohinmaa A, Malmivaara A, et al. Cost effectiveness of periradicular infiltration for sciatica: subgroup analysis of a randomized controlled trial. Spine (Phila Pa 1976). Dec. 1. 2001;26(23):2587-2595. [pmid: 11725240].
83 Kennedy DJ, Plastaras C, Casey E, et al. Comparative effectiveness of lumbar transforaminal epidural steroid injections with particulate versus nonparticulate corticosteroids for lumbar radicular pain due to intervertebral disc herniation: a prospective, randomized, double-blind trial. Pain Medicine. Apr. 2014;15(4):548-555. [pmid: 24393129].
84 Kim D, Brown J. Efficacy and safety of lumbar epidural dexamethasone versus methylprednisolone in the treatment of lumbar radiculopathy: a comparison of soluble versus particulate steroids. Clinical Journal of Pain. Jul-Aug. 2011;27(6):518-522. [pmid: 21562412].
85 Klenerman L, Greenwood R, Davenport HT, et al. Lumbar epidural injections in the treatment of sciatica. Br J Rheumatol. Feb. 1984;23(1):35-38. [pmid: 6697071].
86 Koh WU, Choi SS, Park SY, et al. Transforaminal hypertonic saline for the treatment of lumbar lateral canal stenosis: a double-blinded, randomized, active-control trial. Pain Physician. May-Jun. 2013;16(3):197-211. [pmid: 23703407].
87 Kolsi I, Delecrin J, Berthelot JM, et al. Efficacy of nerve root versus interspinous injections of glucocorticoids in the treatment of disk-related sciatica. A pilot, prospective, randomized, double-blind study. Joint Bone Spine. 2000;67(2):113-118. [pmid: 10769103].
88 Kraemer J, Ludwig J, Bickert U, et al. Lumbar epidural perineural injection: a new technique. Eur Spine J. 1997;6(5):357-361. [pmid: 9391811].
89 Laiq N, Khan MN, Iqbal MJ, et al. Comparison of Epidural Steroid Injections with conservative management in patients with lumbar radiculopathy. Jcpsp, Journal of the College of Physicians & Surgeons - Pakistan. Sep. 2009;19(9):539-543. [pmid: 19728936].
90 Manchikanti L, Singh V, Cash KA, et al. A randomized, double-blind, active-control trial of the effectiveness of lumbar interlaminar epidural injections in disc herniation. Pain Physician. Jan-Feb. 2014;17(1):E61-E74. [pmid: 24452658].
91 Manchikanti L, Singh V, Cash KA, et al. The role of fluoroscopic interlaminar epidural injections in managing chronic pain of lumbar disc herniation or radiculitis: a randomized, double-blind trial. Pain Practice. Sep. 2013;13(7):547-558. [pmid: 23279452].
92 Manchikanti L, Singh V, Falco FJ, et al. Evaluation of the effectiveness of lumbar interlaminar epidural injections in managing chronic pain of lumbar disc herniation or radiculitis: a randomized, double-blind, controlled trial. Pain Physician. Jul-Aug. 2010;13(4):343-355. [pmid: 20648203].
93 Manchikanti L, Singh V, Cash KA, et al. Effect of fluoroscopically guided caudal epidural steroid or local anesthetic injections in the treatment of lumbar disc herniation and radiculitis: a randomized, controlled, double blind trial with a two-year follow-up. Pain Physician. Jul-Aug. 2012;15(4):273-286. [pmid: 22828681].
94 Manchikanti L, Singh V, Cash KA, et al. A randomized, controlled, double-blind trial of fluoroscopic caudal epidural injections in the treatment of lumbar disc herniation and radiculitis. Spine. Nov. 1. 2011;36(23):1897-1905. [pmid: 21897343].
95 Manchikanti L, Singh V, Cash KA, et al. Preliminary results of a randomized, equivalence trial of fluoroscopic caudal epidural injections in managing chronic low back pain: Part 2--Disc herniation and radiculitis. Pain Physician. Nov-Dec. 2008;11(6):801-815. [pmid: 19057627].
96 Matthews JA, Mills SB, Jenkins VM, et al. Back Pain and Sciatica: Controlled Trials of Manipulation, Traction, Sclerosant, and Epidural Injections. Br J Rheumatol. 1987;26(6):16-23. [pmid: 2961394].
97 McCahon RA, Ravenscroft A, Hodgkinson V, et al. A pilot study of the dose-response of caudal methylprednisolone with levobupivacaine in chronic lower back pain. Anaesthesia. Jul. 2011;66(7):595-603. [pmid: 21564047].
98 Murakibhavi VG, Khemka AG. Caudal epidural steroid injection: a randomized controlled trial. Evid Based Spine Care J. Nov. 2011;2(4):19-26. [pmid: 23230402].
99 Owlia MB, Salimzadeh A, Alishiri G, et al. Comparison of two doses of corticosteroid in epidural steroid injection for lumbar radicular pain. Singapore Medical Journal. Mar. 2007;48(3):241-245. [pmid: 17342295].
100 Park CH, Lee SH, Kim BI. Comparison of the effectiveness of lumbar transforaminal epidural injection with particulate and nonparticulate corticosteroids in lumbar radiating pain. Pain Medicine. Nov. 2010;11(11):1654-1658. [pmid: 20807343].
101 Park Y, Lee J-H, Park KD, et al. Ultrasound-guided vs. fluoroscopy-guided caudal epidural steroid injection for the treatment of unilateral lower lumbar radicular pain: a prospective, randomized, single-blind clinical study. American Journal of Physical Medicine & Rehabilitation. Jul. 2013;92(7):575-586. [pmid: 23636087].
102 Rados I, Sakic K, Fingler M, et al. Efficacy of interlaminar vs transforaminal epidural steroid injection for the treatment of chronic unilateral radicular pain: prospective, randomized study. Pain Medicine. Sep. 2011;12(9):1316-1321. [pmid: 21914118].
103 Ridley M, Kingsley G, Gibson T, et al. Outpatient lumbar epidural corticosteroid injection in the management of sciatica. Rheumatology. August. 1. 1988;27(4):295-299. [pmid: 3408828].
104 Riew KD, Yin Y, Gilula L, et al. The effect of nerve-root injections on the need for operative treatment of lumbar radicular pain. A prospective, randomized, controlled, double-blind study. J Bone Joint Surg Am. Nov. 2000;82-A(11):1589-1593. [pmid: 11097449].
105 Riew KD, Park JB, Cho YS, et al. Nerve root blocks in the treatment of lumbar radicular pain. A minimum five-year follow-up. J Bone Joint Surg Am. Aug. 2006;88(8):1722-1725. [pmid: 16882893].
106 Rogers P, Nash T, Schiller D, et al. Epidural steroids for sciatica. Pain Clinic. 1992;5:67-72.
107 Sayegh FE, Kenanidis EI, Papavasiliou KA, et al. Efficacy of steroid and nonsteroid caudal epidural injections for low back pain and sciatica: a prospective, randomized, double-blind clinical trial. Spine (Phila Pa 1976). Jun. 15. 2009;34(14):1441-1447. [pmid: 19525834].
108 Snoek W, Weber H, Jorgensen B. Double blind evaluation of extradural methyl prednisolone for herniated lumbar discs. Acta Orthop Scand. 1977;48(6):635-641. [pmid: 343479].
109 Tafazal S, Ng L, Chaudhary N, et al. Corticosteroids in peri-radicular infiltration for radicular pain: a randomised double blind controlled trial. One year results and subgroup analysis. European Spine Journal. August. 1. 2009;18(8):1220-1225. [pmid: 19387704].
110 Ng L, Chaudhary N, Sell P. The efficacy of corticosteroids in periradicular infiltration for chronic radicular pain: a randomized, double-blind, controlled trial. Spine (Phila Pa 1976). Apr. 15. 2005;30(8):857-862. [pmid: 15834326].
111 Tauheed N, Usmani H, Siddiqui AH. A comparison of the analgesic efficacy of transforaminal methylprednisolone alone and with low doses of clonidine in lumbo-sacral radiculopathy. Saudi journal of anaesthesia. Jan. 2014;8(1):51-58. [pmid: 24665240].
112 Thomas E, Cyteval C, Abiad L, et al. Efficacy of transforaminal versus interspinous corticosteroid injectionin discal radiculalgia - a prospective, randomised, double-blind study. Clin Rheumatol. Oct. 2003;22(4–5):299-304. [pmid: 14579160].
113 Valat JP, Giraudeau B, Rozenberg S, et al. Epidural corticosteroid injections for sciatica: a randomised, double blind, controlled clinical trial. Ann Rheum Dis. Jul. 2003;62(7):639-643. [pmid: 12810426].
114 Wilson-MacDonald J, Burt G, Griffin D, et al. Epidural steroid injection for nerve root compression. A randomised, controlled trial. J Bone Joint Surg Br. Mar. 2005;87(3):352-355. [pmid: 15773645].
115 el Zahaar MS. The value of caudal epidural steroids in the treatment of lumbar neural compression syndromes. J Neurol Orthop Med Surg. 1991;12:181-184.
116 Brown LL. A double-blind, randomized, prospective study of epidural steroid injection vs. the mild procedure in patients with symptomatic lumbar spinal stenosis. Pain Practice. Jun. 2012;12(5):333-341. [pmid: 22272730].
117 Friedly JL, Comstock BA, Turner JA, et al. A randomized trial of epidural glucocorticoid injections for spinal stenosis. New Engl J Med. Jul. 3. 2014;371(1):11-21. [pmid: 24988555].
118 Fukusaki M, Kobayashi I, Hara T, et al. Symptoms of spinal stenosis do not improve after epidural steroid injection. Clin J Pain. Jun. 1998;14(2):148-151. [pmid: 9647457].
119 Huda N, Bansal P, Gupta SM, et al. The efficacy of epidural depo-methylprednisolone and triamcinolone acetate in relieving the symptoms of lumbar anal stenosis: a comparative study. J Clin and Diag Res. 2010;4:2843-2847.
120 Koc Z, Ozcakir S, Sivrioglu K, et al. Effectiveness of physical therapy and epidural steroid injections in lumbar spinal stenosis. Spine (Phila Pa 1976). May. 1. 2009;34(10):985-989. [pmid: 19404172].
121 Manchikanti KN, Cash KA, McManus CD, et al. The preliminary results of a comparative effectivenesss evaluation of adhesiolysis and caudal epidural injections in managing chronic low back pain secondary to spinal stenosis: a randomized, equivalence controlled trial. Pain Physician. 2009;12:E341-E54. [pmid: 19935991].
122 Manchikanti L, Cash KA, McManus CD, et al. Lumbar interlaminar epidural injections in central spinal stenosis: preliminary results of a randomized, double-blind, active control trial. Pain Physician. Jan-Feb. 2012;15(1):51-63. [pmid: 22270738].
123 Manchikanti L, Cash KA, McManus CD, et al. Results of 2-year follow-up of a randomized, double-blind, controlled trial of fluoroscopic caudal epidural injections in central spinal stenosis. Pain Physician. Sep-Oct. 2012;15(5):371-384. [pmid: 22996849].
124 Manchikanti L, Cash KA, McManus CD, et al. Fluoroscopic caudal epidural injections with or without steroids in managing pain of lumbar spinal stenosis: one-year results of randomized, double-blind, active-controlled trial. Journal of Spinal Disorders & Techniques. Jun. 2012;25(4):226-234. [pmid: 22652990].
125 Manchikanti L, Cash KA, McManus CD, et al. Preliminary results of a randomized, equivalence trial of fluoroscopic caudal epidural injections in managing chronic low back pain: Part 4--Spinal stenosis. Pain Physician. Nov-Dec. 2008;11(6):833-848. [pmid: 19057629].
126 Nam HS, Park YB. Effects of transforaminal injection for degenerative lumbar scoliosis combined with spinal stenosis. Ann Rehabil Med. Aug. 2011;35(4):514-523. [pmid: 22506167].
127 Ohtori S, Miyagi M, Eguchi Y, et al. Epidural administration of spinal nerves with the tumor necrosis factor-alpha inhibitor, etanercept, compared with dexamethasone for treatment of sciatica in patients with lumbar spinal stenosis: a prospective randomized study. Spine. Mar. 15. 2012;37(6):439-444. [pmid: 22020607].
128 Lee JH, An JH, Lee SH. Comparison of the effectiveness of interlaminar and bilateral transforaminal epidural steroid injections in treatment of patients with lumbosacral disc herniation and spinal stenosis. Clin J Pain. 2009;25(3):206-210. [pmid: 19333170].
129 Manchikanti L, Cash KA, McManus CD, et al. Fluoroscopic caudal epidural injections in managing chronic axial low back pain without disc herniation, radiculitis, or facet joint pain. J Pain Res. 2012;5:381-390. [pmid: 23091395].
130 Manchikanti L, Cash KA, McManus CD, et al. One-year results of a randomized, double-blind, active controlled trial of fluoroscopic caudal epidural injections with or without steroids in managing chronic discogenic low back pain without disc herniation or radiculitis. Pain Physician. Jan-Feb. 2011;14(1):25-36. [pmid: 21267039].
131 Manchikanti L, Cash KA, McManus CD, et al. Preliminary results of a randomized, equivalence trial of fluoroscopic caudal epidural injections in managing chronic low back pain: Part 1--Discogenic pain without disc herniation or radiculitis. Pain Physician. Nov-Dec. 2008;11(6):785-800. [pmid: 19057626].
132 Manchikanti L, Cash KA, McManus CD, et al. A randomized, double-blind, active-controlled trial of fluoroscopic lumbar interlaminar epidural injections in chronic axial or discogenic low back pain: Results of 2-year follow-up. Pain Physician. 2013;16(5):E491-E504. [pmid: 24077199].
133 Manchikanti L, Cash KA, McManus CD, et al. Fluoroscopic lumbar interlaminar epidural injections in managing chronic lumbar axial or discogenic pain. J Pain Res. 2012;5:301-311. [pmid: 23055773].
134 Manchikanti L, Cash KA, McManus CD, et al. Preliminary results of a randomized, double-blind, controlled trial of fluoroscopic lumbar interlaminar epidural injections in managing chronic lumbar discogenic pain without disc herniation or radiculitis. Pain Physician. Jul-Aug. 2010;13(4):E279-E292. [pmid: 20648214].
135 Devulder J, Deene P, De Laat M, et al. Nerve root sleeve injections in patients with failed back surgery syndrome: a comparison of three solutions. Clinical Journal of Pain. Jun. 1999;15(2):132-135. [pmid: 10382927].
136 Manchikanti L, Singh V, Cash KA, et al. Assessment of effectiveness of percutaneous adhesiolysis and caudal epidural injections in managing post lumbar surgery syndrome: 2-year follow-up of a randomized, controlled trial. J Pain Res. 2012;5:597-608. [pmid: 23293536].
137 Meadeb J, Rozenberg S, Duquesnoy B, et al. Forceful sacrococcygeal injections in the treatment of postdiscectomy sciatica. A controlled study versus glucocorticoid injections. Joint Bone Spine. Feb. 2001;68(1):43-49. [pmid: 11235780].
138 Rahimzadeh P, Sharma V, Imani F, et al. Adjuvant hyaluronidase to epidural steroid improves the quality of analgesia in failed back surgery syndrome: a prospective randomized clinical trial. Pain Physician. Jan-Feb. 2014;17(1):E75-E82. [pmid: 24452659].
139 Rocco AG, Frank E, Kaul AF, et al. Epidural steroids, epidural morphine and epidural steroids combined with morphine in the treatment of post-laminectomy syndrome. Pain. Mar. 1989;36(3):297-303. [pmid: 2523528].
140 Ackerman WE 3rd, Ahmad M. Pain relief with intraarticular or medial branch nerve blocks in patients with positive lumbar facet joint SPECT imaging: a 12-week outcome study. Southern Medical Journal. Sep. 2008;101(9):931-934. [pmid: 18708988].
141 Carette S, Marcoux S, Truchon R, et al. A controlled trial of corticosteroid injections into facet joints for chronic low back pain. N Engl J Med. Oct. 3. 1991;325(14):1002-1007. [pmid: 1832209].
142 Civelek E, Cansever T, Kabatas S, et al. Comparison of effectiveness of facet joint injection and radiofrequency denervation in chronic low back pain. Turk Neurosurg. 2012;22(2):200-206. [pmid: 22437295].
143 Fuchs S, Erbe T, Fischer HL, et al. Intraarticular hyaluronic acid versus glucocorticoid injections for nonradicular pain in the lumbar spine. J Vasc Interv Radiol. Nov. 2005;16(11):1493-1498. [pmid: 16319156].
144 Galiano K, Obwegeser AA, Walch C, et al. Ultrasound-guided versus computed tomography-controlled facet joint injections in the lumbar spine: a prospective randomized clinical trial. Regional Anesthesia & Pain Medicine. Jul-Aug. 2007;32(4):317-322. [pmid: 17720116].
145 Lakemeier S, Lind M, Schultz W, et al. A comparison of intraarticular lumbar facet joint steroid injections and lumbar facet joint radiofrequency denervation in the treatment of low back pain: a randomized, controlled, double-blind trial. Anesthesia & Analgesia. Jul. 2013;117(1):228-235. [pmid: 23632051].
146 Lilius G, Laasonen EM, Myllynen P, et al. Lumbar facet joint syndrome. A randomised clinical trial. Journal of Bone & Joint Surgery - British Volume. Aug. 1989;71(4):681-684. [pmid: 2527856].
147 Manchikanti L, Pampati V, Bakhit CE, et al. Effectiveness of lumbar facet joint nerve blocks in chronic low back pain: a randomized clinical trial. Pain Physician. Jan. 2001;4(1):101-117. [pmid: 16906173].
148 Manchikanti L, Singh V, Falco FJ, et al. Evaluation of lumbar facet joint nerve blocks in managing chronic low back pain: a randomized, double-blind, controlled trial with a 2-year follow-up. Int J Med Sci. 2010;7(3):124-135. [pmid: 20567613].
149 Manchikanti L, Singh V, Falco FJE, et al. Lumbar facet joint nerve blocks in managing chronic facet joint pain: one-year follow-up of a randomized, double-blind controlled trial: Clinical Trial NCT00355914. Pain Physician. Mar-Apr. 2008;11(2):121-132. [pmid: 18354721].
150 Marks RC, Houston T, Thulbourne T. Facet joint injection and facet nerve block: a randomised comparison in 86 patients with chronic low back pain. Pain. Jun. 1992;49(3):325-328. [pmid: 1408298].
151 Nash T. Facet joints-intra-articular steroids or nerve block. Pain Clinic. 1990;3(2):77-82.
152 Pneumaticos SG, Chatziioannou SN, Hipp JA, et al. Low back pain: prediction of short-term outcome of facet joint injection with bone scintigraphy. Radiology. Feb. 2006;238(2):693-698. [pmid: 16436824].
153 Ribeiro LH, Furtado RN, Konai MS, et al. Effect of facet joint injection versus systemic steroids in low back pain: a randomized controlled trial. Spine. Nov. 1. 2013;38(23):1995-2002. [pmid: 23921331].
154 Luukkainen RK, Wennerstrand PV, Kautiainen HH, et al. Efficacy of periarticular corticosteroid treatment of the sacroiliac joint in non-spondylarthropathic patients with chronic low back pain in the region of the sacroiliac joint. Clin Exp Rheumatol. Jan-Feb. 2002;20(1):52-54. [pmid: 11892709].
155 Rados I, Sakic Zdravcevic K, Hrgovic Z. painDETECT questionnaire and lumbar epidural steroid injection for chronic radiculopathy. European Neurology. 2013;69(1):27-32. [pmid: 23128915].
156 Serrao JM, Marks RL, Morley SJ, et al. Intrathecal midazolam for the treatment of chronic mechanical low back pain: a controlled comparison with epidural steroid in a pilot study. Pain. Jan. 1992;48(1):5-12. [pmid: 1531383].
157 McGrath JM, Schaefer MP, Malkamaki DM. Incidence and characteristics of complications from epidural steroid injections. Pain Medicine. May. 2011;12(5):726-731. [pmid: 21392252].
158 Manchikanti L, Malla Y, Wargo BW, et al. A prospective evaluation of complications of 10,000 fluoroscopically directed epidural injections. Pain Physician. Mar-Apr. 2012;15(2):131-140. [pmid: 22430650].
159 Manchikanti L, Malla Y, Wargo BW, et al. Complications of fluoroscopically directed facet joint nerve blocks: a prospective evaluation of 7,500 episodes with 43,000 nerve blocks. Pain Physician. Mar-Apr. 2012;15(2):E143-E150. [pmid: 22430660].
160 Manchikanti L, Malla Y, Wargo BW, et al. A prospective evaluation of bleeding risk of interventional techniques in chronic pain. Pain Physician. 2011;14(4):317-329. [pmid: 21785475].
161 Epstein NE. The risks of epidural and transforaminal steroid injections in the Spine: Commentary and a comprehensive review of the literature. Surg Neurol Int. 2013;4(Suppl 2):S74-S93. [pmid: 23646278].
162 Smith RM, Schaefer MK, Kainer MA, et al. Fungal infections associated with contaminated methylprednisolone injections. New Engl J Med. 2013;369(17):1598-1609. [pmid: 23252499].
163 Shamliyan TA, Staal JB, Goldmann D, et al. Epidural Steroid Injections for Radicular Lumbosacral Pain: A Systematic Review. Phys Med Rehabil Clin N Am. 2014;25(2):471-489.e50. [pmid: 24787344].
164 Choi HJ, Hahn S, Kim CH, et al. Epidural steroid injection therapy for low back pain: a meta-analysis. Int J Technol Assess Health Care. Jul. 2013;29(3):244-253. [pmid: 23769210].
165 Novak S, Nemeth WC. The basis for recommending repeating epidural steroid injections for radicular low back pain: a literature review. Archives of Physical Medicine & Rehabilitation. Mar. 2008;89(3):543-552. [pmid: 18295635].
166 Rabinovitch DL, Peliowski A, Furlan AD. Influence of lumbar epidural injection volume on pain relief for radicular leg pain and/or low back pain. Spine Journal: Official Journal of the North American Spine Society. Jun. 2009;9(6):509-517. [pmid: 19398387].
167 Edwards SJ, Clarke MJ, Wordsworth S, et al. Indirect comparisons of treatments based on systematic reviews of randomised controlled trials. Int J Clin Pract. 2009;63(6):841-854. [pmid: 19490195].
168 Staal JB, de Bie R, de Vet HC, et al. Injection therapy for subacute and chronic low-back pain. Cochrane Database of Systematic Reviews. 2008;(3):CD001824. [pmid: 18646078].
169 Henschke N, Kuijpers T, Rubinstein SM, et al. Injection therapy and denervation procedures for chronic low-back pain: a systematic review. European Spine Journal. Sep. 2010;19(9):1425-1449. [pmid: 20424870].
170 MacVicar J, King W, Landers MH, et al. The effectiveness of lumbar transforaminal injection of steroids: a comprehensive review with systematic analysis of the published data. Pain Medicine. Jan. 2013;14(1):14-28. [pmid: 23110347].
171 Roberts ST, Willick SE, Rho ME, et al. Efficacy of lumbosacral transforaminal epidural steroid injections: a systematic review. Pm & R. Jul. 2009;1(7):657-668. [pmid: 19627959].
172 Falco FJE, Manchikanti L, Datta S, et al. An update of the effectiveness of therapeutic lumbar facet joint interventions. Pain Physician. Nov-Dec. 2012;15(6):E909-E953. [pmid: 23159980].
173 Dworkin RH, Turk DC, Farrar JT, et al. Core outcome measures for chronic pain clinical trials: IMMPACT recommendations. Pain. 2005;113(1–2):9-19. [pmid: 15621359].
174 U.S. Food and Drug Administration. Slides for the November 24–25, 2014 Meeting of the Anesthetic and Analgesic Drug Products Advisory Committee (AADPAC). Accessed at: http://www.fda.gov/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/ucm425962.htm on February 13, 2015.
175 National Institute for Health and Care Excellence. Low back pain: Early management of persistent non-specific now back pain. 2009. 2010/08/13 ed.
176 Manchikanti L, Abdi S, Atluri S, et al. An update of comprehensive evidence-based guidelines for interventional techniques in chronic spinal pain. Part II: guidance and recommendations. Pain Physician. Apr. 2013;16(2 Suppl):S49-S283. [pmid: 23615883].
177 Song F, Loke YK, Walsh T, et al. Methodological problems in the use of indirect comparisons for evaluating healthcare interventions: survey of published systematic reviews. BMJ. 2009. 2009-04-03 11:14:19;338;b1147. [doi: 10.1136/bmj.b1147]. [pmid: 19346285].
178 Morrison A, Moulton K, Clark M, et al. English-Language Restriction When Conducting Systematic Review-based Meta-analyses: Systematic Review of Published Studies. Canadian Agency for Drugs and Technologies in Health. Available at: http://cadth.ca/media/pdf/H0478_Language_Restriction_Systematic_Review_Pub_Studies_e.pdf. 1471-6348 (Electronic) 0266-4623 (Linking). Ottawa: Apr 2009. http://cadth.ca/media/pdf/H0478_Language_Restriction_Systematic_Review_Pub_Studies_e.pdf.
179 Cohen SP, Williams KA, Kurihara C, et al. Multicenter, randomized, comparative cost-effectiveness study comparing 0, 1, and 2 diagnostic medial branch (facet joint nerve) block treatment paradigms before lumbar facet radiofrequency denervation. Anesthesiology. Aug. 2010;113(2):395-405. [pmid: 20613471].