# Methods

The methods for this Technology Assessment follow the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.36 All methods were determined a priori.

## Input From Stakeholders

This topic was selected for review based on a nomination from the Centers for Medicare and Medicaid Services (CMS). The initial Key Questions for this Technology Assessment were developed with input from CMS staff. The Key Questions and scope were further developed with input from a group of stakeholders (Key Informants) convened for this report to provide diverse stakeholder perspectives and content and methodological expertise. The Key Informants consisted of experts in internal medicine, health services research, pain medicine, radiology, neurology, occupational medicine, and physical medicine and rehabilitation, as well as those representing the patient perspective. Key Informants disclosed financial and other conflicts of interest prior to participation. The AHRQ Task Order Officer and the investigators reviewed the disclosures and determined that the Key Informants had no conflicts of interest that precluded participation. A topic refinement document was then posted for public comment from December 17, 2013, through January 17, 2014 with the Key Question and inclusion criteria. Based on public comments, we further revised the Key Questions and scope. The protocol for this Technology Assessment was finalized prior to initiation of the review, and was posted on the AHRQ Web site.

## Literature Search Strategy

A research librarian conducted searches in Ovid MEDLINE, the Cochrane Central Register of Controlled Trials, the Cochrane Database of Systematic Reviews, and the National Guideline Clearinghouse from 2008 through October, 2014 (see Appendix A for full search strategy). We restricted search start dates to January 2008, as there are multiple recent systematic evidence reviews directly addressing the Key Questions in the current review, including a good-quality review conducted by the same investigators of the current review that was commissioned by the American Pain Society (APS) and conducted searches through July 2008.^17^ The APS review included all of the interventions addressed in the current review. We used the APS review and other systematic reviews37 to identify studies published prior to 2008.

We also hand searched the reference lists of relevant studies and searched for unpublished studies in ClinicalTrials.gov. We did not solicit Scientific Information Packets (SIPs) for published and unpublished studies because the corticosteroid and local anesthetic drugs examined in this review are generic and the injections do not involve use of proprietary devices.

Literature searches will be updated while the draft report is posted for public comment and undergoing peer review to identify any new publications. Literature identified during the update search will be assessed by following the same process of dual review as all other studies considered for inclusion in the report. If any pertinent new literature is identified for inclusion in the report, it will be incorporated before the final submission of the report.

## Study Selection

We developed criteria for inclusion and exclusion of articles based on the Key Questions and the populations, interventions, comparators, outcomes, timing, setting approach (Appendix B), in accordance with the AHRQ Methods Guide.38 Articles were selected for full-text review if they were about epidural injections, facet joint injections, therapeutic medial branch injections, or sacroiliac injections with corticosteroids for radicular low back pain, spinal stenosis, or nonradicular low back pain, were relevant to a Key Question, and met the predefined inclusion criteria as described below. We excluded studies published only as conference abstracts, restricted inclusion to English-language articles, and excluded studies of nonhuman subjects. Studies had to report original data to be included.

To ensure accuracy, all excluded abstracts were dual reviewed. All citations deemed appropriate for inclusion by at least one of the reviewers were retrieved. Each full-text article was independently reviewed for eligibility for final inclusion by two team members. Discrepancies were resolved through discussion and consensus. A list of the included studies is available in Appendix C; excluded studies are shown Appendix D, with primary reasons for exclusion. Members of the review team were not involved in inclusion decisions for studies that they were authors on.

For epidural injections, we selected studies of adults undergoing epidural corticosteroid injections with radicular low back pain, spinal stenosis, nonradicular low back pain, or chronic postsurgical pain. We defined radiculopathy as presence of leg pain (typically worse than back pain), with or without sensory deficits or weakness, in a nerve root distribution. A number of studies used the term “sciatica,” which we classified as radiculopathy. We included epidural injections performed via any approach, including the transforaminal, interlaminar, or caudal techniques. We also included studies of injections performed via the transforaminal approach that targeted the affected nerve root but did not necessarily enter the epidural space (“periradicular” injections).

For facet joint and sacroiliac injections, we selected studies of adults undergoing corticosteroid injections in or around the facet or sacroiliac joints for nonradicular low back pain presumed to originate from the facet joints (facet injections) or sacroiliac joints (sacroiliac injections). We included injections into the joint (intra-articular) or around the joint (extra-articular [peri-articular]), as well as therapeutic medial branch blocks (injections at the site of the medial branch of the dorsal ramus nerves innervating the facet joints).

We excluded studies of patients younger than 18 years of age, pregnant women, and patients with back pain due to fracture, high-impact trauma, cancer, infection, or spondyloarthropathy. We excluded studies of noninjection ablative therapies such as intradiscal electrothermal therapy or radiofrequency denervation, other noninjection therapies such as nucleoplasty, and studies that involved injection of noncorticosteroid medications (such as ozone, antitumor necrosis factor medications, methylene blue, or clonidine) unless they were compared to a corticosteroid injection. Studies on the diagnostic accuracy of diagnostic blocks was outside the scope of the review, but we evaluated how use of diagnostic blocks to select patients impacted estimates of effectiveness.

We included studies of patients with symptoms of any duration prior to enrollment. We included studies that compared the injections of interest versus epidural nonsteroid injections, soft tissue injections, no injection, surgery, or noninjection, nonsurgical therapies. We classified epidural injections with local anesthetics or saline, soft tissue injections with local anesthetics or saline, and no injections as “placebo” interventions to distinguish them from “active” interventions such as epidural injections of other medications, other interventional procedures, surgery, or nonsurgical, noninterventional therapies. We also included studies that compared different injection techniques and corticosteroid doses.

Outcomes were pain, function, quality of life, opioid use, subsequent surgery, health care utilization, and harms, including bleeding, infection, neurological events, and systemic complications, such as weight gain, diabetes, osteoporosis, and other endocrinological effects. We included outcomes measured 1 week or later after the injection.

We included randomized trials for all Key Questions. For harms, we also included large (sample size >1000 patients) treatment series of patients who underwent the injections of interest. We excluded case series and case reports. We reviewed reference lists of systematic reviews for potentially relevant references.

## Data Extraction

We extracted the following information from included studies into evidence tables using Excel spreadsheets: study design, year, setting, country, sample size, inclusion and exclusion criteria (including age, sex, race, back pain condition, duration of pain, baseline pain, baseline function, prior therapies, imaging and diagnostic findings, and psychosocial factors), intervention characteristics (including type and dose of corticosteroid and local anesthetic, volume of injectate, number and frequency of injections, levels injected, injection approach, use of imaging guidance, and experience of the person performing the injection), characteristics of the control intervention, and results.

For studies of interventions, we calculated relative risks and associated 95 percent confidence intervals (CI) based on the information provided (sample sizes and incidence of outcomes of interest in each intervention group). We noted discrepancies between calculated and reported results when present.

Data extraction for each study was performed by two investigators. The first investigator extracted the data, and the second investigator independently reviewed the extracted data for accuracy and completeness.

## Assessing Quality

We assessed quality (risk of bias) for each study using predefined criteria. We used the term “quality” rather than the alternate term “risk of bias;” both refer to internal validity. Randomized trials were evaluated with criteria and methods developed by the Cochrane Back Review Group.39 These criteria were applied in conjunction with the approach recommended in the chapter on Assessing the Risk of Bias of Individual Studies When Comparing Medical Interventions38 in the AHRQ Methods Guide. Two investigators independently assessed the quality of each study. Discrepancies were resolved through discussion and consensus. Members of the review team who were authors on included studies were not involved in quality rating of those studies.

Individual studies were rated as having “poor,” “fair,” or “good” quality. We rated the quality of each randomized trial based on the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; whether attrition was adequately reported and acceptable; similarity in use of cointerventions; compliance to allocated treatments; the use of intent-to-treat analysis; and avoidance of selective outcomes reporting.39, 40

Studies rated “good quality” were considered to have low risk of bias and their results are likely to be valid. Studies rated “fair quality” have some methodological shortcomings, but no flaw or combination of flaws judged likely to cause major bias. In some cases, the article did not report important information, making it difficult to assess its methods or potential limitations. The “fair quality” (moderate risk of bias) category is broad and studies with this rating vary in their strengths and weaknesses; the results of some studies assessed to have moderate risk of bias are likely to be valid, while others may be only possibly valid. Studies rated “poor quality” (high risk of bias) have significant flaws that may invalidate the results. They have a serious or “fatal” flaw or combination of flaws in design, analysis, or reporting; large amounts of missing information (including publication of only preliminary results in a subgroup of patients randomized); or serious discrepancies in reporting. The results of these studies are at least as likely to reflect flaws in the study design as the differences between the compared interventions. We did not exclude poor-quality studies a priori, but they were considered the least reliable when synthesizing the evidence, particularly when discrepancies between studies were present.

Treatment series of patients undergoing injection therapies were not formally rated because they already are known to have serious limitations due to the lack of a control group of patients who did not undergo injections.

## Assessing Research Applicability

We recorded factors important for understanding the applicability of studies, such as whether the publication adequately described the study sample, the country in which the study was conducted, the characteristics of the patient sample (e.g., age, sex, race, type of back pain, imaging findings, duration or severity of pain, medical comorbidities, and psychosocial factors), the characteristics of the interventions used (e.g., specific corticosteroid, dose, technique, number or frequency of injections, and use of imaging guidance), and the magnitude of effects on clinical outcomes.41 We also recorded the funding source and role of the sponsor. We did not assign a rating of applicability (such as high or low) because applicability may differ based on the user of the report.

For interpreting the clinical importance of mean changes in outcome scores, we defined a minimum clinically important difference as an improvement in 15 points on a 0 to 100 pain scale, 10 points on the Oswestry Low Back Pain Disability Questionnaire (ODI), and 5 points on the Roland Morris Disability Questionnaire (RDQ).42 These thresholds were recommended in a report from a panel of 36 experts in the low back pain field following a review of the evidence.42

## Evidence Synthesis and Rating the Body of Evidence

We constructed evidence tables summarizing study characteristics, results, and quality ratings for all included studies. We summarized evidence for each Key Question qualitatively using a hierarchy-of-evidence approach, where the best evidence was the focus of our synthesis for each Key Question.

We conducted meta-analyses to summarize data and obtain more precise estimates for outcomes and comparisons for which studies were homogeneous enough to provide a meaningful combined estimate.43 Comparisons for which evidence was suitable for pooling were epidural corticosteroid injection versus placebo (epidural local anesthetic injection, epidural saline injection, soft tissue local anesthetic injection, soft tissue saline injection, needling with no injection, or no injection) for radiculopathy, epidural corticosteroid injection versus placebo for spinal stenosis, and transforaminal versus interlaminar epidural injections with corticosteroid for radiculopathy.

Outcomes were extracted and stratified by duration of followup as immediate (≤2 weeks), short term (2 weeks to ≤3 months), intermediate term (3 months to <1 year), and long term (>1 year). For each category, we used the longest duration data available. We analyzed two continuous outcomes: pain and function. For pain, we used pain as measured on a 0 to 10 or 0 to100 visual analogue or numerical rating scale and converted all scores to 0 (no pain) to 100 (worst possible pain). We used data for leg pain when available; if leg pain was not specifically reported we used overall pain (leg pain is typically worse than back pain in patients with radiculopathy). Other pain scores reported were also included, including the Multidimensional Pain Inventory (range 0 to 100, higher scores indicate greater disability) and the McGill Pain Questionnaire (pain rating index score ranges from 0 to 78; present pain intensity ranges from 1 to 5; higher scores indicate greater pain disability). For studies that assessed function using more than one measure, we prioritized the outcome used for pooling in the following order: ODI (range 0 to 100, higher scores indicate greater disability), RDQ (range 0 to 24, higher scores indicate greater disability), and other function scales (including the Hannover Functional Ability Questionnaire (range 0 to 24, lower scores indicate greater disability), the Low Back Outcome Score (range 0 to 75, higher scores indicate less disability or need), and North American Spine Society Lumbar Spine Questionnaire (range 0 to 100, higher scores indicate greater disability). The ODI and the RDQ are the most commonly used measures of back-specific function and are recommended core outcome measures.44 Other included outcome measures are detailed in the evidence tables. In the primary analyses, we combined weighted mean difference (WMD) for pain and standardized mean difference (SMD) for function. The mean difference was calculated using the change between the followup and baseline scores. We also conducted sensitivity analysis based on differences in scores at followup and estimates from analysis of covariance or other results that adjusted for other covariates if available; results were similar to the primary analyses and not reported further. When the standard deviation was missing, we imputed the missing value using the mean standard deviation from other studies in that analysis. For binary outcomes, we combined relative risks (RR) for pain and function “success” (e.g., ≥50% improvement in pain scores or ODI, or as otherwise defined in the trials), composite or overall measures of success (e.g., ≥50% improvement in pain and ≥50% function, or as otherwise defined in the trials), and rates of subsequent surgery. In addition, we pooled placebo response rates for the binary pain and function and mean difference in change scores for pain and function in the placebo group (as a measure of placebo response), stratified by the comparator used.

The studies were combined using the Dersimonian-Laird random effects method. We assessed the presence of statistical heterogeneity among the studies by using the standard Cochran’s chi-square test, and the magnitude of heterogeneity by using the I^2^ statistic.45 When statistical heterogeneity was present, we performed sensitivity analyses by conducting meta-analysis using the profile likelihood method.46 For the primary analyses of epidural injections versus placebo, we pooled across approaches (transforaminal, interlaminar, or caudal), but also stratified the results by approach. We performed sensitivity analyses by excluding poor-quality studies and outlier studies. When the number of studies was relatively large (eight to 10),43 we performed additional subgroup analyses and meta-regression based on the specific corticosteroid used, the corticosteroid dose (converted into prednisolone equivalents, for transforaminal ≥50 mg vs. <50 mg; for interlaminar and caudal, ≥100 mg vs. <100 mg), the local anesthetic used, the specific comparator (epidural injection with local anesthetic, epidural injection with saline, soft tissue injection with local anesthetic, soft tissue injection with saline, needling without injection, or no injection), the volume of injected (for transforaminal, >3 ml vs. ≤ 3 ml; for interlaminar, ≥10 ml vs. <10 ml; for caudal, ≥20 ml vs. <20 ml), the duration of symptoms (restricted to acute [symptoms ≤4 weeks]), whether imaging correlation was required for patient enrollment, whether enrollment was restricted to patients with herniated disc on imaging, use of fluoroscopic guidance, whether the intervention was limited to a single injection, whether patients with prior surgery were excluded, overall quality rating (good, fair, poor), whether the person performing the injection was blinded, and blinding of outcomes assessors and patients. For transforaminal injections, we also stratified studies according to whether the injection clearly entered the epidural space or targeted the nerve root (“periradicular”) without clearly entering the epidural space. Similar analyses were performed for the analysis of transforaminal versus interlaminar injections when data allowed. A funnel plot was created and the Egger test performed for primary analyses across approaches (transforaminal, interlaminar, or caudal) with 10 studies to assess for small study effects.47 All analyses were conducted using Stata/IC 13.0 (StataCorp LP, College Station, TX).

We assessed the strength of evidence (SOE) for each Key Question and outcome using the approach described in the AHRQ Methods Guide,38 based on the overall quality of each body of evidence, based on the risk of bias (graded low, moderate, or high); the consistency of results across studies (graded consistent, inconsistent, or unable to determine when only one study was available); the directness of the evidence linking the intervention and health outcomes (graded direct or indirect); and the precision of the estimate of effect, based on the number and size of studies and confidence intervals for the estimates (graded precise or imprecise).

We graded the SOE for each Key Question using the four categories recommended in the AHRQ Methods Guide.38 A “high” grade indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect. A “moderate” grade indicates moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate. A “low” grade indicates low confidence that the evidence reflects the true effect and further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. An “insufficient” grade indicates evidence either is unavailable or is too limited to permit any conclusion, due to the availability of only poor-quality studies, extreme inconsistency, or extreme imprecision.

## Peer Review and Public Commentary

Experts in low back pain and injection therapies, as well as individuals representing important stakeholder groups, have been invited to provide external peer review of this report. The AHRQ Task Order Officer will also provide comments and editorial review. To obtain public comment, the draft report was posted on the AHRQ Web site for 2 weeks. A disposition of comments report detailing the authors' responses to the peer and public review comments will be made available after the AHRQ posts the final report on the public Web site.