# Introduction

## Background

Low back pain is one of the most frequently encountered conditions in clinical practice. Up to 84 percent of adults have low back pain at some time in their lives, and a national survey of U.S. adults in 2002 found that over one-quarter reported low back pain lasting at least a whole day in the previous 3 months.1, 2 Although low back pain affects individuals of all ages, its prevalence peaks at 55 to 64 years of age and remains common in those 65 years of age and older.3 Low back pain can have major adverse impacts on quality of life and function and is frequently associated with depression or anxiety. Low back pain is also costly. In 1998, total U.S. health care expenditures for low back pain were estimated at $90 billion.4 Since that time, costs of low back pain care have risen substantially, at a rate higher than observed for overall health expenditures.5 Low back pain is one of the most common reasons for missed work or reduced productivity while at work, resulting in high indirect costs; this makes the total costs associated with low back pain substantially higher than the direct health care costs.6

The prognosis of acute low back pain (an episode lasting less than 4 weeks) is generally favorable. Following onset of low back pain, most patients experience a rapid improvement in (and often a complete resolution of) pain and disability and are able to return to work.7 In those with persistent symptoms, continued improvement is often seen in the subacute phase between 4 and 12 weeks, though at a slower rate than observed in the acute phase. In a minority of patients, low back pain lasts longer than 12 weeks, at which point it is considered chronic, and levels of pain and disability often remain relatively constant.8 Such patients appear to account for the bulk of the burdens and costs associated with low back pain.9, 10

In the majority (>85%) of patients with low back pain, symptoms cannot be attributed to a specific disease or spinal pathology.11 Spinal imaging abnormalities such as degenerative disc disease, facet joint arthropathy, and bulging or herniated intervertebral discs are extremely common in patients with low back pain, particularly in older adults. However, such findings poorly predict the presence or severity of low back pain.12 Radiculopathy from nerve root impingement and spinal stenosis (narrowing of the spinal canal) each occur in about 4 to 5 percent of patients with low back pain and can cause neurological symptoms such as lower extremity pain, paresthesias, and weakness.13, 14

Multiple treatment options for subacute and chronic low back pain are available. Broadly, these can be classified as pharmacological treatments,15 nonpharmacological treatments (e.g., exercise therapy, cognitive behavioral therapy, spinal manipulation, acupuncture, and others),16 injection therapies,17 and surgical treatments.18 Injection therapies, the topic of this evidence review, include injections of medications to various structures in and around the spine (such as the epidural space, facet joints, intervertebral discs, and soft tissues).17 The most commonly used medications in back injections are corticosteroids to reduce inflammation and local anesthetics for analgesia, though others (such as anti-tumor necrosis factor agents, clonidine, methylene blue, and ozone) have also been studied. Corticosteroid injections can be administered into the epidural space or in and around the facet joints. Other interventional therapies involve the application of various types of energy to ablate pain-generating nerves, without the injection of medications.17 Ablative therapies include radiofrequency denervation, intradiscal electrothermal therapy, percutaneous intradiscal radiofrequency thermocoagulation, and other procedures.

Between 1994 and 2001, use of epidural injections increased by 271 percent and facet joint injections by 231 percent among Medicare beneficiaries.19 Total inflation-adjusted reimbursed costs (based on professional fees only) increased from $24 million to over $175 million over this time period. More recent data indicate continued rapid growth in use of spinal injection therapies among Medicare beneficiaries, with an increase of 187 percent in use between 2000 and 2008.^19^

Despite these dramatic increases, use of injection therapies for low back pain remains controversial. Systematic reviews of injection therapies have come to conflicting conclusions regarding the benefits of injection therapies,17, 20–27 and clinical practice guidelines provide discordant recommendations regarding their use.28–34 An important challenge in interpreting the evidence on injection therapies is the inconsistency of results across trials. Some of this inconsistency could be due to variability across studies in the methods used to select patients for inclusion, the specific injection techniques used, the comparisons evaluated, and the outcomes assessed.17 For example, trials of epidural corticosteroid injections for radiculopathy differ in how they define radiculopathy, whether imaging correlation with symptoms is required to be eligible for inclusion, the specific findings on imaging required for eligibility, the duration of pain, and other factors. All of these factors, which impact how patients are selected for study inclusion, could affect outcomes related to the injection therapy. There has also been variability in methods used to approach the epidural space (e.g., interlaminar [via the interlaminar space in the spine], transforaminal [through the neuroforamen of the exiting nerve root], or caudal [through the sacral hiatus at the sacral canal]), the use of fluoroscopic guidance, the volume of injectate administered, the specific corticosteroid and dose used, the local anesthetic used, and the number of injections and levels injected.23 In addition, trials have compared an epidural corticosteroid injection to an epidural saline injection, epidural injection of local anesthetic without corticosteroid, a soft tissue injection with local anesthetic and/or saline, no injection, or noninjection comparators.35 Similarly, for trials of facet joint injections, diagnostic methods for identifying patients with presumed facet joint pain vary across studies, including use of single or double facet joint blocks, the type and dose of corticosteroid injected, and the location of the injection (e.g., intra-articular [into the facet joint] or peri-articular [around the facet joint]).28 Although medial branch blocks, which are performed at the medial branch of the primary dorsal ramus nerves that innervate the facet joints were originally developed as a diagnostic test to determine presence of facet joint, they have also been evaluated as therapeutic facet joint injections using corticosteroid and/or local anesthetic.

All of these factors could introduce heterogeneity and make it difficult to determine whether negative results in a given trial are due to suboptimal patient selection, an ineffective therapy, or some combination of both factors.17 Another challenge is that trials of injection therapies have frequently focused on short-term outcomes related to pain, rather than longer-term functional outcomes.

Given the continued growth in use of epidural, facet joint, and sacroiliac injections for low back pain and continued uncertainty regarding their role and optimal use, the purpose of this systematic review is to summarize the current state of evidence, identify and evaluate inconsistencies in the evidence on these therapies, and identify important research gaps.

## Scope of Review and Key Questions

The Key Questions used to guide this report are shown below. The analytic framework (Figure 1, located at the end of the report) shows the target populations, interventions, and outcomes that we examined.

Figure 1 Analytic framework for pain management injection therapies for low back pain

^a^ Patients with nonradicular low back pain, low back pain with radiculopathy, and low back pain with spinal stenosis.

This figure depicts the analytic framework which outlines the evidence areas covered in the review, including the population, interventions and related harms, and outcomes. The population includes adults with nonspecific, subacute, or chronic low back pain, with a footnote specifying patients with non-radicular low back pain, low back pain with radiculopathy, and low back pain with spinal stenosis. An arrow from the population leads to the intervention types, which are epidural corticosteroid injections; facet joint corticosteroid injections; medial branch block injections; and sacroiliac joint corticosteroid injections. A dotted line leads from the interventions to the outcomes examined in the review, which are pain, function, quality of life, opioid use, and healthcare utilization. A subsequent arrow from the interventions assesses resulting harms. An additional arrow in the framework examines the effect of patient characteristics on outcomes.

Key Question 1. In patients with low back pain, what is the effectiveness of epidural corticosteroid injections, facet joint corticosteroid injections, medial branch blocks, and sacroiliac joint corticosteroid injections versus epidural nonsteroid injection, nonepidural injection, no injection, surgery or nonsurgical therapies on outcomes related to pain, function and quality of life?

Key Question 1a. How does effectiveness vary according to the medication (corticosteroid, local anesthetic) used, the dose or frequency of injections, the number of levels treated, or degree of provider experience?

Key Question 1b. How does effectiveness vary according to use of imaging guidance or route of administration (e.g., for epidural injections interlaminar, transforaminal, caudal for epidural injections and for facet joint injections intra-articular, extra-articular [peri-capsular] or medial branch injections)?

Key Question 2. In patients with low back pain, what patient characteristics predict responsiveness to injection therapies on outcomes related to pain, function, and quality of life?

Key Question 3. In randomized trials of low back pain injection therapies, how does effectiveness vary according to the control therapy used (e.g., epidural nonsteroid injection, nonepidural injection, no injection)?

Key Question 3a. How do response rates vary according to the specific comparator evaluated (e.g., saline epidural, epidural with local anesthetic, nonepidural injection, no injection, surgery, nonsurgical therapies)?

Key Question 4. What are the harms of epidural corticosteroid, facet joint corticosteroid injections, medial branch blocks, and sacroiliac joint corticosteroid injection compared to epidural nonsteroid injection, nonepidural injection, no injection, surgery, or nonsurgical therapies?