# Discussion

## Key Findings and Strength of Evidence Summary

The key findings of this review are summarized in the summary of evidence table (Table 13) and the factors used to determine the overall strength of evidence grades are summarized in Appendix G. Strengths of our review are inclusion of additional trials compared with prior reviews, evaluation of epidural corticosteroid injections for back pain conditions other than radiculopathy, evaluation of continuous as well as dichotomous outcomes, evaluation of outcomes at defined time points, evaluation of the effectiveness of epidural corticosteroids versus other active interventions, conduction of additional analyses to evaluate effects of methodological limitations, patient characteristics, and injection techniques on findings.

Table 13 Summary of evidence

Key Question Outcome | Strength of Evidence Grade | Conclusion
Key Question 1. In patients with low back pain, what is the effectiveness of epidural corticosteroid injections, facet joint corticosteroid injections, medial branch blocks, and sacroiliac joint corticosteroid injections vs. epidural nonsteroid injection, nonepidural injection, no injection, surgery or nonsurgical therapies on outcomes related to pain, function and quality of life?
Epidural injections for radiculopathy
Epidural corticosteroid injections vs. placebo interventions
Mean improvement in pain, immediate-term followup | Moderate | Epidural corticosteroid injections associated with greater improvement vs. placebo interventions (6 trials, WMD −7.55 on 0 to 100 scale, 95% CI −11.4 to −3.74, I2=30%)
Mean improvement in pain, short-term followup | Low | No difference (14 trials, WMD −3.94, 95% CI −9.11 to 1.24, I2=82%)
Mean improvement in pain, intermediate-term followup | Low | No difference (4 trials, WMD −0.07, 95% CI −8.41 to 8.26, I2=82%)
Mean improvement in pain, long-term followup | Moderate | No difference (6 trials, WMD −0.86, 95% CI −3.78 to 2.06, I2=0%)
Successful pain outcome, short-term followup | Low | No difference (8 trials, RR 1.21, 95% CI 0.98 to 1.49, I2=67%)
Successful pain outcome, intermediate-term followup | Low | No difference (3 trials, RR 1.12, 95% CI 0.93 to 1.36, I2=41%)
Successful pain outcome, long-term followup | Moderate | No difference (4 trials, RR 1.10, 95% CI 0.94 to 1.28, I2=0%)
Mean improvement in function, immediate-term followup | Low | No difference, based on all trials (4 trials, SMD −0.75, 95% CI −1.62 to 0.11, I2=94%). Excluding an outlier trial eliminated statistical heterogeneity and resulted in a statistically significant effect favoring epidural corticosteroid injections (3 trials, SMD −0.33, 95% CI −0.56 to −0.09, I2=0%)
Mean improvement in function, short-term followup | Moderate | No difference (11 trials, SMD −0.03, 95% CI −0.20 to 0.15, I2=53%)
Mean improvement in function, intermediate-term followup | Low | No difference (5 trials, SMD −0.30, 95% CI −0.74 to 0.15, I2=86%)
Mean improvement in function, long-term followup | Low | No difference (7 trials, SMD −0.23, 95% CI −0.55 to 0.10, I2=82%)
Successful functional outcome, short-term followup | Low | No difference (6 trials, RR 1.01, 95% CI 0.74 to 1.38, I2=76%)
Successful functional outcome, intermediate-term followup | Low | No difference (2 trials, RR 1.18, 95% CI 0.89 to 1.57, I2=71%)
Successful functional outcome, long-term followup | Low | No difference (3 trials, RR 1.15, 95% CI 0.97 to 1.35, I2=0%)
Risk of surgery, short-term followup | Low | Epidural corticosteroid injections were associated with lower risk vs. placebo interventions (8 trials, RR 0.62, 95% CI 0.41 to 0.92, I2=0%), but the estimate was no longer statistically significant after exclusion of poor-quality trials (5 trials, RR 0.69, 95% CI 0.42 to 1.13, I2=0%)
Risk of surgery, intermediate-term followup | Low | No difference (1 trial, RR 0.56, 95% CI 0.12 to 2.68)
Risk of surgery, long-term followup | Moderate | No difference (14 trials, RR 0.97, 95% CI 0.75 to 1.25, I2=23%)
Successful composite outcome, short-term followup | Moderate | No difference (9 trials, RR 1.13, 95% CI 0.98 to 1.32, I2=3.5%)
Successful composite outcome, intermediate-term followup | Low | No difference (1 trial, RR 0.71, 95% CI 0.34 to 1.48)
Successful composite outcome, long-term followup | Low | No difference (2 trials, 1.04, 95% CI 0.81 to 1.34, I2=0%)
Epidural corticosteroid injections vs. other interventions
Pain, function, surgery | Insufficient | There was insufficient evidence from two trials to determine effects of epidural corticosteroid injections vs. discectomy, due to methodological shortcomings in the trials
Pain function, surgery | Low | One trial found epidural corticosteroid injections associated with lower likelihood than MILD of achieving ≥ 25 point improvement in leg pain (RR 0.49, 95% CI 0.24 to 1.0), ≥13 point improvement in ODI (RR 0.34, 95% CI 0.34 to 0.95), and ≥5 point improvement in SF-36 (RR 0.34, 95% CI 0.12 to 0.95) through 2 years. There was no difference in risk of undergoing surgery (RR 0.45, 95% CI 0.09 to 2.19)
Pain, function, surgery | Insufficient | There was insufficient evidence from one small (n=26), fair-quality trial to determine effects of epidural corticosteroid injections vs. epidural clonidine injection
Pain, function, analgesic use | Low | One trial found transforaminal epidural corticosteroid injection superior to etanercept on the ODI at 1 month (difference −16 on 0 to 100 scale, 95% CI −26.0 to −6.27). There were no differences on other outcomes, including pain and analgesic use
Pain, function | Low | One trial found no differences between epidural corticosteroid vs. autologous conditioned serum administered via the oblique interlaminar approach in improvement in pain or ODI scores after 22 weeks
Pain, function, surgery | Insufficient | There was insufficient evidence from two trials to determine effects of epidural corticosteroid injections vs. nonsurgical, noninterventional therapies due to methodological shortcomings in the trials and differences in the nonsurgical, noninterventional therapies evaluated
Pain, function | Low | One trial found transforaminal epidural corticosteroid injection with corticosteroid plus hypertonic saline associated with greater decrease in pain intensity through 4 months than a corticosteroid injection alone (difference from baseline −2.78 vs. −1.50 on 0 to 10 NRS, p=0.05), though the effect was smaller and no longer statistically significant at 6 months. There were no differences in global assessment or the ODI
Pain, function | Low | One trial found no difference between transforaminal epidural injection with corticosteroid versus corticosteroid plus low-dose clonidine in pain scores through 12 weeks in patients with subacute low back pain
Epidural injections for spinal stenosis
Epidural corticosteroid injections vs. placebo interventions
Mean improvement in pain, immediate-term followup | Low | Epidural corticosteroid injection was superior to placebo at intermediate-term followup (1 trial, WMD −22.0, 95 % −36.0 to −8.0)
Mean improvement in pain, short-term followup | Moderate | No difference (5 trials, WMD 0.62, 95% CI −2.87 to 4.11, I2=0%)
Mean improvement in pain, intermediate-term followup | Low | No difference (3 trials, WMD 3.73, 95% CI −0.81 to 8.26, I2=0%)
Mean improvement in pain, long-term followup | Low | No difference (1 trial, mean difference 4.00, 95% CI −2.87 to 10.9)
Successful pain outcome, short-term followup | Low | No difference (3 trials, RR 0.98, 95% CI 0.84 to 1.15, I2=0%)
Successful pain outcome, intermediate-term followup | Low | No difference (2 trials, RR 0.98, 95% CI 0.78 to 1.24, I2=0%)
Successful pain outcome, long-term followup | Low | No difference (3 trials, RR 0.97, 95% CI 0.74 to 1.28, I2=0%)
Mean improvement in function, immediate-term followup | Low | No difference (2 trials, SMD −0.32, 95% CI −0.85 to 0.22, I2=0%)
Mean improvement in function, short-term followup | Moderate | No difference (5 trials, SMD −0.03, 95% CI −0.31 to 0.26, I2=60%)
Mean improvement in function, intermediate-term followup | Low | No difference (3 trials, WMD 2.81, 95% CI −0.44 to 6.06, I2=0%)
Mean improvement in function, long-term followup | Low | No difference (2 trials, WMD 2.78, 95% CI −1.24 to 6.79, I2=0%)
Successful functional outcome, short-term followup | Low | No difference (3 trials, RR 0.91, 95% CI 0.70 to 1.18, I2=37%)
Successful functional outcome, intermediate-term followup | Low | No difference (2 trials, RR 0.96, 95% CI 0.74 to 1.25, I2=0%)
Successful functional outcome, long-term followup | Low | No difference (2 trials, RR 0.95, 95% CI 0.71 to 1.26, I2=0%)
Successful composite outcome, short-term followup | Low | No difference (2 trials, RR 1.18, 95% CI 0.55 to 2.55, I2=80%)
Successful composite outcome, intermediate-term followup | Low | No difference (1 trial, RR 0.93, 95% CI 0.63 to 1.35)
Successful composite outcome, long-term followup | Low | No difference (2 trials, RR 1.16, 95% CI 0.76 to 1.78, I2=0%)
Risk of surgery, long-term followup | Low | No difference (1 trial, RR 0.76, 95% CI 0.38 to 1.54)
Epidural corticosteroid injections vs. other interventions
Pain, function | Low | One trial found an epidural corticosteroid injection associated with lower likelihood of experiencing ≥2 point improvement in pain at 2 weeks vs. the MILD procedure, but the difference was no longer present at 6 weeks. There was no difference in function
Pain, function | Low | One trial found no differences between and epidural corticosteroid injection vs. intense physical therapy in pain intensity or functional outcomes at 2 weeks through 6 months
Pain, function | Low | One trial found epidural corticosteroid injection associated with worse leg pain than epidural etanercept injection at 1 month, with no difference in functional outcomes
Pain, function | Insufficient | There was insufficient evidence from one poor-quality trial to determine effects of epidural corticosteroid injections vs. epidural adhesiolysis
Epidural corticosteroid injections vs. placebo interventions for nonradicular low back pain
Pain, function, opioid use | Low | Two trials found no differences between epidural corticosteroid injections and epidural local anesthetic injections in pain, function, or opioid use
Epidural injections for chronic postsurgical pain
All outcomes | Insufficient | No trial compared an epidural injection with corticosteroid vs. a placebo intervention
All outcomes | Insufficient | Evidence from 4 trials was insufficient to determine effects of epidural corticosteroid injections vs. other interventions, due to methodological limitations, differences in the comparators evaluated, and small sample sizes
Facet joint injections
Pain, function | Low | Two trials found no clear differences between an intra-articular facet joint injection with corticosteroid vs. saline in pain or function at 1 to 3 months
All outcomes | Insufficient | Evidence from one small, poor-quality trial was insufficient to determine effects of an intra-articular corticosteroid facet joint injection vs. medial branch local anesthetic injection
All outcomes | Insufficient | Evidence from one poor-quality trial was insufficient to determine effects of an extra-articular facet joint corticosteroid injection vs. intra-articular saline injection
Pain, function, opioid use | Low | Two trials found no differences between medial branch corticosteroid injection vs. medial branch local anesthetic injection in pain, function, or opioid use through 12 to 24 months
Pain, function, quality of life | Low | One trial found no clear differences between an intra-articular facet joint versus an intramuscular corticosteroid injection in pain, function, or quality of life through 6 months
Pain, function, quality of life | Low | One trial found no differences between intra-articular facet injection with triamcinolone acetonide vs. hyaluronic acid in pain or function at 1 month or in health-related quality of life at 1 week
Pain, function, analgesic use | Low | One trial found no differences between intra-articular corticosteroid injection plus sham neurotomy vs. medial branch radiofrequency facet neurotomy plus local anesthetic injection in pain, function, or analgesic use at 6 months
Pain, quality of life | Low | One fair-quality trial found medial branch corticosteroid injection inferior to radiofrequency facet denervation on pain at 1, 6, and 12 months, with no differences in quality of life (1, 6, and 12 months), but results may have been confounded by differential use of diagnostic blocks to select patients for inclusion
Sacroiliac joint injections
All outcomes | Insufficient | There was insufficient evidence from one small (n=24) trial to determine effects of peri-articular sacroiliac corticosteroid injection vs. local anesthetic injection
Key Question 1a. How does effectiveness vary according to the medication (corticosteroid, local anesthetic) used, the dose or frequency of injections, the number of levels treated, or degree of provider experience?
Epidural injections
Epidural corticosteroid injections for radiculopathy
Effects of different corticosteroids: all outcomes | Low | Four trials that directly compared epidural corticosteroid injections for radiculopathy with different corticosteroids found few differences in outcomes including pain and function, but conclusions were limited by differences in the corticosteroids compared, doses, and some inconsistency
Effects of different local anesthetics: all outcomes | Insufficient | No trial directly compared effects of epidural corticosteroid injections with one local anesthetic vs. another
Effects of corticosteroid dose: all outcomes | Low | Six trials that directly compared epidural injections for radiculopathy using different corticosteroid doses found no clear differences in outcomes including pain and function
Effects of number of injections, number of levels injected, or provider experience: all outcomes | Low for number of injections, insufficient for number of levels and provider experience | No trial directly compared the effectiveness of epidural corticosteroid injections based on the number of injections, number of levels injected, or provider experience. Two trials found no association between receipt of more injections and better outcomes
Epidural corticosteroid injections for spinal stenosis
Effects of corticosteroids: pain, claudication distance | Low | One trial found no clear differences between caudal epidural injection for spinal stenosis with methylprednisolone vs. triamcinolone in pain or claudication distance through 6 months, though results favored methylprednisolone
Facet joint injections
Effects of different corticosteroids, local anesthetics, doses, frequency or number of injections, or degree of provider experience | Insufficient | No trial of facet joint injections directly compared effects of different corticosteroids, different local anesthetics, different doses, different frequency or number of injections, or degree of provider experience. Indirect evidence was too limited to reach reliable conclusions
Key Question 1b. How does effectiveness vary according to use of imaging guidance or route of administration (e.g., for epidural injections interlaminar, transforaminal, caudal for epidural injections and for facet joint injections intra-articular, extra-articular [peri-capsular] or medial branch injections)?
Epidural injections
Use of imaging
Effects of imaging guidance vs. no imaging guidance: All outcomes | Insufficient | No trial directly compared the effectiveness of epidural injections for radiculopathy performed with or without imaging guidance. Indirect evidence was not useful for evaluating effects of imaging guidance on estimates of effects because use of imaging guidance was highly associated with the epidural technique used
Effects of fluoroscopic plus Doppler vs. fluoroscopic imaging guidance: Pain, function | Low | One trial of caudal epidural corticosteroid injections for radiculopathy found no difference between fluoroscopic plus Doppler guidance vs. fluoroscopic guidance alone in pain or ODI scores through 12 weeks
Effects of imaging to guide epidural injection targets: Pain, function, medication use | Low | One trial found no difference between use of MRI vs. history and physical examination without MRI to guide epidural corticosteroid injection treatment and targets on pain, function, or medication use
Transforaminal vs. interlaminar corticosteroid injections
Mean improvement in pain, immediate-term followup | Low | No difference (5 trials, WMD −10.1, 95% CI −24.8 to 4.6, I2=83%)
Mean improvement in pain, short-term followup | Low | No difference (3 trials, WMD −1.29, 95% CI −12.6 to 10.1, I2=54%)
Mean improvement in pain, intermediate-term followup | Low | No difference (2 trials, WMD −11.3, 95% CI −44.8 to 22.2, I2=87%)
Mean improvement in function, immediate-term followup | Low | No difference (4 trials, SMD 0.03, 95% CI −0.48 to 0.53, I2=68%)
Mean improvement in function, short-term followup | Low | No difference (3 trials, SMD 0.39, 95% CI −0.36 to 1.13, I2=74%)
Mean improvement in function, long-term followup | Low | No difference (1 trial, WMD −2.00, 95% CI −8.77 to 4.77)
Likelihood of undergoing surgery, intermediate-term followup | Low | There were no differences between transforaminal vs. interlaminar epidural corticosteroid injections for radiculopathy in risk of undergoing surgery at intermediate-term followup in two trials (RR 0.76, 95% CI 0.18 to 3.19 and RR 1.33, 95% CI 0.44 to 4.05)
Comparisons of other approaches
Epidural injections for radiculopathy
Caudal vs. other approaches: Pain, function, depression | Low | One trial found the transforaminal epidural corticosteroid injections for radiculopathy associated with better pain outcomes than the caudal approach, with no differences in measures of function or depression, but no differences between the interlaminar vs. caudal approaches in measures of pain or depression
Oblique vs. standard interlaminar approaches: Successful composite outcome, surgery | Low | One trial found no differences between epidural corticosteroid injections for radiculopathy using the oblique interlaminar vs. standard interlaminar approaches in likelihood of achieving a successful outcome or undergoing surgery
Lateral parasagittal vs. standard interlaminar approaches: Pain, function | Low | One trial of epidural corticosteroid injections for radiculopathy found the lateral parasagittal interlaminar approach associated with greater likelihood of achieving >50% pain relief (RR 4.1, 95% CI 1.4 to 12) and greater improvement in pain and function than the standard interlaminar approach through 6 months; a second trial also reported results that favored the lateral parasagittal approach, but differences were smaller and not statistically significant
Lateral parasagittal vs. transforaminal approaches: Pain | Low | Two trials found no differences between epidural corticosteroid injections for radiculopathy using the lateral parasagittal vs. transforaminal approaches in pain or function through 6 or 12 months
Ganglionic vs. preganglionic transforaminal injections: Successful composite outcome | Low | One trial found transforaminal epidural corticosteroid injections for radiculopathy at the ganglionic vs. preganglionic approaches associated with a lower likelihood of a successful outcome at 1 month (RR 0.80, 95% CI 0.70 to 0.91), though differences were no longer present after 5 months
Epidural injections for spinal stenosis
Transforaminal vs. interlaminar: Leg pain, function | Low | No trial randomized patients with spinal stenosis to different approaches for performing epidural corticosteroid injections. One trial in which epidural corticosteroid injections could be performed by the interlaminar or transforaminal approaches found that interlaminar corticosteroid injections were associated with greater improvement in leg pain and function vs. local anesthetic injections at 3 weeks, but there were no differences between transforaminal corticosteroid vs. local anesthetic injections
Facet joint injections
Intra-articular facet joint corticosteroid injection: Pain | Low | One trial found intra-articular facet joint corticosteroid injection in patients with subacute low back pain selected on the basis of positive facet joint SPECT findings associated with lower pain intensity (3.2 vs. 5.4 on 0 to 10 NRS, p<0.05), greater likelihood of ≥50% pain relief (61% vs. 26%, RR 2.33, 95% CI 1.09 to 5.00), and better ODI score (12 vs. 23, p<0.05). versus medial branch injection at 12 weeks
Intra-articular facet joint vs. medial branch corticosteroid injection for chronic low back pain (imaging findings not required): Pain | Low | One trial found intra-articular facet joint corticosteroid injection associated with higher likelihood of pain relief vs. medial branch injection at 1 month (RR 1.68, 95% CI 1.03 to 2.73), but results were no longer statistically significant at 3 months, and there was no difference in likelihood of experiencing good or excellent pain relief
Intra-articular vs. extra-articular (peri-capsular) facet joint corticosteroid injection: All outcomes | Insufficient | There was insufficient evidence from one poor-quality trial to determine effectiveness of intra- vs. extra-articular (peri-capsular) facet joint corticosteroid injections
Effects of imaging guidance vs. no imaging guidance: All outcomes | Insufficient | No trial directly compared the effectiveness of epidural injections for radiculopathy performed with or without imaging guidance
Effects of CT- vs. ultrasound imaging guidance: Pain | Low | One trial found no difference between CT- vs. ultrasound-guided intra-articular facet joint corticosteroid injections with betamethasone and local anesthetic in pain at 6 weeks
Key Question 2. In patients with low back pain, what patient characteristics predict responsiveness to injection therapies on outcomes related to pain, function, and quality of life?
Epidural injections
Effects of duration: Pain, function | Low | Five of six trials of patients with radiculopathy found no association between duration of symptoms and responsiveness to epidural corticosteroid injections
Effects of age, sex, anxiety/depression, opioid use, baseline function, presence of neurological abnormalities, previous episodes, or work status: Pain, function | Low | Trials or patients with radiculopathy found no association between age, sex, anxiety/depression, opioid use, baseline function, presence of neurological abnormalities, previous episodes, or work status and responsiveness to epidural corticosteroid injections
Effects of cause of radicular symptoms: Pain, function | Insufficient | There was insufficient evidence from 4 trials to determine effects of the cause of radicular symptoms on responsiveness to epidural corticosteroid injections for radiculopathy, due to inconsistent results
Effects of smoking status, body mass index, use of opioid therapies or other concomitant therapies: Pain, function | Insufficient | No study evaluated the association between smoking status, body mass index, opioid therapies, or other concomitant therapies on responsiveness to epidural corticosteroid injection therapies for radiculopathy
Effects of pain, function | Low | Based on meta-regression analyses of trials of epidural corticosteroid injections vs. placebo interventions for radiculopathy, there was no clear association between prior lumbar surgery, requirement for imaging correlation with symptoms, or requirement for presence of herniated disc on imaging and estimates of treatment effect
Effects of race: All outcomes | Low | One trial of patients with spinal stenosis found no interaction between race and responsiveness to epidural corticosteroid injections
Effects of pain, patient satisfaction | Low | One trial of patients with nonradicular low back pain found no differences between transforaminal versus interlaminar epidural corticosteroid injection in pain or a patient satisfaction index in the subgroup of patient with imaging findings of a herniated disc, but in patients with spinal stenosis effects on pain favored the transforaminal approach (1.79 vs. 2.19 on the 0 to 5 Roland pain score, p<0.05; likelihood of improving ≥2 points 51% vs. 31%, RR 1.64, 95% CI 0.98 to 2.76 )
Facet joint injections
Effects of use of SPECT vs. no SPECT to identify targets for facet joint injections: Pain | Low | One trial found no difference between use of SPECT bone scans vs. no SPECT to identify targets for intra- and extra-articular facet joint corticosteroid injections in pain outcomes through 6 months
Sacroiliac joint injections | Insufficient | No evidence
Key Question 3. In randomized trials of low back pain injection therapies, how does effectiveness vary according to the control therapy used (e.g., epidural nonsteroid injection, nonepidural injection, no injection)?
Epidural injections
Effects of type of placebo intervention in patients with radiculopathy: Pain, function | Low | In trials of epidural corticosteroid injections vs. placebo injections for radiculopathy, there were no clear differences in estimates for improvement in pain or function, likelihood of a successful pain or functional outcome, or likelihood of undergoing surgery when trials were stratified according to the type of placebo intervention
Effects of type of control intervention in patients with radiculopathy: All outcomes | Insufficient | Trials of epidural corticosteroid injections vs. other interventions were too limited to determine effects on outcome estimates, due to variability in the interventions evaluated, small numbers of trials, and methodological limitations
Effects of type of placebo intervention in patients with other back conditions: All outcomes | Insufficient | There was insufficient evidence from trials of epidural corticosteroid injections for spinal stenosis, nonradicular back pain, or chronic postsurgical pain, to determine effects of comparators on estimates of effect, due to small numbers of trials for specific comparisons
Facet joint injections
Effects of type of placebo therapy: | Insufficient | There was insufficient evidence from trials facet joint injections to determine effects of comparators on estimates of effect, due to small numbers of trials for specific comparisons
Key Question 3a. How do response rates vary according to the specific comparator evaluated (e.g., saline epidural, epidural with local anesthetic, nonepidural injection, no injection, surgery, nonsurgical therapies)?
Epidural injections for radiculopathy
Epidural corticosteroid injections vs. placebo interventions (direct comparisons): Pain, function, successful outcome | Low | Three trials found no differences between epidural local anesthetic vs. epidural saline injections (3 trials) or soft tissue injections (2 trials) in mean improvements in pain or function or the proportion experiencing pain relief or a successful outcome
Epidural corticosteroid injections vs. placebo interventions (indirect comparisons): Pain function | Low | In trials of epidural corticosteroid injections for radiculopathy, improvement in pain was smaller in patients who received epidural local anesthetic injections (3 trials, WMD −6.51, 95% CI −11.9 to −1.16, I2=45%) than epidural saline injections (4 trials, WMD −19.8, 95% CI −25.1 to −14.3, I2=56%) at immediate-term followup; there were no clear differences at other time points, but analyses were limited by small numbers of trials and statistical heterogeneity
Epidural corticosteroid injections vs. other interventions: Pain, function | Insufficient | Trials were too limited to determine effects on response rates, due to variability in the interventions evaluated, small numbers of trials, and methodological limitations
Key Question 4. What are the harms of epidural corticosteroid, facet joint corticosteroid injections, medial branch blocks, and sacroiliac joint corticosteroid injection compared to epidural nonsteroid injection, nonepidural injection, no injection, surgery, or nonsurgical therapies?
Epidural injections
Harms | Moderate | 29 trials of epidural corticosteroid injections vs. placebo for radiculopathy reported no serious adverse events and few harms, but methods for assessing harms were not well reported and harms data were sparse. Observational studies were consistent with the trials in showing a low risk of serious adverse events
Harms | Moderate | Nine trials of epidural corticosteroid injections vs. other therapies for radiculopathy reported no serious adverse events and few harms
Harms | Low | Two trials of transforaminal vs. interlaminar epidural corticosteroid injections for radiculopathy reported no serious adverse events
Harms | Insufficient | There was insufficient evidence from four trials that compared epidural injections for radiculopathy with different corticosteroids to determine effects on harms
Harms | Insufficient | There was insufficient evidence from six trials of epidural corticosteroid injections for radiculopathy that compared different doses to determine effects on harms
Harms | Low | Eight trials of epidural corticosteroid injections vs. placebo injections for spinal stenosis reported no serious harms and few adverse events, but methods for assessing harms were not well reported and harms data were sparse
Harms | Low | Two trials of epidural corticosteroid injections for nonradicular back pain reported no serious harms
Harms | Insufficient | There was insufficient evidence from four trials of epidural corticosteroid injections for chronic postsurgical back pain to determine effects on harms
Facet joint injections
Harms | Low | Ten trials of facet joint corticosteroid injections reported no serious harms and few adverse events, but methods for assessing harms were not well reported and harms data sparse
Sacroiliac joint injections
Harms | Insufficient | Harms were not reported in one small trial of peri-articular sacroiliac joint injections

CI, confidence interval; MILD, minimally invasive lumbar decompression; ODI, Oswestry Disability Index; RR, relative risk; SF-36, Short Form-36; SMD, standardized mean difference; SPECT= single photon electronic computed tomography; WMD, weighted mean difference.

Evidence was most robust for epidural corticosteroid injections in patients with radiculopathy. In trials of epidural corticosteroid injections versus placebo interventions, the only statistically significant effects were on mean improvement in pain at immediate-term (5 days to ≤2 weeks) followup (weighted mean difference [WMD] −7.55 on a 0 to 100 scale, 95% confidence interval [CI] −11.4 to −3.74), mean improvement in function at immediate-term followup (standardized mean difference [SMD] −0.33, 95% CI −0.56 to −0.09), and risk of surgery at short-term (>2 weeks to ≤3 months) followup (RR 0.62, 95% CI 0.41 to 0.92). However, the magnitude of the effect on pain was small (WMD −7.55 on 0 to 100 scale) and did not meet our predefined minimum clinically important differences of 15 points.42 The effect on immediate-term function was only statistically significant when an outlier trial107 was excluded. Differences were also small in the nonoutlier trials (5.1 and 7.6 points on the 0 to 100 Oswestry Disability Index [ODI]56, 81 and 1.3 points on the 0 to 24 Roland Morris Disability Questionnaire [RDQ]) and did not meet predefined thresholds for minimum clinically important differences (10 points for the ODI and 5 points for the RDQ).42 Differences were not present for either outcome at longer-term followup. There were also no differences at any time point between epidural corticosteroid injections and placebo interventions in likelihood of experiencing a successful pain, function, or composite outcome; or likelihood of undergoing surgery. Direct evidence from randomized trials on effects of performing epidural corticosteroid injections for radiculopathy using different approaches, different corticosteroids, or different doses was limited, but indicated no clear effects on outcomes. There were also no clear differential effects of the epidural approach used, different corticosteroids, different doses, year of publication, use of imaging correlation, restriction to patients with herniated disc, duration of symptoms, or exclusion of patients with prior surgery, primarily based on meta-regression and subgroup analyses.

Although comparator interventions such as epidural local anesthetic injection, epidural saline injection, soft tissue injections, and no injection have traditionally been considered placebo interventions, it is possible that they may have some therapeutic effects.35 However, placebo response rates were high in trials of epidural corticosteroid injections regardless of the comparator used and there were no clear differences in estimates of effectiveness based on the specific comparator, suggesting that observed improvements represent the natural history of radiculopathy or a general placebo response.

Trials of epidural corticosteroid injections for radiculopathy versus nonplacebo interventions did not clearly demonstrate effectiveness, but were limited by small numbers of trials for specific comparisons and methodological limitations, resulting in low or insufficient strength of evidence ratings. Evidence was limited for epidural corticosteroid injections versus placebo interventions for spinal stenosis or nonradicular back pain, but showed no differences in outcomes related to pain or function. The evidence on epidural corticosteroid injections for spinal stenosis included a recent, well-conducted multicenter trial that was also the largest trial (n=386) to date in this population.117 Although epidural injections could be performed by either the interlaminar or transforaminal approach in this trial, there was also no evidence of an effect when results were stratified according to the approach used. Another potential issue in interpreting this trial is that the corticosteroids and doses varied, which could have attenuated effects if certain corticosteroids or lower doses are associated with decreased effectiveness. For chronic postsurgical pain, evidence was very limited. No trial compared epidural corticosteroid injections versus placebo, and trials of epidural corticosteroid injections versus various other interventions found no clear differences.

Evidence was also limited for facet joint corticosteroid injections versus placebo interventions. Studies found no clear differences between various facet joint corticosteroid injections (intra-articular, extra-articular [peri-capsular], or medial branch) and placebo interventions. Although one trial found an intra-articular corticosteroid injection associated with better outcomes than a saline injection at 6 months, results are difficult to interpret because there were no differences at 1 month, the corticosteroid group received more cointerventions, and there was no difference in the likelihood of sustained improvement (improvement at 6 months in patients with improvement at 1 month).141 Trials of facet joint injections versus radiofrequency denervation were difficult to interpret because they reported inconsistent outcomes, evaluation of different types of injections (intra-articular or medial branch corticosteroid injection), and differential use of diagnostic blocks to select patients, depending on which intervention they were randomized to.142, 145

There was insufficient evidence from one very small (n=24) trial to determine effects of peri-articular sacroiliac joint corticosteroid injections versus a placebo (local anesthetic) injection.145

Methods for assessing harms in randomized trials were generally not well-reported and data sparsely reported, but evidence from trials and observational studies were consistent in suggesting a low risk of serious harms following epidural injections such as neurological complications or infection. However, cases of serious neurological complications have been reported following lumbar epidural injections, and there was a recent outbreak of serious fungal infections due to contaminated methylprednisolone injections.17, 161, 162

## Findings in Relationship to What is Already Known

Our findings were consistent with a previous qualitative review17 conducted by our team and funded by the American Pain Society (APS) that found fair evidence that epidural corticosteroid injections for radiculopathy are more effective than placebo interventions for short-term symptom relief, but not for long-term symptom relief, and limited evidence of ineffectiveness for spinal stenosis and nonradicular low back pain. Unlike the current review, which found that short-term effects on pain did not meet the threshold for minimum clinically important differences, the APS review classified the magnitude of short-term benefit for pain relief as “moderate” (equivalent to a 10 to 20 point difference on a 100 point pain scale). However, it noted inconsistency between trials, did not perform meta-analysis, and based some conclusions on prior reviews with small numbers of studies. Our findings were also consistent with more recent qualitative and quantitative systematic reviews, despite variability in the studies included and methods used for data synthesis and meta-analysis.20, 21, 23, 37, 163, 164 Our review was also concordant with other reviews in finding limited evidence that lumbar epidural corticosteroid injections are associated with a low risk of serious harms.17, 20, 161 Like a prior review, we also found no evidence on effectiveness of multiple versus single injections.165 Although one systematic review found an association between volume differences (higher volume relative to control interventions) and effectiveness of epidural corticosteroid injections, results may have been confounded by differences in epidural approaches (e.g., caudal injections typically used higher volumes) and inclusion of comparators that did not involve epidural injections (e.g., soft tissue injections or noninjection therapies).166 We were unable to determine effects of differences in injectate volume on effectiveness, as only three trials that compared epidural corticosteroid injections versus epidural local anesthetic or saline injections reported a volume difference.62, 107, 109

With regard to effects of control interventions on effect estimates, our findings were similar to a recent systematic review that found limited direct evidence showing no differences between epidural nonsteroid and nonepidural injections.35 Although the prior systematic review found some evidence that epidural nonsteroid injections might be more effective than nonepidural injections, its conclusions were based on indirect comparisons that were highly discrepant with direct comparisons. We did not perform indirect comparisons, as the presence of such discrepancies may result in misleading findings.167 Although the prior APS review found some evidence that effects of epidural corticosteroid injections were more likely to be positive in studies that used epidural nonsteroid injection controls than in studies that used nonepidural injection controls, these findings were based on a qualitative evaluation based on counts of positive and negative studies.17

Our findings of limited evidence on facet joint corticosteroid injections versus placebo interventions, without clear demonstration of beneficial effects, were also consistent with prior systematic reviews.17, 168, 169

Some systematic reviews reported more positive conclusions regarding the effectiveness of epidural corticosteroid and facet joint injections.24–26, 170–172 Differences between the methods used in these reviews and ours that may explain the discrepant findings include reliance on qualitative synthesis, inclusion of observational studies, categorization of improvement from baseline following an epidural corticosteroid injection as demonstrating effectiveness (even when there was no difference versus a placebo intervention), and failure to consider inconsistency between trials.

## Applicability

Some issues could impact the applicability of our findings. Results are most applicable to patients with chronic back pain, as few trials enrolled patients with acute or subacute symptoms. Although studies were typically performed in the United States or Europe in specialty settings, they varied in how the injections were performed, including the use of imaging guidance, the specific epidural or facet injection technique used, the methods used to select patients (e.g., use of imaging, the imaging findings required for inclusion, or the use of diagnostic blocks), the types and doses of corticosteroid used, and the number and frequency of injections. Although we found no clear evidence of an association between these factors and estimates of treatment effectiveness, direct evidence from head-to-head trials on these factors was limited. The effectiveness of injection therapies is also likely to depend in part on the skill and experience of the person performing the injection, but we were unable to determine effects of provider experience on treatment effects, as studies did not report this information or reported it in a nonstandardized manner. Because most trials excluded patients with prior lumbar surgery, results may not be applicable to this patient population. The applicability of findings to patients with important medical and psychiatric comorbidities was also uncertain, and there was insufficient evidence to determine how effectiveness might vary based on the receipt of concomitant interventions such as supervised exercise therapy or cognitive behavioral therapy. Trials also differed in methods used to select patients for inclusion. For example, trials of radiculopathy and spinal stenosis differed in the clinical symptoms required for enrolment as well as in whether concordant imaging findings were required, and trials of presumed facet joint pain varied in whether a positive response to diagnostic blocks were required as well as methods for performing blocks (e.g., single or double block).

In order to facilitate interpretation of findings, we stratified outcomes by followup duration. We also compared observed effects on continuous outcomes to previously proposed thresholds for minimum clinically important changes. Although immediate-term effects of epidural corticosteroid injections versus placebo interventions on improvement in pain scores were statistically significant, they did not meet the predefined threshold for a minimum clinically important difference.42 We also evaluated effects of injection therapies on the likelihood of experiencing a clinically meaningful outcome, which might be more clinically interpretable than mean effects on continuous scales.173 Although trials varied in how they defined clinically meaningful outcomes related to pain, function, or overall success, analyses were consistent in showing no effects at different time points.

## Implications for Clinical and Policy Decisionmaking

Our review has implications for clinical and policy decisionmaking. Epidural corticosteroid injections are the most commonly used interventional procedure for low back pain, but evidence indicates that benefits are limited to pain relief and reduced risk of surgery shortly after the procedure in patients with radiculopathy, without long-term benefits on these outcomes, and no effect on functional outcomes. Some clinical practice guidelines recommend epidural corticosteroid injections for short-term benefits in patients with persistent radicular symptoms, particularly for patients who are not candidates for, or interested in, undergoing surgery.28 Factors that may influence decisions about performing epidural corticosteroid injections include how highly patients value short-term symptom improvement of small magnitude, preferences regarding alternative therapies (including surgery), the severity of symptoms, and costs and other burdens. Decisions should also consider the risk of serious harms with epidural injections, which have been reported in case series and other uncontrolled observational studies.174

Potential strategies to enhance the effectiveness of epidural injections would be to perform them using techniques shown to be more effective, or to selectively perform injections in patients more likely to benefit. However, our review found no clear evidence of greater benefits based on technical factors such as the specific epidural technique used, use of fluoroscopic guidance, the specific corticosteroid, the dose, or the number or frequency of injections. Evidence on patient factors was also too limited to identify subgroups of patients more likely to benefit.

Other findings of our review that have implications for clinical and policy decisionmaking included limited evidence of no effectiveness of epidural corticosteroid injections for spinal stenosis or nonradicular low back pain, or for facet joint corticosteroid injections for presumed facet joint pain. Although prior guidelines found insufficient evidence to develop recommendations on use of epidural corticosteroid injections for spinal stenosis and nonradicular low back pain,28 the strength of evidence has improved, particularly for spinal stenosis,117 suggesting that re-evaluation may be appropriate. Guidelines are inconsistent with regard to use of facet joint corticosteroid injections,28, 175, 176 but recent trials have not provided additional evidence to support effectiveness.

## Limitations of the Comparative Effectiveness Review Process

An important limitation of our review is that substantial statistical heterogeneity was present in several pooled analyses. To address this, we used the Dersimonian-Laird random effects model to pool studies. The Dersimonian-Laird random effects model may result in confidence intervals that are too narrow when heterogeneity is present, particularly when the number of studies is small.46 Therefore, we repeated analyses using the profile likelihood method, which resulted in similar findings. Regardless of the method used, meta-analyses based on small numbers of trials can underestimate statistical heterogeneity and must be interpreted with caution.46 We also stratified trials according to the epidural technique used, and further explored heterogeneity by performing additional analyses stratified based on the comparator used, exclusion of poor-quality and outlier studies, and meta-regression (when sufficient numbers of studies were available) on use of blinding, patient selection methods, and methods used to perform the injections (e.g., the corticosteroid or local anesthetic used and the dose). Although statistical heterogeneity remained present in some analyses, with some unexplained outlier trials, results were generally robust in sensitivity and stratified analyses.

Another limitation of our review is that we used indirect comparisons to supplement limited direct evidence on the effects of technical and patient factors on estimates. Although findings based on indirect comparisons were generally consistent with available evidence from head-to-head trials (e.g., showing no clear effects of different corticosteroids, different epidural approaches, or different doses), results based on indirect comparisons should also be interpreted with caution.177

We excluded non-English language articles and did not search for studies published only as abstracts. However, a systematic review found little empirical evidence that exclusion of non–English-language articles leads to biased estimates for noncomplementary or alternative medicine interventions,178 and we did not identify non-English language articles that would otherwise meet inclusion criteria in literature searches or reviews of reference lists. We formally assessed for publication bias using statistical and graphical methods to assess for small sample effects when there were at least 10 studies, as research indicates that such methods can be misleading with smaller numbers of studies.47 We found no evidence of small sample effects based on analyses of short-term improvement in pain, short-term improvement in function, or long-term risk of surgery. Finally, we restricted evidence on serious harms to randomized controlled trials and large cohorts of patients undergoing injections, in order to be able to estimate rates of events. Although serious neurological events with epidural corticosteroid injections have been reported in case series and other uncontrolled studies, it is not possible to estimate the rates of events from such data.174

## Limitations of the Evidence Base

An important limitation of the evidence base is the small number of trials available on epidural corticosteroid injections for conditions other than radiculopathy and the small number on effectiveness of facet joint or sacroiliac corticosteroid injections. The lack of evidence made it difficult to reach strong conclusions regarding the effectiveness of these interventions versus placebo interventions or to evaluate effects of methodological, technical, or patient factors on outcomes. Although more trials were available for epidural corticosteroid injections for radiculopathy, there were fewer trials when results were stratified by specific outcomes and time points, and subgroup analyses were limited by the variability in techniques used on a number of factors.

In addition to the small number of trials, the evidence base was limited by methodological limitations in the available studies. Only eight trials were rated good quality. Of the 92 included trials, only 27 trials reported blinding of the person performing the injection, 57 trials blinding of patients, and 47 trials blinding of outcome assessors. Conclusions were generally not impacted by exclusion of poor-quality trials or assessments based on blinding status, but would be stronger if more high-quality trials were available.

Other limitations include the relatively limited number of trials that directly compared different injection techniques, corticosteroids, doses, and comparators. No trials directly compared use of imaging guidance versus no guidance, use of a single injection versus multiple injections, or effects of different injectate volumes. Few trials reported how effectiveness varied according to patient characteristics such as age, sex, race, medical or psychological comorbidities, duration of symptoms, imaging findings, cause of low back pain, use of concomitant therapies, or other factors.

## Research Gaps

Research gaps limit the full understanding of the comparative effectiveness of low back injections. For radiculopathy, additional research could help determine whether patient characteristics such as severity or duration of symptoms, presence of specific imaging findings, or presence of psychiatric comorbidities are associated with responsiveness to injections. If such characteristics are identified, future trials could be designed to focus on more specific target populations that might experience greater benefits. Trials are also needed to understand whether injections may be more effective when given in the context of a more comprehensive approach that includes the delivery of concomitant treatments such as supervised exercise therapy or cognitive behavioral therapy. Additional research would also help confirm whether there are differences in outcomes associated with different epidural injection approaches (including newer approaches such as the lateral parasagittal interlaminar approach), corticosteroids, doses, use of imaging guidance, and number and frequency of injections. Ideally such studies would include a placebo intervention group to aid in interpretability of findings.

For spinal stenosis and nonradicular low back pain, evidence was limited but indicated that epidural corticosteroid injections are not effective compared to placebo interventions. Because spinal stenosis is usually degenerative and the etiology of nonradicular low back pain may be difficult to determine, the rationale for performing epidural corticosteroid injections may not be as strong as for radiculopathy due to herniated disc. Additional research on the effectiveness of epidural corticosteroid injections for these conditions may only be warranted if specific subgroups of patients who have more of an inflammatory component can be identified.

Limited evidence also indicates that facet joint corticosteroid injections are not effective compared with placebo interventions. The lack of effectiveness could be due to the ineffectiveness of the procedure or suboptimal accuracy methods for identifying patients with facet joint pain.17 A randomized trial found that use of dual or single diagnostic facet joint blocks to select patients for radiofrequency denervation (an intervention not included in this report) was associated with lower rates of successful outcomes than selection of patients without a diagnostic block.179 Therefore, additional research on accurate methods for identifying patients with facet joint pain is needed to inform the design of future intervention studies.