# Conclusions

Epidural corticosteroid injections for radiculopathy are associated with immediate improvements in pain and might be associated with immediate improvements in function, but benefits are small and not sustained, and there is no effect on the long-term risk of surgery. Evidence did not suggest that effectiveness varies based on injection technique, corticosteroid, dose, or comparator. Limited evidence suggested that epidural corticosteroid injections are not effective for spinal stenosis or nonradicular back pain, and that facet joint corticosteroid injections are not effective for presumed facet joint pain. There was insufficient evidence to evaluate the effectiveness of sacroiliac joint corticosteroid injections.