# Strength of Evidence

Key Question Outcome | | Study Design Number of Studies (N) | Risk of bias | Consistency | Directness | Precision | Strength of Evidence | Conclusion
Key Question 1. In patients with low back pain, what is the effectiveness of epidural corticosteroid injections, facet joint corticosteroid injections, medial branch blocks, and sacroiliac joint corticosteroid injections versus epidural nonsteroid injection, nonepidural injection, no injection, surgery or non-surgical therapies on outcomes related to pain, function and quality of life?
Epidural injections for radiculopathy
Epidural corticosteroid injections versus placebo interventions
Mean improvement in pain, immediate-term | | 6 trials N=701 | Moderate | No serious inconsistency | Direct | Precise | Moderate | Epidural corticosteroid injections associated with greater improvement versus placebo interventions (6 trials, WMD −7.55 on 0 to 100 scale, 95% CI −11.4 to −3.74, I2=30%)
Mean improvement in pain, short-term | | 14 trials N=1537 | Moderate | Inconsistent | Direct | Precise | Low | No difference (14 trials, WMD −3.94, 95% CI −9.11 to 1.24, I2=82%)
Mean improvement in pain, intermediate-term | | 4 trials N=436 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference (4 trials, WMD 0.07, 95% CI −8.41 to 8.26, I2=82%)
Mean improvement in pain, long-term | | 6 trials N=767 | Moderate | Consistent | Direct | Precise | Moderate | No difference (6 trials, WMD −0.86, 95% CI −3.78 to 2.06, I2=0%)
Successful pain outcome, short-term | | 8 trials N=897 | Moderate | Inconsistent | Direct | Precise | Low | No difference (8 trials, RR 1.21, 95% CI 0.98 to 1.49, I2=67%)
Successful pain outcome, intermediate-term | | 3 trials N=298 | Moderate | Inconsistent | Direct | Precise | Low | No difference (3 trials, RR 1.12, 95% CI 0.93 to 1.36, I2=41%)
Successful pain outcome, long-term | | 4 trials N=504 | Moderate | Consistent | Direct | Precise | Moderate | No difference (4 trials, RR 1.10, 95% CI 0.94 to 1.28, I2=0% )
Mean improvement in function, immediate-term | | 4 trials N=464 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference, based on all trials (4 trials, SMD −0.75, 95% CI −1.62 to 0.11, I2=94%). Excluding an outlier trial eliminated statistical heterogeneity and resulted in a statistically significant effect favoring epidural corticosteroid injections (3 trials, SMD −0.33, 95% CI −0.56 to −0.09, I2=0%)
Mean improvement in function, short-term | | 11 trials N=1226 | Moderate | Inconsistent | Direct | Precise | Moderate | No difference (11 trials, SMD −0.03, 95% CI −0.20 to 0.15, I2=53%)
Mean improvement in function, intermediate-term | | 5 trials N=619 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference (5 trials, SMD −0.30, 95% CI −0.74 to 0.15, I2=86%)
Mean improvement in function, long-term | | 8 trials N=950 | Moderate | Inconsistent | Direct | Precise | Low | No difference (7 trials, SMD −0.23, 95% CI −0.55 to 0.10, I2=82%)
Successful functional outcome, short-term | | 6 trials N=873 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference (6 trials, RR 1.01, 95% CI 0.74 to 1.38, I2=76%)
Successful functional outcome, intermediate-term | | 2 trials N=240 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference (2 trials, RR 1.18, 95% CI 0.89 to 1.57, I2=71%)
Successful functional outcome, long-term | | 3 trials N=468 | Moderate | Consistent | Direct | Precise | Low | No difference (3 trials, RR 1.15, 95% CI 0.97 to 1.35, I2=0%)
Risk of surgery, short-term | | 5 trials N=845 | Moderate | Consistent | Direct | Imprecise | Low | Epidural corticosteroid injections were associated with lower risk versus placebo interventions (8 trials, RR 0.62, 95% CI 0.41 to 0.92, I2=0%), but the estimate was no longer statistically significant after exclusion of poor-quality trials (5 trials, RR 0.69, 95% CI 0.42 to 1.13, I2=0%)
Risk of surgery, intermediate-term | | 1 trial N=36 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | No difference (1 trial, RR 0.56, 95% CI 0.12 to 2.68)
Risk of surgery, long-term | | 14 trials N=1208 | Moderate | Consistent | Direct | Precise | Moderate | No difference (14 trials, RR 0.97, 95% CI 0.75 to 1.25, I2=23%)
Successful composite outcome, short-term | | 9 trials N=604 | Moderate | Consistent | Direct | Precise | Moderate | No difference (9 trials, RR 1.13, 95% CI 0.98 to 1.32, I2=3.5%)
Successful composite outcome, intermediate-term | | 1 trial N=58 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | No difference (1 trial, RR 0.71, 95% CI 0.34 to 1.48)
Successful composite outcome, long-term | | 2 trials N=153 | Moderate | Consistent | Direct | Imprecise | Low | No difference (2 trials, 1.04, 95% CI 0.81 to 1.34, I2=0%)
Epidural corticosteroid injections versus other interventions
Pain, function, surgery | | 2 trials N=150 | High | Inconsistent | Direct | Imprecise | Insufficient | There was insufficient evidence from two trials to determine effects of epidural corticosteroid injections versus discectomy, due to methodological shortcomings in the trials
Pain function, surgery | | 1 trial N=90 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found epidural corticosteroid injections associated with lower likelihood than minimally invasive lumbar decompression of achieving ≥ 25 point improvement in leg pain (RR 0.49, 95% CI 0.24 to 1.0), ≥13 point improvement in ODI (RR 0.34, 95% CI 0.34 to 0.95), and ≥5 point improvement in SF-36 (RR 0.34, 95% CI 0.12 to 0.95) through 2 years. There was no difference in risk of undergoing surgery (RR 0.45, 95% CI 0.09 to 2.19)
Pain, function, surgery | | 1 trial N=26 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Insufficient | There was insufficient evidence from one small, fair-quality trial to determine effects of epidural corticosteroid injections versus epidural clonidine injection
Pain, function, analgesic use | | 1 trial N=132 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found transforaminal epidural corticosteroid injection superior to etanercept on the ODI at 1 month (difference −16 on 0 to 100 scale, 95% CI −26.0 to −6.27). There were no differences on other outcomes, including pain and analgesic use
Pain, function | | 1 trial N=72 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no differences between epidural corticosteroid versus autologous conditioned serum administered via the oblique interlaminar approach in improvement in pain or ODI scores after 22 weeks
Pain, function, surgery | | 2 trials N=151 | High | Inconsistent | Direct | Imprecise | Insufficient | There was insufficient evidence from two trials to determine effects of epidural corticosteroid injections versus non-surgical, non-interventional therapies due to methodological shortcomings in the trials and differences in the non-surgical, non-interventional therapies evaluated
Pain, function | | 1 trial N=53 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found transforaminal epidural corticosteroid injection with corticosteroid plus hypertonic saline associated with greater decrease in pain intensity through 4 months than a corticosteroid injection alone (difference from baseline −2.78 vs. −1.50 on 0 to 10 NRS, p=0.05), though the effect was smaller and no longer statistically significant at 6 months. There were no differences in global assessment or the ODI
Pain, function | | 1 trial N=177 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no difference between transforaminal epidural injection with corticosteroid versus corticosteroid plus low-dose clonidine in pain scores through 12 weeks in patients with subacute low back pain
Epidural injections for spinal stenosis
Epidural corticosteroid injections versus placebo interventions
Mean improvement in pain, immediate-term | | 1 trial N=29 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | Epidural corticosteroid injection was superior to placebo at intermediate-term (1 trial, WMD −22.0, 95 % −36.0 to −8.0)
Mean improvement in pain, short-term | | 5 trials N=615 | Moderate | Consistent | Direct | Precise | Moderate | No difference (5 trials, WMD 0.62, 95% CI −2.87 to 4.11, I2=0%)
Mean improvement in pain, intermediate-term | | 3 trials N=179 | Moderate | Consistent | Direct | Imprecise | Low | No difference (3 trials, WMD 3.73, 95% CI −0.81 to 8.26, I2=0%)
Mean improvement in pain, long-term | | 1 trial N=100 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | No difference (1 trial, mean difference 4.00, 95% CI −2.87 to 10.9)
Successful pain outcome, short-term | | 3 trials N=546 | Moderate | Consistent | Direct | Imprecise | Low | No difference (3 trials, RR 0.98, 95% CI 0.84 to 1.15, I2=0%)
Successful pain outcome, intermediate-term | | 2 trials N=160 | Moderate | Consistent | Direct | Imprecise | Low | No difference (2 trials, RR 0.98, 95% CI 0.78 to 1.24, I2=0%)
Successful pain outcome, long-term | | 3 trials N=197 | Moderate | Consistent | Direct | Imprecise | Low | No difference (3 trials, RR 0.97, 95% CI 0.74 to 1.28, I2=0%)
Mean improvement in function, immediate-term | | 2 trials N=55 | Moderate | Consistent | Direct | Imprecise | Low | No difference (2 trials, SMD −0.32, 95% CI −0.85 to 0.22, I2=0%)
Mean improvement in function, short-term | | 5 trials N=615 | Moderate | Consistent | Direct | Precise | Moderate | No difference (5 trials, SMD −0.03, 95% CI −0.31 to 0.26, I2=60%)
Mean improvement in function, intermediate-term | | 3 trials N=179 | Moderate | Consistent | Direct | Imprecise | Low | No difference (3 trials, WMD 2.81, 95% CI −0.44 to 6.06, I2=0%)
Mean improvement in function, long-term | | 2 trials N=160 | Moderate | Consistent | Direct | Imprecise | Low | No difference (2 trials, WMD 2.78, 95% CI −1.24 to 6.79, I2=0%)
Successful functional outcome, short-term | | 3 trials N=546 | Moderate | Consistent | Direct | Imprecise | Low | No difference (3 trials, RR 0.91, 95% CI 0.70 to 1.18, I2=37%)
Successful functional outcome, intermediate-term | | 2 trials N=160 | Moderate | Consistent | Direct | Imprecise | Low | No difference (2 trials, RR 0.96, 95% CI 0.74 to 1.25, I2=0%)
Successful functional outcome, long-term | | 2 trials N=160 | Moderate | Consistent | Direct | Imprecise | Low | No difference (2 trials, RR 0.95, 95% CI 0.71 to 1.26, I2=0%)
Successful composite outcome, short-term | | 2 trials N=136 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference (2 trials, RR 1.18, 95% CI 0.55 to 2.55, I2=80%)
Successful composite outcome, intermediate-term | | 1 trial N=100 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | No difference (1 trial, RR 0.93, 95% CI 0.63 to 1.35)
Successful composite outcome, long-term | | 2 trials N=130 | Moderate | Consistent | Direct | Imprecise | Low | No difference (2 trials, RR 1.16, 95% CI 0.76 to 1.78, I2=0%)
Risk of surgery, long-term | | 1 trial N=30 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | No difference (1 trial, RR 0.76, 95% CI 0.38 to 1.54)
Epidural corticosteroid injections versus other interventions
Pain, function | | 1 trial N=38 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found an epidural corticosteroid injection associated with lower likelihood of experiencing >2 point improvement in pain at 2 weeks versus the minimally invasive lumbar decompression procedure, but the difference was no longer present at 6 weeks. There was no difference in function
Pain, function | | 1 trial N=23 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no differences between and epidural corticosteroid injection versus intense physical therapy in pain intensity or functional outcomes at 2 weeks through 6 months
Pain, function | | 1 trial N=80 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found epidural corticosteroid injection associated with worse leg pain than epidural etanercept injection at 1 month, with no difference in functional outcomes
Pain, function | | 1 trial N=50 | High | Cannot determine (1 trial) | Direct | Imprecise | Insufficient | There was insufficient evidence from one poor-quality trial to determine effects of epidural corticosteroid injections versus epidural adhesiolysis
Epidural corticosteroid injections versus placebo interventions for non-radicular low back pain
Pain, function, opioid use | | 2 trials N=240 | Moderate | Consistent | Direct | Imprecise | Low | Two trials found no differences between epidural corticosteroid injections and epidural local anesthetic injections in pain, function, or opioid use
Epidural injections for chronic post-surgical pain
All outcomes | | 0 trials | No evidence | No evidence | No evidence | No evidence | Insufficient | No trial compared an epidural injection with corticosteroid versus a placebo intervention
All outcomes | | 5 trials N=274 | High | Inconsistent | Direct | Imprecise | Insufficient | Evidence from 5 trials was insufficient to determine effects of epidural corticosteroid injections versus other interventions, due to methodological limitations, differences in the comparators evaluated, and small sample sizes
Facet joint injections
Pain, function | | 2 trials N=171 | Moderate | Consistent | Direct | Imprecise | Low | Two trials found no clear differences between an intra-articular facet joint injection with corticosteroid versus saline in pain or function at one to three months
All outcomes | | 1 trial N=67 | High | Cannot determine (1 trial) | Direct | Imprecise | Insufficient | Evidence from one small, poor-quality trial was insufficient to determine effects of an intra-articular corticosteroid facet joint injection versus medial branch local anesthetic injection
All outcomes | | 1 trial N=81 | High | Cannot determine (1 trial) | Direct | Imprecise | Insufficient | Evidence from one poor-quality trial was insufficient to determine effects of an extra-articular facet joint corticosteroid injection versus intra-articular saline injection
Pain, function, opioid use | | 2 trials N=204 | Moderate | Consistent | Direct | Imprecise | Low | Two trials found no differences between medial branch corticosteroid injection versus medial branch local anesthetic injection in pain, function, or opioid use through 12 to 24 months
Pain, function, quality of life | | 1 trial N=60 | Low | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no clear differences between an intra-articular facet joint versus an intramuscular corticosteroid injection in pain, function, or quality of life through 6 months
Pain, function, quality of life | | 1 trial N=60 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no differences between intra-articular facet injection with triamcinolone acetonide versus hyaluronic acid in pain or function at 1 month or in health-related quality of life at 1 week
Pain, function, analgesic use | | 1 trial N=56 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no differences between intra-articular corticosteroid injection plus sham neurotomy versus medial branch radiofrequency facet neurotomy plus local anesthetic injection in pain, function, or analgesic use at six months
Pain, quality of life | | 1 trial N=100 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One fair-quality trial found medial branch corticosteroid injection inferior to radiofrequency facet denervation on pain at 1, 6, and 12 months, with no differences in quality of life (1, 6, and 12 months), but results may have been confounded by differential use of diagnostic blocks to select patients for inclusion
Sacroiliac joint injections
All outcomes | | 1 trial N=24 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Insufficient | There was insufficient evidence from one small (n=24) trial to determine effects of periarticular sacroiliac corticosteroid injection versus local anesthetic injection
Key Question 1a. How does effectiveness vary according to the medication (corticosteroid, local anesthetic) used, the dose or frequency of injections, the number of levels treated, or degree of provider experience?
Epidural injections
Epidural corticosteroid injections for radiculopathy
Effects of different corticosteroids: all outcomes | | 4 trials^a^ N=329 | Moderate | Inconsistent | Direct | Imprecise | Low | Four trials that directly compared epidural corticosteroid injections for radiculopathy with different corticosteroids found few differences in outcomes including pain and function, but conclusions were limited by differences in the corticosteroids compared, doses, and some inconsistency
Effects of different local anesthetics: all outcomes | | 0 trials^a^ | No direct evidence | No direct evidence | Indirect | No direct evidence | Insufficient | No trial directly compared effects of epidural corticosteroid injections with one local anesthetic versus another
Effects of corticosteroid dose: all outcomes | | 6 trials^a^ N=506 | Moderate | Consistent | Direct | Imprecise | Low | Six trials that directly compared epidural injections for radiculopathy using different corticosteroid doses found no clear differences in outcomes including pain and function
Effects of number of injections, number of levels injected, or provider experience: all outcomes | | 2 trials N=334 | Moderate | Consistent | Indirect | Imprecise | Low for number of injections, insufficient for number of levels and provider experience | No trial directly compared the effectiveness of epidural corticosteroid injections based on the number of injections, number of levels injected, or provider experience. Two trials found no association between receipt of more injections and better outcomes
Epidural corticosteroid injections for spinal stenosis
Effects of corticosteroids: pain, claudication distance | | 1 trial N=70 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no clear differences between caudal epidural injection for spinal stenosis with methylprednisolone versus triamcinolone in pain or claudication distance through 6 months, though results favored methylprednisolone
Facet joint injections
Effects of different corticosteroids, local anesthetics, doses, frequency or number of injections, or degree of provider experience | | 0 trials^a^ | No direct evidence | No direct evidence | Indirect | No direct evidence | Insufficient | No trial of facet joint injections directly compared effects of different corticosteroids, different local anesthetics, different doses, different frequency or number of injections, or degree of provider experience. Indirect evidence was too limited to reach reliable conclusions
Key Question 1b. How does effectiveness vary according to use of imaging guidance or route of administration (e.g., for epidural injections interlaminar, transforaminal, caudal for epidural injections and for facet joint injections intra-articular, extra-articular [pericapsular] or medial branch injections)?
Epidural injections
Use of imaging
Effects of imaging guidance versus no imaging guidance: All outcomes | | 0 trials^a^ | No direct evidence | No direct evidence | Indirect | No direct evidence | Insufficient | No trial directly compared the effectiveness of epidural injections for radiculopathy performed with or without imaging guidance. Indirect evidence was not useful for evaluating effects of imaging guidance on estimates of effects because use of imaging guidance was highly associated with the epidural technique used
Effects of fluoroscopic plus Doppler versus fluoroscopic imaging guidance: Pain, function | | 1 trial N=110 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial of caudal epidural corticosteroid injections for radiculopathy found no difference between fluoroscopic plus Doppler guidance versus fluoroscopic guidance alone in pain or ODI scores through 12 weeks
Effects of imaging to guide epidural injection targets: Pain, function, medication use | | 1 trial N=132 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no difference between use of MRI versus history and physical examination without MRI to guide epidural corticosteroid injection treatment and targets on pain, function, or medication use
Transforaminal versus interlaminar corticosteroid injections^a^
Mean improvement in pain, immediate-term | | 5 trials N=227 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference (5 trials, WMD −10.1, 95% CI −24.8 to 4.63, I2=83%)
Mean improvement in pain, short-term | | 3 trials N=125 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference (3 trials, WMD −1.29, 95% CI −12.6 to 10.1, I2=54%)
Mean improvement in pain, intermediate-term | | 2 trials N=95 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference (2 trials, WMD −11.3, 95% CI −44.8 to 22.2, I2=87%)
Mean improvement in function, immediate-term | | 4 trials N=197 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference (4 trials, SMD 0.03, 95% CI −0.48 to 0.53, I2=68%)
Mean improvement in function, short-term | | 3 trials N=125 | Moderate | Inconsistent | Direct | Imprecise | Low | No difference (3 trials, SMD 0.39, 95% CI −0.36 to 1.13, I2=74%)
Mean improvement in function, long-term | | 1 trial N=64 | Low | Cannot determine (1 trial) | Direct | Imprecise | Low | No difference (1 trial, WMD −2.00, 95% CI −8.77 to 4.77)
Likelihood of undergoing surgery, intermediate-term | | 2 trials N=61 | Moderate | Inconsistent | Direct | Imprecise | Low | There were no differences between transforaminal versus interlaminar epidural corticosteroid injections for radiculopathy in risk of undergoing surgery at intermediate-term in two trials (RR 0.76, 95% CI 0.18 to 3.19 and RR 1.33, 95% CI 0.44 to 4.05)
Comparisons of other approaches
Epidural injections for radiculopathy
Caudal versus other approaches: Pain, function, depression | | 1 trial N=60 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found the transforaminal epidural corticosteroid injections for radiculopathy associated with better pain outcomes than the caudal approach, with no differences in measures of function or depression, but no differences between the interlaminar versus caudal approaches in measures of pain or depression
Oblique versus standard interlaminar approaches: Successful composite outcome, surgery | | 1 trial N=87 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no differences between epidural corticosteroid injections for radiculopathy using the oblique interlaminar versus standard interlaminar approaches in likelihood of achieving a successful outcome or undergoing surgery
Lateral parasagittal versus standard interlaminar approaches: Pain, function | | 2 trials N=143 | Moderate | Consistent | Direct | Imprecise | Low | One trial of epidural corticosteroid injections for radiculopathy found the lateral parasagittal interlaminar approach associated with greater likelihood of achieving >50% pain relief (RR 4.1, 95% CI 1.4 to 12) and greater improvement in pain and function than the standard interlaminar approach through 6 months; a second trial also reported results that favored the lateral parasagittal approach, but differences were smaller and not statistically significant
Lateral parasagittal versus transforaminal approaches: Pain | | 2 trials N=119 | Moderate | Consistent | Direct | Imprecise | Low | Two trials found no differences between epidural corticosteroid injections for radiculopathy using the lateral parasagittal versus transforaminal approaches in pain or function through 6 or 12 months
Ganglionic versus preganglionic transforaminal injections: Successful composite outcome | | 1 trial N=239 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found transforaminal epidural corticosteroid injections for radiculopathy at the ganglionic versus preganglionic approaches associated with a lower likelihood of a successful outcome at 1 month (RR 0.80, 95% CI 0.70 to 0.91), though differences were no longer present after 5 months
Epidural injections for spinal stenosis
Transforaminal versus interlaminar: Leg pain, function | | 1 trial (subgroup analysis) N=400 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | No trial randomized patients with spinal stenosis to different approaches for performing epidural corticosteroid injections. One trial in which epidural corticosteroid injections could be performed by the interlaminar or transforaminal approaches found that interlaminar corticosteroid injections were associated with greater improvement in leg pain and function versus local anesthetic injections at 3 weeks, but there were no differences between transforaminal corticosteroid versus local anesthetic injections
Facet joint injections
Intra-articular facet joint corticosteroid injection: Pain | | 1 trial N=46 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found intra-articular facet joint corticosteroid injection in patients with subacute low back pain selected on the basis of positive facet joint SPECT findings associated with lower pain intensity (3.2 vs. 5.4 on 0 to 10 NRS, p<0.05), greater likelihood of ≥50% pain relief (61% vs. 26%, RR 2.33, 95% CI 1.09 to 5.00), and better ODI score (12 vs. 23, p<0.05). versus medial branch injection at 12 weeks
Intra-articular facet joint versus medial branch corticosteroid injection for chronic low back pain (imaging findings not required): Pain | | 1 trial N=86 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found intra-articular facet joint corticosteroid injection associated with higher likelihood of pain relief versus medial branch injection at 1 month (RR 1.68, 95% CI 1.03 to 2.73), but results were no longer statistically significant at 3 months, and there was no difference in likelihood of experiencing good or excellent pain relief
Intra-articular versus extra-articular (pericapsular) facet joint corticosteroid injection: All outcomes | | 1 trial N=67 | High | Cannot determine (1 trial) | Direct | Imprecise | Insufficient | There was insufficient evidence from one poor-quality trial to determine effectiveness of intra- versus extra-articular (pericapsular) facet joint corticosteroid injections
Effects of imaging guidance versus no imaging guidance: All outcomes | | 0 trials | No evidence | No evidence | No evidence | No evidence | Insufficient | No trial directly compared the effectiveness of epidural injections for radiculopathy performed with or without imaging guidance
Effects of CT- versus ultrasound imaging guidance: Pain | | 1 trial N=40 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no difference between CT- versus ultrasound-guided intra-articular facet joint corticosteroid injections with betamethasone and local anesthetic in pain at 6 weeks
Key Question 2. In patients with low back pain, what patient characteristics predict responsiveness to injection therapies on outcomes related to pain, function, and quality of life?
Epidural injections
Effects of duration: Pain, function | | 6 trials N=869 | Moderate | Consistent | Indirect | Precise | Low | Five of six trials of patients with radiculopathy found no association between duration of symptoms and responsiveness to epidural corticosteroid injections
Effects of age, sex, anxiety/depression, opioid use, baseline function, presence of neurological abnormalities, previous episodes, or work status: Pain, function | | 6 trials N=869 | Moderate | Consistent | Indirect | Precise | Low | Trials or patients with radiculopathy found no association between age, sex, anxiety/depression, opioid use, baseline function, presence of neurological abnormalities, previous episodes, or work status and responsiveness to epidural corticosteroid injections
Effects of cause of radicular symptoms: Pain, function | | 4 trials N=406 | Moderate | Inconsistent | Indirect | Imprecise | Insufficient | There was insufficient evidence from 4 trials to determine effects of the cause of radicular symptoms on responsiveness to epidural corticosteroid injections for radiculopathy, due to inconsistent results
Effects of smoking status, body mass index, use of opioid therapies: Pain, function | | 0 trials | No evidence | No evidence | No evidence | No evidence | Insufficient | No study evaluated the association between smoking status, body mass index, or opioid therapies on responsiveness to epidural corticosteroid injection therapies for radiculopathy
Effects of pain, function | | 29 trials used in meta-regression analyses N=2792 | Moderate | Consistent | Indirect | Imprecise | Low | Based on meta-regression analyses of trials of epidural corticosteroid injections versus placebo interventions for radiculopathy, there was no clear association between prior lumbar surgery, requirement for imaging correlation with symptoms, or requirement for presence of herniated disc on imaging and estimates of treatment effect
Effects of race: All outcomes | | 1 trial N=400 | Moderate | Cannot determine (1 trial) | Indirect | Imprecise | Low | One trial of patients with spinal stenosis found no interaction between race and responsiveness to epidural corticosteroid injections
Effects of pain, patient satisfaction | | 1 trial N=192 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial of patients with non-radicular low back pain found no differences between transforaminal versus interlaminar epidural corticosteroid injection in pain or a patient satisfaction index in the subgroup of patient with imaging findings of a herniated disc, but in patients with spinal stenosis effects on pain favored the transforaminal approach (1.79 vs. 2.19 on the 0 to 5 Roland pain score, p<0.05; likelihood of improving ≥2 points 51% vs. 31%, RR 1.64, 95% CI 0.98 to 2.76 )
Facet joint injections
Effects of use of SPECT versus no SPECT to identify targets for facet joint injections: Pain | | 1 trial N=46 | Moderate | Cannot determine (1 trial) | Direct | Imprecise | Low | One trial found no difference between use of SPECT bone scans versus no SPECT to identify targets for intra- and extra-articular facet joint corticosteroid injections in pain outcomes through 6 months
Key Question 3. In randomized trials of low back pain injection therapies, how does effectiveness vary according to the control therapy used (e.g., epidural nonsteroid injection, nonepidural injection, no injection)?
Epidural injections
Effects of type of placebo intervention in patients with radiculopathy: Pain, function | | 29 trials included in stratified analyses N=2792 | Moderate | Consistent | Indirect | Imprecise | Low | In trials of epidural corticosteroid injections versus placebo injections for radiculopathy, there were no clear differences in estimates for improvement in pain or function, likelihood of a successful pain or functional outcome, or likelihood of undergoing surgery when trials were stratified according to the type of placebo intervention
Effects of type of control intervention in patients with radiculopathy: All outcomes | | 11 trials N=896 | Moderate | Consistent | Indirect | Imprecise | Insufficient | Trials of epidural corticosteroid injections versus other interventions were too limited to determine effects on outcome estimates, due to variability in the interventions evaluated, small numbers of trials, and methodological limitations
Effects of type of placebo intervention in patients with other back conditions: All outcomes | | 20 trials N=1880 | Moderate | Consistent | Indirect | Imprecise | Insufficient | There was insufficient evidence from trials of epidural corticosteroid injections for spinal stenosis, non-radicular back pain, or chronic post-surgical pain, to determine effects of comparators on estimates of effect, due to small numbers of trials for specific comparisons
Facet joint injections
Effects of type of placebo therapy: | | 8 trials N=589 | Moderate | Consistent | Indirect | Imprecise | Insufficient | There was insufficient evidence from trials facet joint injections to determine effects of comparators on estimates of effect, due to small numbers of trials for specific comparisons
Key Question 3a. How do response rates vary according to the specific comparator evaluated (e.g., saline epidural, epidural with local anesthetic, nonepidural injection, no injection, surgery, non-surgical therapies)?
Epidural injections for radiculopathy
Epidural corticosteroid injections versus placebo interventions (direct comparisons): Pain, function, successful outcome | | 3 trials N=340 | Moderate | Consistent | Direct | Imprecise | Low | Three trials found no differences between epidural local anesthetic versus epidural saline injections (3 trials) or soft tissue injections (2 trials) in mean improvements in pain or function or the proportion experiencing pain relief or a successful outcome
Epidural corticosteroid injections versus placebo interventions (indirect comparisons): Pain function | | 29 trials included in stratified analyses N=2792 | Moderate | Inconsistent | Indirect | Precise | Low | In trials of epidural corticosteroid injections for radiculopathy, improvement in pain was smaller in patients who received epidural local anesthetic injections (3 trials, WMD ‒6.51, 95% CI ‒11.9 to ‒1.16, I2=45%) than epidural saline injections (4 trials, WMD ‒19.8, 95% CI ‒25.1 to ‒14.3, I2=56%) at immediate-term; there were no clear differences at other time points, but analyses were limited by small numbers of trials and statistical heterogeneity
Epidural corticosteroid injections versus other interventions: Pain, function | | 11 trials N=896 | Moderate | Consistent | Indirect | Imprecise | Insufficient | Trials were too limited to determine effects on response rates, due to variability in the interventions evaluated, small numbers of trials, and methodological limitations
Key Question 4. What are the harms of epidural corticosteroid, facet joint corticosteroid injections, medial branch blocks, and sacroiliac joint corticosteroid injection compared to epidural nonsteroid injection, nonepidural injection, no injection, surgery, or non-surgical therapies?
Epidural injections
Harms | | 29 trials N=2792 | High | Consistent | Direct | Precise | Moderate | 29 trials of epidural corticosteroid injections versus placebo for radiculopathy reported no serious adverse events and few harms, but methods for assessing harms were not well reported and harms data were sparse. Observational studies were consistent with the trials in showing a low risk of serious adverse events
Harms | | 11 trials N=896 | High | Consistent | Direct | Precise | Moderate | Eleven trials of epidural corticosteroid injections versus other therapies for radiculopathy reported no serious adverse events and few harms
Harms | | 2 trials N=120 | High | Consistent | Direct | Imprecise | Low | Two trials of transforaminal versus interlaminar epidural corticosteroid injections for radiculopathy reported no serious adverse events
Harms | | 4 trials N=324 | High | Inconsistent | Direct | Imprecise | Insufficient | There was insufficient evidence from four trials that compared epidural injections for radiculopathy with different corticosteroids to determine effects on harms
Harms | | 5 trials N=452 | High | Inconsistent | Direct | Imprecise | Insufficient | There was insufficient evidence from five trials of epidural corticosteroid injections for radiculopathy that compared different doses to determine effects on harms
Harms | | 8 trials N=821 | High | Consistent | Direct | Precise | Low | Eight trials of epidural corticosteroid injections versus placebo injections for spinal stenosis reported no serious harms and few adverse events, but methods for assessing harms were not well reported and harms data were sparse
Harms | | 2 trials N=240 | High | Consistent | Direct | Imprecise | Low | Two trials of epidural corticosteroid injections for non-radicular back pain reported no serious harms
Harms | | 4 trials N=322 | High | Inconsistent | Direct | Imprecise | Insufficient | There was insufficient evidence from four trials of epidural corticosteroid injections for chronic post-surgical back pain to determine effects on harms
Facet joint injections
Harms | | 10 trials N=823 | High | Consistent | Direct | Imprecise | Low | Ten trials of facet joint corticosteroid injections reported no serious harms and few adverse events, but methods for assessing harms were not well reported and harms data sparse
Sacroiliac joint injections
Harms | | 1 trial N=24 | High | Cannot determine (1 trial) | Direct | Imprecise | Insufficient | Harms were not reported in one small trial of periarticular sacroiliac joint injections

a Study number based on number of trials directly evaluating the comparison of interest

CI=confidence interval; ODI= Oswestry Disability Index; RR=relative risk; SMD=standard mean difference; SPECT= single photon electronic computed tomography; WMD=weighted mean difference

Please see Appendix C. Included Studies for full study references.