# Quality Rating of Epidural Steroid Injections for Sacroiliac Pain

Author, year | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked?
Luukkainen, 2002 | Unclear | Unclear | Unclear | Yes | Yes

Author, year | Care Provider Masked (injection/ postinjection) | Patient Masked? | Attrition and Withdrawals Reported? | Attrition Acceptable and Comparable? | Analyze People in the Groups in Which They Were Randomized? | Primary Outcome Specified and Reported? | Quality Rating
Luukkainen, 2002 | Unclear | Yes | No | Unclear | Yes | No | Fair

Please see Appendix C. Included Studies for full study references.