# Quality Rating of Facet Joint Steroid Injections

Author, year | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked (injection/ postinjection)
Ackerman, 2008 | Yes | Unclear | Yes | Yes | Unclear | No
Carette, 1991 | Yes | Unclear | Yes | Yes | Unclear | Unclear
Civelek, 2012 | Yes | Unclear | Yes | Yes | Yes | Unclear
Fuchs, 2005 | Unclear | Unclear | Yes | Yes | Yes | Unclear
Galiano, 2007 | Yes | Unclear | No | Yes | No | Unclear
Lakemeier, 2013 | Yes | Yes | Yes | Yes | Yes | Yes
Lilius, 1989 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear
Manchikanti, 2010 Manchikanti, 2008 | Yes | Unclear | Yes | Yes | Yes | Yes
Manchikanti, 2001 | Unclear | Unclear | Yes | Yes | No | Unclear
Marks, 1992 | Yes | Unclear | Unclear | Yes | Yes | Yes
Nash, 1990 | Unclear | No | Unclear | Yes | Unclear | Unclear
Pneumaticos, 2006 | Yes | Unclear | Unclear | Yes | Unclear | Unclear
Ribeiro, 2013 | Yes | Yes | Yes | Yes | Yes | No (injectionist), yes (care provider)

Author, year | Patient Masked? | Attrition and Withdrawals Reported? | Attrition Acceptable and Comparable? | Analyze People in the Groups in Which They Were Randomized? | Primary Outcome Specified and Reported? | Quality Rating
Ackerman, 2008 | Yes | Yes | Yes | Yes | Unclear | Fair
Carette, 1991 | Yes | Yes | Yes | Yes | No | Fair
Civelek, 2012 | No | Yes | Yes | Yes | No | Fair
Fuchs, 2005 | No | No | Unclear | Yes | Yes | Fair
Galiano, 2007 | No | No | Unclear | Yes | Yes | Fair
Lakemeier, 2013 | Yes | Yes | Yes | Yes | Yes | Good
Lilius, 1989 | No | Yes | Yes | Yes | No | Poor
Manchikanti, 2010 Manchikanti, 2008 | Yes | Yes | No | Yes | Unclear | Fair
Manchikanti, 2001 | No | No | No | Yes | No | Poor
Marks, 1992 | Yes | Yes | Yes | Yes | No | Fair
Nash, 1990 | No | Yes | Yes | Yes | Unclear | Poor
Pneumaticos, 2006 | No | Yes | Yes | Yes | No | Fair
Ribeiro, 2013 | Yes | Yes | Yes | Yes | Yes | Good

Please see Appendix C. Included Studies for full study references.