# Epidural Steroid Injections for Postsurgery Pain

Author, year | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked (injection/ post-injection)
Devulder, 1999 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear
Manchikanti, 2012 | Yes | Unclear | Yes | Yes | Unclear | Unclear
Meadeb, 2011 | Unclear | Unclear | No | Yes | Unclear | No
Rahimzadeh, 2014 | Yes | Yes | Yes | Yes | Unclear | Yes
Rocco, 1989 | Unclear | Unclear | No | Yes | Yes | Yes

Author, year | Patient Masked? | Attrition and Withdrawals Reported? | Attrition Acceptable and Comparable? | Analyze People in the Groups in Which They Were Randomized? | Primary Outcome Specified and Reported? | Quality Rating
Devulder, 1999 | Unclear | No | Unclear | Yes | No | Poor
Manchikanti, 2012 | Unclear | Yes | No | Yes | Yes | Poor
Meadeb, 2011 | Unclear | Yes | No | No | Yes | Poor
Rahimzadeh, 2014 | Yes | Unclear | Unclear | Unclear | Yes | Poor
Rocco, 1989 | Yes | Yes | Yes | Yes | No | Fair

Please see Appendix C. Included Studies for full study references.