# Quality Assessment of Epidural Steroid Injections for Nonradicular Pain

Author, year | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked (injection/ postinjection)
Lee, 2009 | Unclear | Unclear | Yes | Yes | Unclear | Unclear
Manchikanti, 2012 (J Pain Research 2012;5:381–90) Manchikanti 2011 (Pain Physician 2011;14:25–36)) Manchikanti 2008 (Pain Physician 2008;11:785–800) | Yes | Yes | Yes | Yes | Yes | Yes/Yes
Manchikanti, 2013 (Pain Physician 2013;16:E491–E504) Also Manchikanti 2012 (J Pain Research 2012; 5:301–11; Manchikanti 2010 | Yes | Unclear | Yes | Yes | Yes | Unclear

Author, year | Patient Masked? | Attrition and Withdrawals Reported? | Attrition Acceptable and Comparable? | Analyze People in the Groups in Which They Were Randomized? | Primary Outcome Specified and Reported? | Quality Rating
Lee, 2009 | Unclear | Yes | Yes | Yes | Unclear | Fair
Manchikanti, 2012 (J Pain Research 2012;5:381–90) Manchikanti 2011 (Pain Physician 2011;14:25–36 ) Manchikanti 2008 (Pain Physician 2008;11:785–800) | Yes | Yes | Yes | Yes | Yes | Fair
Manchikanti, 2013 (Pain Physician 2013;16:E491-E504) Also Manchikanti 2012 (J Pain Research 2012; 5:301–11; Manchikanti 2010 | Yes | Yes | Yes | Yes | No | Fair

Please see Appendix C. Included Studies for full study references.