# Quality Assessment of Epidural Steroid injections for Spinal Stenosis

Author, year Title | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked (injection/ postinjection)
Brown, 2012 | Unclear | Yes | Yes | Yes | Yes | Yes
Cuckler, 1985 | Unclear | Unclear | Yes | Yes | Yes | Yes
Friedly, 2014 | Yes | Yes | Yes | Yes | Yes | Yes/Yes
Fukasaki, 1998 | Unclear | Unclear | Yes | Yes | Yes | Unclear
Huda, 2011 | Yes | Unclear | Yes | Yes | Unclear | Unclear
Koc, 2009 | Unclear | Unclear | Yes | Yes | Yes | Unclear
Manchikanti, 2009 | Yes | Unclear | Yes | Yes | Unclear | Unclear
Manchikanti, 2012 | Yes | Yes | Yes | Yes | Yes | Yes
Manchikanti 2012 Manchikanti 2012 and Manchikanti 2008 | Yes | Unclear | Yes | Yes | Yes | Unclear Yes
Nam, 2011 | Yes | Unclear | Yes | Yes | Unclear | Unclear
Ohtori, 2012 | Yes (minimization) | NA (minimization method) | Yes | Yes | Unclear | Unclear/Unclear
El Zahaar, 1991 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear

Author, year Title | Patient Masked? | Attrition and Withdrawals Reported? | Attrition Acceptable and Comparable? | Analyze People in the Groups in Which They Were Randomized? | Primary Outcome Specified and Reported? | Quality Rating
Brown, 2012 | Yes | Yes | Yes | Yes | Yes | Fair
Cuckler, 1985 | Yes | Yes | Yes | Unclear | Unclear | Fair
Friedly, 2014 | Yes | Yes | Yes | Yes | Yes | Good
Fukasaki, 1998 | No | No | Unclear | Yes | No | Poor
Huda, 2011 | Yes | No | Unclear | Yes | Yes | Fair
Koc, 2009 | No | Yes | No | Yes | No | Fair
Manchikanti, 2009 | No | Yes | No | Yes | Yes | Poor
Manchikanti, 2012 | Yes | Yes | No | Yes | Yes | Fair
Manchikanti 2012 Manchikanti 2012 and Manchikanti 2008 | Yes | Yes | Yes | Yes | No | Fair
Nam, 2011 | Unclear | Yes | No | No | No | Poor
Ohtori, 2012 | Unclear | No | Unclear | Unclear | No (not specified) | Fair
El Zahaar, 1991 | Yes | No | Unclear | Yes | Unclear | Poor

Please see Appendix C. Included Studies for full study references.