# Quality Assessment of Epidural Steroid Injections for Radicular Pain and Herniated Disc

Author, year Title | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked (injection/ post-injection)
Ackerman, 2007 | Yes | Unclear | Yes | Yes | Yes | Unclear
Ahadian, 2011 | Yes | Unclear | No | Yes | Yes | No
Arden, 2005/ Price, 2005 | Yes | Unclear | Yes | Yes | Yes | No/Unclear
Aronsohn, 2010 | Unclear | Unclear | Yes | Yes | Unclear | No
Becker, 2007 | Yes | Unclear | Unclear | Yes | Unclear | Yes
Beliveau 1971 | No | No | Unclear | Yes | Unclear | Unclear
Breivik, 1976 | Yes | Unclear | Unclear | Yes | Yes | Unclear
Buchner, 2000 | Unclear | Unclear | No | Yes | Unclear | Unclear
Burgher, 2011 | Unclear | Unclear | Yes | Yes | Yes | Yes
Bush, 1991 | Unclear | Unclear | No | Yes | Yes | Unclear
Buttermann, 2004 | Yes | Unclear | Yes | Yes | No | No
Candido, 2013 | Yes | Unclear | Yes | Yes | Unclear | No
Candido, 2008 | Yes | Unclear | Unclear | Yes | Unclear | Unclear
Carette, 1997 | Yes | Yes | No | Yes | Yes | Yes
Cocelli, 2009 | Unclear | Unclear | No | Yes | Unclear | Unclear
Cohen, 2012a | Yes | Unclear | Yes | Yes | Yes | Yes
Cohen, 2012b | Yes | Unclear | Yes | Yes | Yes | Yes
Cuckler, 1985 | Unclear | Unclear | Yes | Yes | Yes | Yes
Dashfield, 2005 | Unclear | Unclear | Yes | Yes | Yes | Yes

Author, year Title | Patient Masked? | Attrition and Withdrawals Reported? | Attrition Acceptable and Comparable? | Analyze People in the Groups in Which They Were Randomized? | Primary Outcome Specified and Reported? | Quality Rating
Ackerman, 2007 | Unclear | Yes | Yes | Yes | No | Fair
Ahadian, 2011 | Yes | Yes | Yes | Yes | Yes | Fair
Arden, 2005/ Price, 2005 | Yes | Yes | Yes | Yes | Yes | Fair
Aronsohn, 2010 | No | No | Unclear | Yes | No | Poor
Becker, 2007 | Yes | Yes | Yes | Yes | Yes | Fair
Beliveau 1971 | Unclear | No | Unclear | Yes | No | Poor
Breivik, 1976 | Yes | No | Unclear | Yes | No | Poor
Buchner, 2000 | No | Yes | Yes | Yes | No | Fair
Burgher, 2011 | Yes | Yes | Yes | Yes | Yes | Fair
Bush, 1991 | Yes | Yes | Yes | Yes | No | Fair
Buttermann, 2004 | No | Yes | Yes | No | No | Poor
Candido, 2013 | Unclear | Yes | Yes | Yes | No | Fair
Candido, 2008 | No | No | Unclear | Yes | Yes | Fair
Carette, 1997 | Yes | Yes | Yes | Yes | Yes | Fair
Cocelli, 2009 | Unclear | Yes | Yes | Yes | No | Fair
Cohen, 2012a | Yes | Yes | Yes | Yes | Yes | Good
Cohen, 2012b | Yes | Yes | Yes | Yes | Yes | Fair
Cuckler, 1985 | Yes | Yes | Yes | Unclear | Unclear | Fair
Dashfield, 2005 | Yes | Yes | No | No | Yes | Fair

Author, year Title | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked (injection/ post-injection)
Datta, 2011 | Yes | Yes | Yes | Yes | Unclear | Unclear
Dilke, 1973 | Unclear | Unclear | Yes | Yes | Yes | No
Gerstzen, 2010 | Unclear | Unclear | No | Yes | Unclear | No
Ghahreman, 2010 Ghahreman, 2011 | Yes | Yes | Yes | Yes | Yes | No
Ghai, 2014 | Yes | Yes | Yes | Yes | Yes | Yes
Ghai, 2013 | Yes | Unclear | Yes | Yes | Unclear | Yes
Gharibo, 2011 | Yes | Unclear | Unclear | Yes | Unclear | No
Habib, 2013 | No | No | Yes | Yes | No | No
Helliwell, 1985 | Unclear | Unclear | No | Yes | No | No
Iversen, 2011 | Yes | Yes | Yes | Yes | Yes | No
Jeong, 2007 | Unclear | Unclear | Unclear | Yes | Yes | No
Kang, 2011 | Yes | Unclear | Yes | Yes | Yes | Yes
Karppinen, 2001 Karppinen, 2001 | Yes | Yes | Yes | Yes | Yes | Yes
Kennedy, 2014 | Yes | Unclear | No | Yes | Yes | Unclear
Kim, 2011 | Yes | Unclear | Yes | Yes | Yes | No
Klenerman, 1984 | Yes | Yes | Unclear | Yes | Yes | Unclear
Koh, 2013 | Yes | Unclear | Yes | Yes | Yes | Yes
Kolsi, 2000 | Unclear | Unclear | Yes | Yes | Yes | No
Kraemer, 1997 study 1 | Unclear | Unclear | Yes | Yes | Unclear | Unclear
Kraemer, 1997 study 2 | Unclear | Unclear | Yes | Yes | Unclear | Unclear

Author, year Title | Patient Masked? | Attrition and Withdrawals Reported? | Attrition Acceptable and Comparable? | Analyze People in the Groups in Which They Were Randomized? | Primary Outcome Specified and Reported? | Quality Rating
Datta, 2011 | Unclear | Yes | No | No | No | Poor
Dilke, 1973 | Yes | Yes | Unclear | Yes | Unclear | Fair
Gerstzen, 2010 | No | Yes | Yes | Yes | Yes | Fair
Ghahreman, 2010 Ghahreman, 2011 | Yes | Yes | Yes | Yes | Yes | Good
Ghai, 2014 | Yes | Yes | Yes | Yes | Yes | Good
Ghai, 2013 | Yes | No | Unclear | Yes | Yes | Fair
Gharibo, 2011 | No | No | Unclear | Yes | Yes | Fair
Habib, 2013 | Yes | Yes | Yes | Unclear | Yes | Poor
Helliwell, 1985 | Yes | No | Unclear | Yes | No | Poor
Iversen, 2011 | Yes | Yes | Yes | Yes | Yes | Good
Jeong, 2007 | Yes | Yes | Yes | Yes | Unclear | Fair
Kang, 2011 | Yes | Yes | Yes | Yes | No | Fair
Karppinen, 2001 Karppinen, 2001 | Yes | Yes | Yes | Yes | No | Good
Kennedy, 2014 | Yes | No | Unclear | Yes | Yes | Fair
Kim, 2011 | Yes | Yes | Yes | Yes | No | Fair
Klenerman, 1984 | Unclear | Yes | Yes | No | No | Fair
Koh, 2013 | Yes | Yes | No | Yes | Yes | Fair
Kolsi, 2000 | Yes | Yes | Yes | Yes | No | Fair
Kraemer, 1997 study 1 | Unclear | No | Unclear | Yes | Unclear | Poor
Kraemer, 1997 study 2 | Unclear | No | Unclear | Yes | Unclear | Fair

Author, year Title | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked (injection/ post-injection)
Laiq, 2009 | Yes | Yes | Unclear | Yes | No | Unclear
Manchikanti, 2014 Manchikanti, 2013 Manchikanti, 2010 | Yes | Unclear | No (large differences on multiple characteristics) | Yes | Unclear | Yes
Manchikanti, 2012 Manchikanti 2011 Manchikanti 2008 | Yes | Unclear | Yes | Yes | Yes | Unclear
Matthews, 1987 | Unclear | Unclear | Yes | Yes | Yes | No/Unclear
McCahon, 2011 | Yes | Unclear | Yes | Yes | Yes | Unclear
Murakibhavi, 2011 | Yes | Unclear | Unclear | Yes | No | No
Owlia, 2007 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear
Park, 2010 | Unclear | Unclear | Yes | Yes | Unclear | Unclear
Park, 2013 | Yes | Unclear | Yes | Yes | Yes | Unclear
Rados, 2011 | Yes | Unclear | Yes | Yes | No | Unclear
Ridley, 1988 | Yes | Unclear | Unclear | Yes | No | No/No
Riew, 2000; Riew, 2006 | Unclear | Unclear | Unclear | Yes | Unclear | Yes/Yes
Rogers, 1992 | Unclear | Unclear | Yes | Yes | Yes | Unclear
Sayegh, 2009 | Unclear | Unclear | Unclear | Yes | Unclear | Yes
Snoek, 1977 | Unclear | Unclear | Unclear | Yes | Yes | Unclear
Tafazal, 2009;Ng, 2005 | Yes | Unclear | Yes | Yes | Unclear | Yes
Tauheed, 2014 | Yes | Unclear | Yes | Yes | Unclear | Unclear
Thomas, 2003 | Unclear | Unclear | No | Yes | Unclear | Unclear

Author, year Title | Patient Masked? | Attrition and Withdrawals Reported? | Attrition Acceptable and Comparable? | Analyze People in the Groups in Which They Were Randomized? | Primary Outcome Specified and Reported? | Quality Rating
Laiq, 2009 | No | Yes | Yes | Yes | No | Fair
Manchikanti, 2014 Manchikanti, 2013 Manchikanti, 2010 | Yes | Yes | Yes | Yes | Yes | Poor
Manchikanti, 2012 Manchikanti 2011 Manchikanti 2008 | No | Yes | Yes | Yes | Yes | Fair
Matthews, 1987 | Yes | Yes | Yes | Yes | No | Fair
McCahon, 2011 | Yes | Yes | Yes | Yes | Yes | Fair
Murakibhavi, 2011 | No | No | Unclear | Yes | No | Poor
Owlia, 2007 | Unclear | No | Unclear | Yes | Yes | Poor
Park, 2010 | Unclear | No | Unclear | Yes | No | Fair
Park, 2013 | No | Yes | Yes | Yes | Yes | Fair
Rados, 2011 | Yes | Yes | Yes | Yes | Yes | Fair
Ridley, 1988 | No | Yes | Yes | Yes | Unclear | Fair
Riew, 2000; Riew, 2006 | Yes | Yes | Yes | Yes | Unclear | Fair
Rogers, 1992 | Yes | No | Unclear | Yes | Unclear | Poor
Sayegh, 2009 | Yes | Yes | Yes | Yes | Unclear | Fair
Snoek, 1977 | Yes | No | Unclear | Yes | Unclear | Poor
Tafazal, 2009;Ng, 2005 | Yes | Yes | Yes | Yes | Yes | Fair
Tauheed, 2014 | Yes | Yes | Yes | Yes | Unclear | Fair
Thomas, 2003 | Yes | Yes | No | Yes | No | Fair

Author, year Title | Randomization Adequate? | Allocation Concealment Adequate? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Masked? | Care Provider Masked (injection/ post-injection)
Valat, 2003 | Yes | Yes | Yes | Yes | Yes | Unclear
Wilson-MacDonald, 2005 | Yes | Yes | Unclear | Yes | Unclear | Yes
el Zahaar, 1991 | Unclear | Unclear | Unclear | Yes | Unclear | Unclear

Author, year Title | Patient Masked? | Attrition and Withdrawals Reported? | Attrition Acceptable and Comparable? | Analyze People in the Groups in Which They Were Randomized? | Primary Outcome Specified and Reported? | Quality Rating
Valat, 2003 | Yes | Yes | No | Yes | Yes | Fair
Wilson-MacDonald, 2005 | Yes | Unclear | Unclear | Yes | No | Fair
el Zahaar, 1991 | Yes | No | Unclear | Yes | Unclear | Poor

Please see Appendix C. Included Studies for full study references.