# Excluded Studies

Allen TL, Tatli Y, Lutz GE. Fluoroscopic percutaneous lumbar zygapophyseal joint cyst rupture: a clinical outcome study. Spine J. 2009;9(5):387-395. [pmid: 18809358]. Excluded: Wrong study design for Key Question.
Al-Shoha A, Rao DS, Schilling J, et al. Effect of epidural steroid injection on bone mineral density and markers of bone turnover in postmenopausal women. Spine. 2012;37(25):E1567-E1571. [pmid: 23196966]. Excluded: Wrong outcomes.
Amoretti N, Huwart L, Foti P, et al. Symptomatic lumbar facet joint cysts treated by CT-guided intracystic and intra-articular steroid injections. Eur Radiol. 2012;22(12):2836-2840. [pmid: 22688130]. Excluded: Wrong study design for Key Question.
Andersson GB. Epidural glucocorticoid injections in patients with lumbar spinal stenosis. New Engl J Med. 2014;371(1):75-76. [pmid: 24988561]. Excluded: Not a study (letter, editorial, non-systematic review article).
Atluri S, Glaser SE, Shah RV, et al. Needle position analysis in cases of paralysis from transforaminal epidurals: consider alternative approaches to traditional technique. Pain Physician. 2013;16(4):321-334. [pmid: 23877448]. Excluded: Wrong study design for Key Question.
Bartynski WS, Grahovac SZ, Rothfus WE. Incorrect needle position during lumbar epidural steroid administration: inaccuracy of loss of air pressure resistance and requirement of fluoroscopy and epidurography during needle insertion. AJNR Am J Neuroradiol. 2005;26(3):502-505. [pmid: 15760856]. Excluded: Not relevant.
Bhatia A. Intraarticular steroids versus radiofrequency denervation of lumbar facets for treatment of low back pain. Anesth Analg. 2014;118(1):237. [pmid: 24356171]. Excluded: Not a study (letter, editorial, non-systematic review article).
Block JP. Epidural steroid or etanercept injections have limited to no benefit for subacute sciatica. Journal of Clinical Outcomes Management. 2012;19(6):245-247. PMID: No PMID. Excluded: Using original studies instead (e.g., meta-analysis, compiled study data, or data from another publication).
Bogduk N. A narrative review of intra-articular corticosteroid injections for low back pain. Pain Med. 2005;6(4):287-296. [pmid: 16083458]. Excluded: Wrong study design for Key Question.
Bogduk N. Degenerative Joint Disease of the Spine. Radiol Clin North Am. 2012;50(4):613-628. [pmid: 22643388]. Excluded: Not relevant.
Bogduk N. Editor's response: Group vs. categorical data in epidural studies. Pain Med. 2014;15(10):1812-1813. [pmid: 25236349]. Excluded: Not a study (letter, editorial, non-systematic review article).
Botwin KP, Natalicchio J, Hanna A. Fluoroscopic guided lumbar interlaminar epidural injections: a prospective evaluation of epidurography contrast patterns and anatomical review of the epidural space. Pain Physician. 2004;7(1):77-80. [pmid: 16868616]. Excluded: Not relevant.
Cambron SC, McIntyre JJ, Guerin SJ, et al. Lumbar facet joint synovial cysts: does T2 signal intensity predict outcomes after percutaneous rupture?. AJNR Am J Neuroradiol. 2013;34(8):1661-1664. [pmid: 23449657]. Excluded: Not relevant.
Carr CM, Plastaras C, Pingree MJ, et al. Adverse Event Rates in Interventional Spine Procedures: A Multi-Institutional Study International Spine Intervention Society-2014 22nd Annual Scientific Meeting Research Abstracts. Pain Med. 2014;15(8). PMID: No PMID. Excluded: Not a study (letter, editorial, non-systematic review article).
Centers for Disease Control and Prevention (CDC). Vital signs: overdoses of prescription opioid pain relievers---United States, 1999--2008. MMWR Morb Mortal Wkly Rep. 2011;60(43):1487-1492. [pmid: 22048730]. Excluded: Not relevant.
Chen B, Stitik TP, Foye PM. Safety of interlaminar and transforaminal epidural steroid injections. Anesth Analg. 2014;118(1):236. [pmid: 24356169]. Excluded: Not a study (letter, editorial, non-systematic review article).
Choi SJ, Song JS, Kim C, et al. The use of magnetic resonance imaging to predict the clinical outcome of non-surgical treatment for lumbar intervertebral disc herniation. Korean J Radiol. 2007;8(2):156-163. [pmid: 17420633]. Excluded: Not relevant.
Cyteval C, Fescquet N, Thomas E, et al. Predictive factors of efficacy of periradicular corticosteroid injections for lumbar radiculopathy. AJNR Am J Neuroradiol. 2006;27(5):978-982. [pmid: 16687527]. Excluded: Wrong study design for Key Question.
DePalma MJ, Ketchum JM, Saullo TR. Multivariable analyses of the relationships between age, gender, and body mass index and the source of chronic low back pain. Pain Med. 2012;13(4):498-506. [pmid: 22390231]. Excluded: Not relevant.
Devereaux PJ, Yang H, Yusuf S, et al. Effects of extended-release metoprolol succinate in patients undergoing non-cardiac surgery (POISE trial): a randomised controlled trial. Lancet. 2008;371(9627):1839-1847. [pmid: 18479744]. Excluded: Not relevant.
Deyo RA, Dworkin SF, Amtmann D, et al. Focus article: report of the NIH Task Force on Research Standards for Chronic Low Back Pain. Eur Spine J. 2014;23(10):2028-2045. [pmid: 25212440]. Excluded: Not relevant.
Dolan AL, Ryan PJ, Arden NK, et al. The value of SPECT scans in identifying back pain likely to benefit from facet joint injection. Br J Rheumatol. 1996;35(12):1269-1273. [pmid: 9010055]. Excluded: Not relevant.
Dreyfuss P, Baker R, Bogduk N. Comparative effectiveness of cervical transforaminal injections with particulate and nonparticulate corticosteroid preparations for cervical radicular pain. Pain Med. 2006;7(3):237-242. [pmid: 16712623]. Excluded: Wrong population.
El Abd OH, Amadera JE, Pimentel DC, et al. Intravascular flow detection during transforaminal epidural injections: a prospective assessment. Pain Physician. 2014;17(1):21-27. [pmid: 24452642]. Excluded: Wrong study design for Key Question.
el-Khoury GY, Ehara S, Weinstein JN, et al. Epidural steroid injection: a procedure ideally performed with fluoroscopic control. Radiology. 1988;168(2):554-557. [pmid: 2969118]. Excluded: Not relevant.
El-Yahchouchi C, Geske JR, Carter RE, et al. The noninferiority of the nonparticulate steroid dexamethasone vs the particulate steroids betamethasone and triamcinolone in lumbar transforaminal epidural steroid injections. Pain Med. 2013;14(11):1650-1657. [pmid: 23899304]. Excluded: Wrong study design for Key Question.
El-Yahchouchi C, Geske JR, Carter RE, et al. The noninferiority of the nonparticulate steroid dexamethasone vs the particulate steroids betamethasone and triamcinolone in lumbar transforaminal epidural steroid injections. Pain Med. 2013;14(11):1650-1657. [pmid: 23899304]. Excluded: Wrong study design for Key Question.
El-Yahchouchi C, Wald J, Brault J, et al. Lumbar transforaminal epidural steroid injections: does immediate post-procedure pain response predict longer term effectiveness?. Pain Med. 2014;15(6):921-928. [pmid: 24612150]. Excluded: Wrong study design for Key Question.
Engel A, King W, MacVicar J. The effectiveness and risks of fluoroscopically guided cervical transforaminal injections of steroids: a systematic review with comprehensive analysis of the published data. Pain Med. 2014;15(3):386-402. [pmid: 24308846]. Excluded: Wrong study design for Key Question.
Engel A, MacVicar J, Bogduk N. A philosophical foundation for diagnostic blocks, with criteria for their validation. Pain Med. 2014;15(6):998-1006. [pmid: 24716821]. Excluded: Not relevant.
Epstein NE. The risks of epidural and transforaminal steroid injections in the Spine: Commentary and a comprehensive review of the literature. Surg Neurol Int. Suppl 2. 2013;4:S74-S93. [pmid: 23646278]. Excluded: Wrong study design for Key Question.
Flick RP. Anesthetic and Analgesic Drug Products Advisory Committee c/o Stephanie L. Bagansky P, ed. Silver Spring. MD2014:1-9. Excluded: Not a study (letter, editorial, non-systematic review article).
Fredman B, Nun MB, Zohar E, et al. Epidural steroids for treating "failed back surgery syndrome": is fluoroscopy really necessary?. Anesth Analg. 1999;88(2):367-372. [pmid: 9972758]. Excluded: Wrong study design for Key Question.
Friedman BW, Esses D, Solorzano C, et al. A randomized placebo-controlled trial of single-dose IM corticosteroid for radicular low back pain. Spine. 2008;33(18):E624-E629. [pmid: 18665021]. Excluded: Wrong intervention.
Gerdesmeyer L, Wagenpfeil S, Birkenmaier C, et al. Percutaneous epidural lysis of adhesions in chronic lumbar radicular pain: a randomized, double-blind, placebo-controlled trial. Pain Physician. 2013;16(3):185-196. [pmid: 23703406]. Excluded: Wrong intervention.
Grunnesjo MI, Bogefeldt JP, Blomberg SIE, et al. A randomized controlled trial of the effects of muscle stretching, manual therapy and steroid injections in addition to 'stay active' care on health-related quality of life in acute or subacute low back pain. Clin Rehabil. 2011;25(11):999-1010. [pmid: 21831926]. Excluded: Wrong intervention.
Hagg O, Fritzell P, Nordwall A. The clinical importance of changes in outcome scores after treatment for chronic low back pain. Eur Spine J. 2003;12(1):12-20. [pmid: 12592542]. Excluded: Wrong intervention.
Jee H, Lee JH, Kim J, et al. Ultrasound-guided selective nerve root block versus fluoroscopy-guided transforaminal block for the treatment of radicular pain in the lower cervical spine: a randomized, blinded, controlled study. Skeletal Radiol. 2013;42(1):69-78. [pmid: 22609989]. Excluded: Wrong intervention.
Karp JF, Yu L, Friedly J, et al. Negative affect and sleep disturbance may be associated with response to epidural steroid injections for spine-related pain. Arch Phys Med Rehabil. 2014;95(2):309-315. [pmid: 24060493]. Excluded: Wrong study design for Key Question.
Kaufmann TJ, Geske JR, Murthy NS, et al. Clinical effectiveness of single lumbar transforaminal epidural steroid injections. Pain Med. 2013;14(8):1126-1133. [pmid: 23895182]. Excluded: Wrong study design for Key Question.
Klessinger S. Radicular pain in post lumbar surgery syndrome: the significance of transforaminal injection of steroids. Pain Med. 2013;14(2):243-246. [pmid: 22882468]. Excluded: Wrong study design for Key Question.
Lauridsen HH, Hartvigsen J, Manniche C, et al. Responsiveness and minimal clinically important difference for pain and disability instruments in low back pain patients. BMC Musculoskelet Disord. 2006;7:82. [pmid: 17064410]. Excluded: Not relevant.
Lee JW, Park KW, Chung S-K, et al. Cervical transforaminal epidural steroid injection for the management of cervical radiculopathy: a comparative study of particulate versus non-particulate steroids. Skeletal Radiol. 2009;38(11):1077-1082. [pmid: 19543892]. Excluded: Wrong population.
Loizides A, Gruber H, Peer S, et al. Ultrasound guided versus CT-controlled pararadicular injections in the lumbar spine: a prospective randomized clinical trial. AJNR Am J Neuroradiol. 2013;34(2):466-470. [pmid: 22821925]. Excluded: Wrong outcomes.
Maigne JY, Aivaliklis A, Pfefer F. Results of sacroiliac joint double block and value of sacroiliac pain provocation tests in 54 patients with low back pain. Spine (Phila Pa 1976). 1996;21(16):1889-1892. [pmid: 8875721]. Excluded: Not relevant.
Manchikanti L, Cash KA, McManus CD, et al. Assessment of effectiveness of percutaneous adhesiolysis in managing chronic low back pain secondary to lumbar central spinal canal stenosis. Int J Med Sci. 2013;10(1):50-59. [pmid: 23289005]. Excluded: Wrong intervention.
Manchikanti L, Cash KA, McManus CD, et al. Thoracic interlaminar epidural injections in managing chronic thoracic pain: A randomized, double-blind, controlled trial with a 2-year follow-up. Pain Physician. 2014;17(3):E327-E338. [pmid: 24850114]. Excluded: Wrong population.
Manchikanti L, Cash KA, Pampati V, et al. Evaluation of fluoroscopically guided caudal epidural injections. Pain Physician. 2004;7(1):81-92. [pmid: 16868617]. Excluded: Wrong study design for Key Question.
Manchikanti L, Cash KA, Pampati V, et al. The effectiveness of fluoroscopic cervical interlaminar epidural injections in managing chronic cervical disc herniation and radiculitis: preliminary results of a randomized, double-blind, controlled trial.[Erratum appears in Pain Physician. 2010 Jul-Aurg;13(4)399-400]. Pain Physician. 2010;13(3):223-236. [pmid: 20495586]. Excluded: Wrong population.
Manchikanti L, Cash KA, Pampati V, et al. Management of chronic pain of cervical disc herniation and radiculitis with fluoroscopic cervical interlaminar epidural injections. Int J Med Sci. 2012;9(6):424-434. [pmid: 22859902]. Excluded: Wrong population.
Manchikanti L, Cash KA, Pampati V, et al. A randomized, double-blind, active control trial of fluoroscopic cervical interlaminar epidural injections in chronic pain of cervical disc herniation: Results of a 2-year follow-up. Pain Physician. 2013;16(5):465-478. [pmid: 24077193]. Excluded: Wrong population.
Manchikanti L, Falco FJ, Singh V, et al. Utilization of interventional techniques in managing chronic pain in the Medicare population: analysis of growth patterns from 2000 to 2011. Pain Physician. 2012;15(6):E969-E982. [pmid: 23159982]. Excluded: Wrong population.
Manchikanti L, Malla Y, Cash KA, et al. Fluoroscopic epidural injections in cervical spinal stenosis: preliminary results of a randomized, double-blind, active control trial. Pain Physician. 2012;15(1):E59-E70. [pmid: 22270749]. Excluded: Wrong population.
Manchikanti L, Malla Y, Cash KA, et al. Fluoroscopic cervical interlaminar epidural injections in managing chronic pain of cervical postsurgery syndrome: preliminary results of a randomized, double-blind, active control trial. Pain Physician. 2012;15(1):13-25. [pmid: 22270734]. Excluded: Wrong population.
Manchikanti L, Manchikanti KN, Cash KA, et al. Age-related prevalence of facet-joint involvement in chronic neck and low back pain. Pain Physician. 2008;11(1):67-75. [pmid: 18196171]. Excluded: Not relevant.
Manchikanti L, Pampati V, Cash KA. Protocol for evaluation of the comparative effectiveness of percutaneous adhesiolysis and caudal epidural steroid injections in low back and/or lower extremity pain without post surgery syndrome or spinal stenosis. Pain Physician. 2010;13(2):E91-E110. [pmid: 20309389]. Excluded: Wrong outcomes.
Manchikanti L, Singh V, Cash KA, et al. Preliminary results of a randomized, equivalence trial of fluoroscopic caudal epidural injections in managing chronic low back pain: Part 3--Post surgery syndrome. Pain Physician. 2008;11(6):817-831. [pmid: 19057628]. Excluded: Wrong population.
Manchikanti L, Singh V, Cash KA, et al. A comparative effectiveness evaluation of percutaneous adhesiolysis and epidural steroid injections in managing lumbar post surgery syndrome: a randomized, equivalence controlled trial. Pain Physician. 2009;12(6):E355-E368. [pmid: 19935992]. Excluded: Wrong study design for Key Question.
Manchikanti L, Singh V, Falco FJE, et al. Comparative outcomes of a 2-year follow-up of cervical medial branch blocks in management of chronic neck pain: a randomized, double-blind controlled trial. Pain Physician. 2010;13(5):437-450. [pmid: 20859313]. Excluded: Wrong population.
Manchikanti L, Singh V, Falco FJE, et al. Effectiveness of thoracic medial branch blocks in managing chronic pain: a preliminary report of a randomized, double-blind controlled trial. Pain Physician. 2008;11(4):491-504. [pmid: 18690278]. Excluded: Wrong population.
Manchikanti L, Singh V, Falco FJE, et al. Cervical medial branch blocks for chronic cervical facet joint pain: a randomized, double-blind, controlled trial with one-year follow-up. Spine. 2008;33(17):1813-1820. [pmid: 18670333]. Excluded: Wrong intervention.
Manchikanti L, Singh V, Pampati V, et al. Evaluation of the relative contributions of various structures in chronic low back pain. Pain Physician. 2001;4(4):308-316. [pmid: 16902676]. Excluded: Not relevant.
Mandel S, Schilling J, Peterson E, et al. A retrospective analysis of vertebral body fractures following epidural steroid injections. J Bone Joint Surg Am. 2013;95(11):961-964. [pmid: 23780532]. Excluded: Wrong study design for Key Question.
Manson NA, McKeon MD, Abraham EP. Transforaminal epidural steroid injections prevent the need for surgery in patients with sciatica secondary to lumbar disc herniation: a retrospective case series. Can J Surg. 2013;56(2):89-96. [pmid: 23351495]. Excluded: Wrong study design for Key Question.
Martha JF, Swaim B, Wang DA, et al. Outcome of percutaneous rupture of lumbar synovial cysts: a case series of 101 patients. Spine J. 2009;9(11):899-904. [pmid: 19664971]. Excluded: Not relevant.
Maugars Y, Mathis C, Berthelot JM, et al. Assessment of the efficacy of sacroiliac corticosteroid injections in spondylarthropathies: a double-blind study. Br J Rheumatol. 1996;35(8):767-770. [pmid: 8761190]. Excluded: Wrong population.
Mehta M, Salmon N. Extradural block. Confirmation of the injection site by X-ray monitoring. Anaesthesia. 1985;40(10):1009-1012. [pmid: 4061788]. Excluded: Not relevant.
Mendoza-Lattes S, Weiss A, Found E, et al. Comparable effectiveness of caudal vs. trans-foraminal epidural steroid injections. Iowa Orthop J. 2009;29:91-96. [pmid: 19742093]. Excluded: Wrong study design for Key Question.
Mulleman D, Mammou S, Griffoul I, et al. Pathophysiology of disk-related sciatica. I.--Evidence supporting a chemical component. Joint Bone Spine. 2006;73(2):151-158. [pmid: 16046173]. Excluded: Not relevant.
Murata Y, Kato Y, Miyamoto K, et al. Clinical study of low back pain and radicular pain pathways by using l2 spinal nerve root infiltration: a randomized, controlled, clinical trial. Spine (Phila Pa 1976). 2009;34(19):2008-2013. [pmid: 19730208]. Excluded: Wrong study design for Key Question.
Murthy NS, Geske JR, Shelerud RA, et al. The effectiveness of repeat lumbar transforaminal epidural steroid injections. Pain Med. 2014;15(10):1686-1694. [pmid: 25039323]. Excluded: Wrong study design for Key Question.
Nampiaparampil DE, Engel AJ. A response to two recent reviews of epidural steroid injections. Pain Med. 2013;14(6):954-955. [pmid: 23786560]. Excluded: Not a study (letter, editorial, non-systematic review article).
Peng B, Pang X, Wu Y, et al. A randomized placebo-controlled trial of intradiscal methylene blue injection for the treatment of chronic discogenic low back pain. Pain. 2010;149(1):124-129. [pmid: 20167430]. Excluded: Wrong study design for Key Question.
Price CM, Rogers PD, Prosser AS, et al. Comparison of the caudal and lumbar approaches to the epidural space. Ann Rheum Dis. 2000;59(11):879-882. [pmid: 11053065]. Excluded: Wrong outcomes.
Renfrew DL, Moore TE, Kathol MH, et al. Correct placement of epidural steroid injections: fluoroscopic guidance and contrast administration. AJNR Am J Neuroradiol. 1991;12(5):1003-1007. [pmid: 1719788]. Excluded: Wrong study design for Key Question.
Schwarzer AC, Aprill CN, Bogduk N. The sacroiliac joint in chronic low back pain. Spine (Phila Pa 1976). 1995;20(1):31-37. [pmid: 7709277]. Excluded: Not relevant.
Schwarzer AC, Aprill CN, Derby R, et al. Clinical features of patients with pain stemming from the lumbar zygapophysial joints. Is the lumbar facet syndrome a clinical entity?. Spine (Phila Pa 1976). 1994;19(10):1132-1137. [pmid: 8059268]. Excluded: Not relevant.
Schwarzer AC, Aprill CN, Derby R, et al. The prevalence and clinical features of internal disc disruption in patients with chronic low back pain. Spine (Phila Pa 1976). 1995;20(17):1878-1883. [pmid: 8560335]. Excluded: Not relevant.
Schwarzer AC, Wang SC, Bogduk N, et al. Prevalence and clinical features of lumbar zygapophysial joint pain: a study in an Australian population with chronic low back pain. Ann Rheum Dis. 1995;54(2):100-106. [pmid: 7702395]. Excluded: Not relevant.
Serrao JM, Marks RL, Morley SJ, et al. Intrathecal midazolam for the treatment of chronic mechanical low back pain: a controlled comparison with epidural steroid in a pilot study. Pain. 1992;48(1):5-12. [pmid: 1531383]. Excluded: Wrong intervention.
Singh G. Gastrointestinal complications of prescription and over-the-counter nonsteroidal anti-inflammatory drugs: a view from the ARAMIS database. Arthritis, Rheumatism, and Aging Medical Information System. Am J Ther. 2000;7(2):115-121. [pmid: 11319579]. Excluded: Not relevant.
Smith CC, Booker T, Schaufele MK, et al. Interlaminar versus transforaminal epidural steroid injections for the treatment of symptomatic lumbar spinal stenosis. Pain Med. 2010;11(10):1511-1515. [pmid: 20735751]. Excluded: Wrong study design for Key Question.
Spijker-Huiges A, Vermeulen K, Winters JC, et al. Costs and Cost-effectiveness of Epidural Steroids for Acute Lumbosacral Radicular Syndrome in General Practice: An Economic Evaluation Alongside a Pragmatic Randomized Control Trial. Spine (Phila Pa 1976). 2014;39(24):2007-2012. [pmid: 25202937]. Excluded: Wrong outcomes.
Stitz MY, Sommer HM. Accuracy of blind versus fluoroscopically guided caudal epidural injection. Spine (Phila Pa 1976). 1999;24(13):1371-1376. [pmid: 10404581]. Excluded: Wrong study design for Key Question.
Swerdlow M, Sayler-Creer W. A study of extradural medication in the relief of lumbosciatic syndrome. Anaesthesia. 1970;25(3):341-345. [pmid: 4193992]. Excluded: Wrong study design for Key Question.
Vad VB, Bhat AL, Lutz GE, et al. Transforaminal epidural steroid injections in lumbosacral radiculopathy: a prospective randomized study. Spine (Phila Pa 1976). 2002;27(1):11-16. [pmid: 11805628]. Excluded: Wrong study design for Key Question.
van Helvoirt H, Apeldoorn AT, Ostelo RW, et al. Transforaminal epidural steroid injections followed by mechanical diagnosis and therapy to prevent surgery for lumbar disc herniation. Pain Med. 2014;15(7):1100-1108. [pmid: 24800697]. Excluded: Wrong study design for Key Question.
Wang JC, Lin E, Brodke DS, et al. Epidural injections for the treatment of symptomatic lumbar herniated discs. J Spinal Disord Tech. 2002;15(4):269-272. [pmid: 12177540]. Excluded: Wrong study design for Key Question.
Weil L, Frauwirth NH, Amirdelfan K, et al. Fluoroscopic analysis of lumbar epidural contrast spread after lumbar interlaminar injection. Arch Phys Med Rehabil. 2008;89(3):413-416. [pmid: 18295616]. Excluded: Not relevant.
Weiner BK, Fernandez-Moure J. Caudal epidural steroid injections no better than saline, epidurals or sham injections for the treatment of chronic lumbar radiculopathy. Evidence-Based Medicine. 2012;17(4):110-111. [pmid: 22187493]. Excluded: Not a study (letter, editorial, non-systematic review article).
Weiner BK, Fraser RD. Foraminal injection for lateral lumbar disc herniation. J Bone Joint Surg Br. 1997;79(5):804-807. [pmid: 9331040]. Excluded: Wrong study design for Key Question.
Wewalka M, Abdelrahimsai A, Wiesinger GF, et al. CT-guided transforaminal epidural injections with local anesthetic, steroid, and tramadol for the treatment of persistent lumbar radicular pain. Pain Physician. 2012;15(2):153-159. [pmid: 22430653]. Excluded: Wrong study design for Key Question.
White AA 3rd, Gordon SL. Synopsis: workshop on idiopathic low-back pain. Spine (Phila Pa 1976). 1982;7(2):141-149. [pmid: 6211779]. Excluded: Not relevant.