# Included Studies

## Please refer to this section as a reference list for Appendixes E and F

Ackerman WE 3rd, Ahmad M. The efficacy of lumbar epidural steroid injections in patients with lumbar disc herniations. Anesth Analg. May. 2007;104(5):1217-1222. tables of contents. [pmid: 17456677].
Ackerman WE 3rd, Ahmad M. Pain relief with intraarticular or medial branch nerve blocks in patients with positive lumbar facet joint SPECT imaging: a 12-week outcome study. South Med J. 2008;101(9):931-934. [pmid: 18708988].
Ahadian FM, McGreevy K, Schulteis G. Lumbar transforaminal epidural dexamethasone: a prospective, randomized, double-blind, dose-response trial. Reg Anesth Pain Med. Nov-Dec. 2011;36(6):572-578. [pmid: 22005659].
Arden NK, Price C, Reading I, et al. A multicentre randomized controlled trial of epidural corticosteroid injections for sciatica: the WEST study. Rheumatology (Oxford). Nov. 2005;44(11):1399-1406. [pmid: 16030082].
Aronsohn J, Chapman K, Soliman M, et al. Percutaneous microdiscectomy versus epidural injection for management of chronic spinal pain. Proc West Pharmacol Soc. 2010;53:16-19. [pmid: 22128444].
Becker C, Heidersdorf S, Drewlo S, et al. Efficacy of epidural perineural injections with autologous conditioned serum for lumbar radicular compression: an investigator-initiated, prospective, double-blind, reference-controlled study. Spine (Phila Pa 1976). Aug. 1. 2007;32(17):1803-1808. [pmid: 17762286].
Beliveau P. A comparison between epidural anaesthesia with and without corticosteroid in the treatment of sciatica. Rheumatol Phys Med. Feb. 1971;11(1):40-43. [pmid: 5551095].
Breivik H, Hesla P, Molnar I, et al. Treatment of chronic low back pain and sciatica. Comparison of caudal epidural injections of bupivacaine and methylprednisolone with bupivacaine followed by saline. Adv Pain Res Ther. 1976;1:927-932. PMID: No PMID.
Brown LL. A double-blind, randomized, prospective study of epidural steroid injection vs. the mild procedure in patients with symptomatic lumbar spinal stenosis. Pain pract. Jun. 2012;12(5):333-341. [pmid: 22272730].
Buchner M, Zeifang F, Brocai DR, et al. Epidural corticosteroid injection in the conservative management of sciatica. Clin Orthop Relat Res. Jun. 2000;(375):149-156. [pmid: 10853164].
Burgher AH, Hoelzer BC, Schroeder DR, et al. Transforaminal epidural clonidine versus corticosteroid for acute lumbosacral radiculopathy due to intervertebral disc herniation. Spine. Mar. 1. 2011;36(5):E293-E300. [pmid: 21192304].
Bush K, Hillier S. A controlled study of caudal epidural injections of triamcinolone plus procaine for the management of intractable sciatica. Spine (Phila Pa 1976). May. 1991;16(5):572-575. [pmid: 2053000].
Buttermann GR. Treatment of lumbar disc herniation: epidural steroid injection compared with discectomy. A prospective, randomized study. J Bone Joint Surg Am. Apr. 2004;86-A(4):670-679. [pmid: 15069129].
Candido KD, Raghavendra MS, Chinthagada M, et al. A prospective evaluation of iodinated contrast flow patterns with fluoroscopically guided lumbar epidural steroid injections: the lateral parasagittal interlaminar epidural approach versus the transforaminal epidural approach. Anesth Analg. 2008 of contents. Feb. 2008;106(2):638-644. [pmid: 18227326].
Candido KD, Rana MV, Sauer R, et al. Concordant pressure paresthesia during interlaminar lumbar epidural steroid injections correlates with pain relief in patients with unilateral radicular pain. Pain Physician. 2013;16(5):497-511. [pmid: 24077196].
Carette S, Leclaire R, Marcoux S, et al. Epidural corticosteroid injections for sciatica due to herniated nucleus pulposus. N Engl J Med. Jun. 5. 1997;336(23):1634-1640. [pmid: 9171065].
Carette S, Marcoux S, Truchon R, et al. A controlled trial of corticosteroid injections into facet joints for chronic low back pain. N Engl J Med. Oct. 3. 1991;325(14):1002-1007. [pmid: 1832209].
Civelek E, Cansever T, Kabatas S, et al. Comparison of effectiveness of facet joint injection and radiofrequency denervation in chronic low back pain. Turk Neurosurg. 2012;22(2):200-206. [pmid: 22437295].
Cocelli LP, Karakurum G, Cebesoy O, et al. Clinical comparison of effectiveness of epidural triamcinolone and betamethasone in discal radiculalgia: a prospective, randomized study. Journal of Musculoskeletal Pain. 2009;17(3):281-286.
Cohen SP, Gupta A, Strassels SA, et al. Effect of MRI on treatment results or decision making in patients with lumbosacral radiculopathy referred for epidural steroid injections: a multicenter, randomized controlled trial. [Erratum appears in Arch Intern Med. 2012 Apr 23;172(8)673]. Arch Intern Med. Jan. 23. 2012;172(2):134-142. [pmid: 22157067].
Cohen SP, White RL, Kurihara C, et al. Epidural steroids, etanercept, or saline in subacute sciatica: a multicenter, randomized trial. Ann Intern Med. Apr. 17. 2012;156(8):551-559. [pmid: 22508732].
Cuckler JM, Bernini PA, Wiesel SW, et al. The use of epidural steroids in the treatment of lumbar radicular pain. A prospective, randomized, double-blind study. J Bone Joint Surg Am. Jan. 1985;67(1):63-66. [pmid: 3155742].
Dashfield AK, Taylor MB, Cleaver JS, et al. Comparison of caudal steroid epidural with targeted steroid placement during spinal endoscopy for chronic sciatica: a prospective, randomized, double-blind trial. Br J Anaesth. Apr. 2005;94(4):514-519. [pmid: 15695544].
Datta R, Upadhyay KK. A randomized clinical trial of three different steroid agents for treatment of low backache through the caudal route. Med J Armed Forces India. 2011;67(1):25-33. PMID: No PMID.
Devulder J, Deene P, De Laat M, et al. Nerve root sleeve injections in patients with failed back surgery syndrome: a comparison of three solutions. Clin J Pain. Jun. 1999;15(2):132-135. [pmid: 10382927].
Dilke TF, Burry HC, Grahame R. Extradural corticosteroid injection in management of lumbar nerve root compression. Br Med J. Jun. 16. 1973;2(5867):635-637. [pmid: 4577015].
el Zahaar MS. The value of caudal epidural steroids in the treatment of lumbar neural compression syndromes. J Neurol Orthop Med Surg. 1991;12:181-184. PMID: No PMID.
Friedly JL, Comstock BA, Turner JA, et al. A randomized trial of epidural glucocorticoid injections for spinal stenosis. N Engl J Med. Jul. 3. 2014;371(1):11-21. [pmid: 24988555].
Fuchs S, Erbe T, Fischer HL, et al. Intraarticular hyaluronic acid versus glucocorticoid injections for nonradicular pain in the lumbar spine. J Vasc Interv Radiol. Nov. 2005;16(11):1493-1498. [pmid: 16319156].
Fukusaki M, Kobayashi I, Hara T, et al. Symptoms of spinal stenosis do not improve after epidural steroid injection. Clin J Pain. Jun. 1998;14(2):148-151. [pmid: 9647457].
Galiano K, Obwegeser AA, Walch C, et al. Ultrasound-guided versus computed tomography-controlled facet joint injections in the lumbar spine: a prospective randomized clinical trial. Reg Anesth Pain Med. Jul-Aug. 2007;32(4):317-322. [pmid: 17720116].
Gerszten PC, Smuck M, Rathmell JP, et al. Plasma disc decompression compared with fluoroscopy-guided transforaminal epidural steroid injections for symptomatic contained lumbar disc herniation: a prospective, randomized, controlled trial. J Neurosurg Spine. Apr. 2010;12(4):357-371. [pmid: 20201654].
Ghahreman A, Bogduk N. Predictors of a favorable response to transforaminal injection of steroids in patients with lumbar radicular pain due to disc herniation. Pain Med. 2011;12(6):871-879. [pmid: 21539702].
Ghahreman A, Ferch R, Bogduk N. The efficacy of transforaminal injection of steroids for the treatment of lumbar radicular pain. Pain Med. Aug. 2010;11(8):1149-1168. [pmid: 20704666].
Ghai B, Bansal D, Kay JP, et al. Transforaminal versus parasagittal interlaminar epidural steroid injection in low back pain with radicular pain: A randomized, double-blind, active-control trial. Pain Physician. 2014;17(4):277-290. [pmid: 25054387].
Ghai B, Vadaje KS, Wig J, et al. Lateral parasagittal versus midline interlaminar lumbar epidural steroid injection for management of low back pain with lumbosacral radicular pain: a double-blind, randomized study. Anesth Analg. Jul. 2013;117(1):219-227. [pmid: 23632053].
Gharibo CG, Varlotta GP, Rhame EE, et al. Interlaminar versus transforaminal epidural steroids for the treatment of subacute lumbar radicular pain: a randomized, blinded, prospective outcome study. Pain physician. Nov-Dec. 2011;14(6):499-511. [pmid: 22086091].
Habib G, Jabbour A, Salman J, et al. The effect of epidural methylprednisolone acetate injection on the hypothalamic-pituitary-adrenal axis. J Clin Anesth. 2013;25(8):629-633. [pmid: 23988802].
Helliwell M, Robertson J, Ellis R. Outpatient treatment of low-back pain and sciatica by a single extradural corticosteroid injection. British Journal of Clinical Practice. 1985;39(6):228-231. PMID: No PMID.
Huda N, Bansal P, Gupta SM, et al. The efficacy of epidural depo-methylprednisolone and triamcinolone acetate in relieving the symptoms of lumbar anal stenosis: a comparative study. J Clin and Diag Res. 2010;4:2843-2847.
Iversen T, Solberg TK, Romner B, et al. Effect of caudal epidural steroid or saline injection in chronic lumbar radiculopathy: multicentre, blinded, randomised controlled trial. Bmj. 2011;343:d5278. [pmid: 21914755].
Jeong HS, Lee JW, Kim SH, et al. Effectiveness of transforaminal epidural steroid injection by using a preganglionic approach: a prospective randomized controlled study. Radiology. Nov. 2007;245(2):584-590. [pmid: 17940309].
Kang S-S, Hwang B-M, Son H-J, et al. The dosages of corticosteroid in transforaminal epidural steroid injections for lumbar radicular pain due to a herniated disc. Pain physician. Jul-Aug. 2011;14(4):361-370. [pmid: 21785479].
Karppinen J, Malmivaara A, Kurunlahti M, et al. Periradicular infiltration for sciatica: a randomized controlled trial. Spine (Phila Pa 1976). May. 1. 2001;26(9):1059-1067. [pmid: 11337625].
Karppinen J, Ohinmaa A, Malmivaara A, et al. Cost effectiveness of periradicular infiltration for sciatica: subgroup analysis of a randomized controlled trial. Spine (Phila Pa 1976). 2001;26(23):2587-2595. [pmid: 11725240].
Kennedy DJ, Plastaras C, Casey E, et al. Comparative effectiveness of lumbar transforaminal epidural steroid injections with particulate versus nonparticulate corticosteroids for lumbar radicular pain due to intervertebral disc herniation: a prospective, randomized, double-blind trial. Pain Med. Apr. 2014;15(4):548-555. [pmid: 24393129].
Kim D, Brown J. Efficacy and safety of lumbar epidural dexamethasone versus methylprednisolone in the treatment of lumbar radiculopathy: a comparison of soluble versus particulate steroids. Clin J Pain. Jul-Aug. 2011;27(6):518-522. [pmid: 21562412].
Klenerman L, Greenwood R, Davenport HT, et al. Lumbar epidural injections in the treatment of sciatica. Br J Rheumatol. Feb. 1984;23(1):35-38. [pmid: 6697071].
Koc Z, Ozcakir S, Sivrioglu K, et al. Effectiveness of physical therapy and epidural steroid injections in lumbar spinal stenosis. Spine (Phila Pa 1976). May. 1. 2009;34(10):985-989. [pmid: 19404172].
Koh WU, Choi SS, Park SY, et al. Transforaminal hypertonic saline for the treatment of lumbar lateral canal stenosis: a double-blinded, randomized, active-control trial. Pain Physician. 2013;16(3):197-211. [pmid: 23703407].
Kolsi I, Delecrin J, Berthelot JM, et al. Efficacy of nerve root versus interspinous injections of glucocorticoids in the treatment of disk-related sciatica. A pilot, prospective, randomized, double-blind study. Joint Bone Spine. 2000;67(2):113-118. [pmid: 10769103].
Kraemer J, Ludwig J, Bickert U, et al. Lumbar epidural perineural injection: a new technique. Eur Spine J. 1997;6(5):357-361. [pmid: 9391811].
Laiq N, Khan MN, Iqbal MJ, et al. Comparison of Epidural Steroid Injections with conservative management in patients with lumbar radiculopathy. J Coll Physicians Surg Pak. Sep. 2009;19(9):539-543. [pmid: 19728936].
Lakemeier S, Lind M, Schultz W, et al. A comparison of intraarticular lumbar facet joint steroid injections and lumbar facet joint radiofrequency denervation in the treatment of low back pain: a randomized, controlled, double-blind trial. Anesth Analg. Jul. 2013;117(1):228-235. [pmid: 23632051].
Lee JH, An JH, Lee SH. Comparison of the effectiveness of interlaminar and bilateral transforaminal epidural steroid injections in treatment of patients with lumbosacral disc herniation and spinal stenosis. Clin J Pain. 2009;25(3):206-210. [pmid: 19333170].
Lilius G, Laasonen EM, Myllynen P, et al. Lumbar facet joint syndrome. A randomised clinical trial. J Bone Joint Surg Br. Aug. 1989;71(4):681-684. [pmid: 2527856].
Luukkainen RK, Wennerstrand PV, Kautiainen HH, et al. Efficacy of periarticular corticosteroid treatment of the sacroiliac joint in non-spondylarthropathic patients with chronic low back pain in the region of the sacroiliac joint. Clin Exp Rheumatol. Jan-Feb. 2002;20(1):52-54. [pmid: 11892709].
Manchikanti KN, Cash KA, McManus CD, et al. The preliminary results of a comparative effectivenesss evaluation of adhesiolysis and caudal epidural injections in managing chronic low back pain secondary to spinal stenosis: a randomized, equivalence controlled trial. Pain physician. 2009;12:E341-E54. [pmid: 19935991].
Manchikanti L, Cash KA, McManus CD, et al. Lumbar interlaminar epidural injections in central spinal stenosis: preliminary results of a randomized, double-blind, active control trial. Pain physician. Jan-Feb. 2012;15(1):51-63. [pmid: 22270738].
Manchikanti L, Cash KA, McManus CD, et al. Fluoroscopic caudal epidural injections in managing chronic axial low back pain without disc herniation, radiculitis, or facet joint pain. Journal of Pain Research. 2012;5:381-390. [pmid: 23091395].
Manchikanti L, Cash KA, McManus CD, et al. Preliminary results of a randomized, equivalence trial of fluoroscopic caudal epidural injections in managing chronic low back pain: Part 4--Spinal stenosis. Pain physician. Nov-Dec. 2008;11(6):833-848. [pmid: 19057629].
Manchikanti L, Cash KA, McManus CD, et al. Fluoroscopic lumbar interlaminar epidural injections in managing chronic lumbar axial or discogenic pain. Journal of Pain Research. 2012;5:301-311. [pmid: 23055773].
Manchikanti L, Cash KA, McManus CD, et al. Preliminary results of a randomized, double-blind, controlled trial of fluoroscopic lumbar interlaminar epidural injections in managing chronic lumbar discogenic pain without disc herniation or radiculitis. Pain physician. Jul-Aug. 2010;13(4):E279-E292. [pmid: 20648214].
Manchikanti L, Cash KA, McManus CD, et al. A randomized, double-blind, active-controlled trial of fluoroscopic lumbar interlaminar epidural injections in chronic axial or discogenic low back pain: Results of 2-year follow-up. Pain physician. 2013;16(5):E491-E504. [pmid: 24077199].
Manchikanti L, Cash KA, McManus CD, et al. Results of 2-year follow-up of a randomized, double-blind, controlled trial of fluoroscopic caudal epidural injections in central spinal stenosis. Pain physician. Sep-Oct. 2012;15(5):371-384. [pmid: 22996849].
Manchikanti L, Cash KA, McManus CD, et al. Fluoroscopic caudal epidural injections with or without steroids in managing pain of lumbar spinal stenosis: one-year results of randomized, double-blind, active-controlled trial. J Spinal Disord Tech. Jun. 2012;25(4):226-234. [pmid: 22652990].
Manchikanti L, Cash KA, McManus CD, et al. Preliminary results of a randomized, equivalence trial of fluoroscopic caudal epidural injections in managing chronic low back pain: Part 1--Discogenic pain without disc herniation or radiculitis. Pain physician. Nov-Dec. 2008;11(6):785-800. [pmid: 19057626].
Manchikanti L, Cash KA, McManus CD, et al. One-year results of a randomized, double-blind, active controlled trial of fluoroscopic caudal epidural injections with or without steroids in managing chronic discogenic low back pain without disc herniation or radiculitis. Pain Physician. Jan-Feb. 2011;14(1):25-36. [pmid: 21267039].
Manchikanti L, Pampati V, Bakhit CE, et al. Effectiveness of lumbar facet joint nerve blocks in chronic low back pain: a randomized clinical trial. Pain Physician. Jan. 2001;4(1):101-117. [pmid: 16906173].
Manchikanti L, Singh V, Cash KA, et al. Assessment of effectiveness of percutaneous adhesiolysis and caudal epidural injections in managing post lumbar surgery syndrome: 2-year follow-up of a randomized, controlled trial. J Pain Res. 2012;5:597-608. [pmid: 23293536].
Manchikanti L, Singh V, Cash KA, et al. Preliminary results of a randomized, equivalence trial of fluoroscopic caudal epidural injections in managing chronic low back pain: Part 2--Disc herniation and radiculitis. Pain physician. Nov-Dec. 2008;11(6):801-815. [pmid: 19057627].
Manchikanti L, Singh V, Cash KA, et al. A randomized, controlled, double-blind trial of fluoroscopic caudal epidural injections in the treatment of lumbar disc herniation and radiculitis. Spine. Nov. 1. 2011;36(23):1897-1905. [pmid: 21897343].
Manchikanti L, Singh V, Cash KA, et al. Effect of fluoroscopically guided caudal epidural steroid or local anesthetic injections in the treatment of lumbar disc herniation and radiculitis: a randomized, controlled, double blind trial with a two-year follow-up. Pain physician. Jul-Aug. 2012;15(4):273-286. [pmid: 22828681].
Manchikanti L, Singh V, Cash KA, et al. The role of fluoroscopic interlaminar epidural injections in managing chronic pain of lumbar disc herniation or radiculitis: a randomized, double-blind trial. Pain pract. 2013;13(7):547-558. [pmid: 23279452].
Manchikanti L, Singh V, Cash KA, et al. A randomized, double-blind, active-control trial of the effectiveness of lumbar interlaminar epidural injections in disc herniation. Pain Physician. 2014;17(1):E61-E74. [pmid: 24452658].
Manchikanti L, Singh V, Falco FJ, et al. Evaluation of lumbar facet joint nerve blocks in managing chronic low back pain: a randomized, double-blind, controlled trial with a 2-year follow-up. Int J Med Sci. 2010;7(3):124-135. [pmid: 20567613].
Manchikanti L, Singh V, Falco FJ, et al. Evaluation of the effectiveness of lumbar interlaminar epidural injections in managing chronic pain of lumbar disc herniation or radiculitis: a randomized, double-blind, controlled trial. Pain Physician. Jul-Aug. 2010;13(4):343-355. [pmid: 20648203].
Manchikanti L, Singh V, Falco FJE, et al. Lumbar facet joint nerve blocks in managing chronic facet joint pain: one-year follow-up of a randomized, double-blind controlled trial: Clinical Trial NCT00355914. Pain Physician. Mar-Apr. 2008;11(2):121-132. [pmid: 18354721].
Marks RC, Houston T, Thulbourne T. Facet joint injection and facet nerve block: a randomised comparison in 86 patients with chronic low back pain. Pain. Jun. 1992;49(3):325-328. [pmid: 1408298].
Matthews JA, Mills SB, Jenkins VM, et al. Back Pain and Sciatica: Controlled Trials of Manipulation, Traction, Sclerosant, and Epidural Injections. 1987. [pmid: 2961394].
McCahon RA, Ravenscroft A, Hodgkinson V, et al. A pilot study of the dose-response of caudal methylprednisolone with levobupivacaine in chronic lower back pain. Anaesthesia. Jul. 2011;66(7):595-603. [pmid: 21564047].
Meadeb J, Rozenberg S, Duquesnoy B, et al. Forceful sacrococcygeal injections in the treatment of postdiscectomy sciatica. A controlled study versus glucocorticoid injections. Joint Bone Spine. Feb. 2001;68(1):43-49. [pmid: 11235780].
Murakibhavi VG, Khemka AG. Caudal epidural steroid injection: a randomized controlled trial. Evid Based Spine Care J. Nov. 2011;2(4):19-26. [pmid: 23230402].
Nam HS, Park YB. Effects of transforaminal injection for degenerative lumbar scoliosis combined with spinal stenosis. Ann Rehabil Med. Aug. 2011;35(4):514-523. [pmid: 22506167].
Nash T. Facet joints-intra-articular steroids or nerve block. Pain Clinic. 1990;3(2):77-82. PMID: No PMID.
Ng L, Chaudhary N, Sell P. The efficacy of corticosteroids in periradicular infiltration for chronic radicular pain: a randomized, double-blind, controlled trial. Spine (Phila Pa 1976). Apr. 15. 2005;30(8):857-862. [pmid: 15834326].
Ohtori S, Miyagi M, Eguchi Y, et al. Epidural administration of spinal nerves with the tumor necrosis factor-alpha inhibitor, etanercept, compared with dexamethasone for treatment of sciatica in patients with lumbar spinal stenosis: a prospective randomized study. Spine. Mar. 15. 2012;37(6):439-444. [pmid: 22020607].
Owlia MB, Salimzadeh A, Alishiri G, et al. Comparison of two doses of corticosteroid in epidural steroid injection for lumbar radicular pain. Singapore Med J. Mar. 2007;48(3):241-245. [pmid: 17342295].
Park CH, Lee SH, Kim BI. Comparison of the effectiveness of lumbar transforaminal epidural injection with particulate and nonparticulate corticosteroids in lumbar radiating pain. Pain Med. Nov. 2010;11(11):1654-1658. [pmid: 20807343].
Park Y, Lee J-H, Park KD, et al. Ultrasound-guided vs. fluoroscopy-guided caudal epidural steroid injection for the treatment of unilateral lower lumbar radicular pain: a prospective, randomized, single-blind clinical study. Am J Phys Med Rehabil. Jul. 2013;92(7):575-586. [pmid: 23636087].
Pneumaticos SG, Chatziioannou SN, Hipp JA, et al. Low back pain: prediction of short-term outcome of facet joint injection with bone scintigraphy. Radiology. Feb. 2006;238(2):693-698. [pmid: 16436824].
Price C, Arden N, Coglan L, et al. Cost-effectiveness and safety of epidural steroids in the management of sciatica. Health Technol Assess. Aug. 2005;9(33):1-58. iii. [pmid: 16095548].
Rados I, Sakic K, Fingler M, et al. Efficacy of interlaminar vs transforaminal epidural steroid injection for the treatment of chronic unilateral radicular pain: prospective, randomized study. Pain Med. Sep. 2011;12(9):1316-1321. [pmid: 21914118].
Rahimzadeh P, Sharma V, Imani F, et al. Adjuvant hyaluronidase to epidural steroid improves the quality of analgesia in failed back surgery syndrome: a prospective randomized clinical trial. Pain Physician. 2014;17(1):E75-E82. [pmid: 24452659].
Ribeiro LH, Furtado RN, Konai MS, et al. Effect of facet joint injection versus systemic steroids in low back pain: a randomized controlled trial. Spine. 2013;38(23):1995-2002. [pmid: 23921331].
Ridley M, Kingsley G, Gibson T, et al. Outpatient lumbar epidural corticosteroid injection in the management of sciatica. Rheumatology (Oxford). Aug. 1988;27(4):295-299. [pmid: 3408828].
Riew KD, Park JB, Cho YS, et al. Nerve root blocks in the treatment of lumbar radicular pain. A minimum five-year follow-up. J Bone Joint Surg Am. Aug. 2006;88(8):1722-1725. [pmid: 16882893].
Riew KD, Yin Y, Gilula L, et al. The effect of nerve-root injections on the need for operative treatment of lumbar radicular pain. A prospective, randomized, controlled, double-blind study. J Bone Joint Surg Am. Nov. 2000;82-A(11):1589-1593. [pmid: 11097449].
Rocco AG, Frank E, Kaul AF, et al. Epidural steroids, epidural morphine and epidural steroids combined with morphine in the treatment of post-laminectomy syndrome. Pain. Mar. 1989;36(3):297-303. [pmid: 2523528].
Rogers P, Nash T, Schiller D, et al. Epidural steroids for sciatica. Pain Clinic. 1992;5:67-72. PMID: No PMID.
Sayegh FE, Kenanidis EI, Papavasiliou KA, et al. Efficacy of steroid and nonsteroid caudal epidural injections for low back pain and sciatica: a prospective, randomized, double-blind clinical trial. Spine (Phila Pa 1976). Jun. 15. 2009;34(14):1441-1447. [pmid: 19525834].
Snoek W, Weber H, Jorgensen B. Double blind evaluation of extradural methyl prednisolone for herniated lumbar discs. Acta Orthop Scand. 1977;48(6):635-641. [pmid: 343479].
Tafazal S, Ng L, Chaudhary N, et al. Corticosteroids in peri-radicular infiltration for radicular pain: a randomised double blind controlled trial. One year results and subgroup analysis. Eur Spine J. August. 1. 2009;18(8):1220-1225. [pmid: 19387704].
Tauheed N, Usmani H, Siddiqui AH. A comparison of the analgesic efficacy of transforaminal methylprednisolone alone and with low doses of clonidine in lumbo-sacral radiculopathy. Saudi J Anaesth. 2014;8(1):51-58. [pmid: 24665240].
Thomas E, Cyteval C, Abiad L, et al. Efficacy of transforaminal versus interspinous corticosteroid injectionin discal radiculalgia - a prospective, randomised, double-blind study. Clin Rheumatol. Oct. 2003;22(4–5):299-304. [pmid: 14579160].
Valat JP, Giraudeau B, Rozenberg S, et al. Epidural corticosteroid injections for sciatica: a randomised, double blind, controlled clinical trial. Ann Rheum Dis. Jul. 2003;62(7):639-643. [pmid: 12810426].
Wilson-MacDonald J, Burt G, Griffin D, et al. Epidural steroid injection for nerve root compression. A randomised, controlled trial. J Bone Joint Surg. Br. Mar. 2005;87(3):352-355. [pmid: 15773645].