# PICOTS

PICOT | Include | Exclude
Population and Conditions of Interest | - For all KQs: Adults with subacute (4 to 12 weeks) or chronic (>12 weeks) symptoms of the following:; - For epidural corticosteroid injections-Nonradicular low back pain, low back pain with radiculopathy, or spinal stenosis; - For facet joint corticosteroid injection and medial branch block- Nonradicular low back pain; - For sacroiliac joint corticosteroid injection-Nonradicular back pain in the sacroiliac region | - Persons younger than 18 years of age
Interventions | - All KQs: Epidural corticosteroid injection, facet joint corticosteroid injection, medial branch block, sacroiliac joint corticosteroid joint injection | - Intraspinal injections involving anti-tumor necrosis factor agents, radiofrequency denervation, intradiscal electrothermal therapy, chemonucleolysis, and intradiscal methylene blue or ozone
Comparators | - For KQ 2: Studies that evaluate the effects of patient characteristics (e.g., age, sex, duration of pain, pain level, expectations of treatment benefits, confidence in clinician, worker’s compensation status, ongoing litigation, smoking status, or other treatment received) or findings with interventional diagnostic techniques (e.g., discography, selective nerve root block, facet joint block, medial branch block, sacroiliac joint block), imaging studies, and/or other clinical criteria.; - For KQs 1, 3, and 4: Saline epidural, epidural with local anesthetic, nonepidural injection, no injection, surgery, or nonsurgical therapies. | - Uncontrolled or pre-post studies
Outcomes | - For KQs 1 2, 3: Pain, function, quality of life, opioid use, subsequent surgery, health care utilization; - For KQ 4: Harms, including bleeding, infection, neurological events, and systemic complications, such as weight gain, diabetes, osteoporosis, and other endocrinological effects
Timing | - For all KQs: Outcomes measured 1 week or later after the injection; durability of treatment response will be assessed
Setting | - For all KQs: No restrictions
Study Design | - For KQs 1–3: randomized trials; - For KQ 4: randomized trials or controlled cohort studies

KQ=key question; PICOT=populations; interventions, comparators, outcomes, timing, setting.