# Search Strategies

## Database: Ovid MEDLINE(R) without Revisions

1 | Low Back Pain/ or Spinal Stenosis/ or Radiculopathy/ or ("low back pain" or "spinal adj3 stenosis" or "radiculopathy").mp.
2 | spine/ or coccyx/ or intervertebral disk/ or lumbar vertebrae/ or sacrum/ or spinal canal/ or exp back/ or facet joint/ or zygapophysial joint/ or sacroiliac.mp.
3 | Chronic Pain/ or (chronic adj3 pain).mp.
4 | 2 and 3
5 | 1 or 4
6 | Patient Selection/
7 | exp Treatment Outcome/
8 | Prognosis/ or (prognosis or prognostic).mp.
9 | (patient$ adj5 select$).mp.
10 | (select$ adj5 method$).mp.
11 | or/6–10
12 | exp Injections, Spinal/ or exp Injections, Intra-Articular/
13 | ((spine$ or spinal$ or epidural or facet or sacroiliac or "medial branch") adj5 (block or injection$)).mp.
14 | 12 or 13
15 | 5 and 14
16 | 5 and 11
17 | 16 and inject*.mp.
18 | 11 and 14
19 | 18 and "low back pain".mp.
20 | 15 or 17 or 19
21 | 20 and (random* or control* or cohort).mp.
22 | limit 21 to yr="2008 – 2014"

## Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 | Low Back Pain/ or Spinal Stenosis/ or Radiculopathy/ or ("low back pain" or "spinal adj3 stenosis" or "radiculopathy").mp.
2 | spine/ or coccyx/ or intervertebral disk/ or lumbar vertebrae/ or sacrum/ or spinal canal/ or exp back/ or facet joint/ or zygapophysial joint/ or sacroiliac.mp.
3 | Chronic Pain/ or (chronic adj3 pain).mp.
4 | 2 and 3
5 | 1 or 4
6 | Patient Selection/
7 | exp Treatment Outcome/
8 | Prognosis/ or (prognosis or prognostic).mp.
9 | (patient$ adj5 select$).mp.
10 | (select$ adj5 method$).mp.
11 | or/6–10
12 | exp Injections, Spinal/ or exp Injections, Intra-Articular/
13 | ((spine$ or spinal$ or epidural or facet or sacroiliac or "medial branch") adj5 (block or injection$)).mp.
14 | 12 or 13
15 | 5 and 14
16 | 5 and 11
17 | 16 and inject*.mp.
18 | 11 and 14
19 | 18 and "low back pain".mp.
20 | 15 or 17 or 19 (1306)
21 | limit 20 to yr="2008 – 2014"

## Database: EBM Reviews - Cochrane Database of Systematic Reviews

1 | low back pain.ti.
2 | 1 and (epidural or facet or sacroiliac or "medial branch" or injection).mp.