# Acknowledgments

We thank Rebecca Holmes, M.D., Ian Blazina M.P.H., and Alex Ginsburg, M.A., M.C.R.P. for assistance with data abstraction; Sara Grusing, B.A., for assistance with the EndNote library; and Leah Williams, B.S., for editorial support; Oregon Health and Science University.