# REFERENCES

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 3rd ed. Rockville, MD. Agency for Healthcare Research and Quality. 2002.
2 U.S. Preventive Services Task Force. Screening for high blood pressure: recommendations and rationale. Am Fam Physician. 2003;68:2019-22. [pmid: 14655813].
3 Flynn JT, Falkner BE. The importance of blood pressure screening in children. J Pediatr. 2009;155:299-300. [pmid: 19619758].
4 Din-Dzietham R, Liu Y, Bielo MV, Shamsa F. High blood pressure trends in children and adolescents in national surveys, 1963 to 2002. Circulation. 2007;116:1488-96. [pmid: 17846287].
5 Feber J, Ahmed M. Hypertension in children: new trends and challenges. Clin Sci. 2010;119:151-61. [pmid: 20477751].
6 National High Blood Pressure Education Program Working Group on High Blood Pressure in Children and Adolescents. The fourth report on the diagnosis, evaluation, and treatment of high blood pressure in children and adolescents. Pediatrics. 2004;114:555-76. [pmid: 15286277].
7 Luma GB, Spiotta RT, American Academy of Family Physicians. Hypertension in children and adolescents. Am Fam Physician. 2006;73:1558-68. [pmid: 16719248].
8 Expert Panel on Integrated Guidelines for Cardiovascular Health and Risk Reduction in Children and Adolescents, National Heart, Lung, and Blood Institute. Expert panel on integrated guidelines for cardiovascular health and risk reduction in children and adolescents: summary report. Pediatrics. 2011;128(Suppl 5):S213-56. [pmid: 22084329].
9 Lurbe E, Álvarez J, Redon J. Diagnosis and treatment of hypertension in children. Curr Hypertens Rep. 2010;12:480-6. [pmid: 20872099].
10 Obarzanek E, Wu CO, Cutler JA, Kavey RW, Pearson GD, Daniels SR. Prevalence and incidence of hypertension in adolescent girls. J Pediatr. 2010;157:461-7. [pmid: 20488454].
11 Sorof JM, Lai D, Turner J, Poffenbarger T, Portman RJ. Overweight, ethnicity, and the prevalence of hypertension in school-aged children. Pediatrics. 2004;113:475-82. [pmid: 14993537].
12 Flynn JT, Alderman MH. Characteristics of children with primary hypertension seen at a referral center. Pediatr Nephrol. 2005;20:961-6. [pmid: 15864653].
13 Viera AJ, Neutze DM. Diagnosis of secondary hypertension: an age-based approach. Am Fam Physician. 2010;82:1471-8. [pmid: 21166367].
14 Muntner P, He J, Cutler JA, Wildman RP, Whelton PK. Trends in blood pressure among children and adolescents. JAMA. 2004;291:2107. [pmid: 15126439].
15 Brady TM, Solomon BS, Neu AM, Siberry GK, Parekh RS. Patient-, provider-, and clinic-level predictors of unrecognized elevated blood pressure in children. Pediatrics. 2010;125:e1286-92. [pmid: 20439598].
16 Hansen ML, Gunn PW, Kaelber DC, Hansen ML, Gunn PW, Kaelber DC. Underdiagnosis of hypertension in children and adolescents. JAMA. 2007;298:874-9. [pmid: 17712071].
17 Flynn JT. Evaluation and management of hypertension in childhood. Prog Pediatr Cardiol. 2001;12:177-88. [pmid: 11223345].
18 Litwin M, Niemirska A, Sladowska-Kozlowska J, et al. Regression of target organ damage in children and adolescents with primary hypertension. Pediatr Nephrol. 2010;25:2489-99. [pmid: 20730452].
19 Brady TM, Fivush B, Flynn JT, Parekh R. Ability of blood pressure to predict left ventricular hypertrophy in children with primary hypertension. J Pediatr. 2008;152:73-8. [pmid: 18154904].
20 McNiece KL, Gupta-Malhotra M, Samuels J, et al. Left ventricular hypertrophy in hypertensive adolescents: analysis of risk by 2004 National High Blood Pressure Education Program Working Group staging criteria. Hypertension. 2007;50:392-5. [pmid: 17592068].
21 Lande MB, Carson NL, Roy J, Meagher CC. Effects of childhood primary hypertension on carotid intima media thickness: a matched controlled study. Hypertension. 2006;48:40-4. [pmid: 16735644].
22 Laird WP, Fixler DE. Left ventricular hypertrophy in adolescents with elevated blood pressure: assessment by chest roentgenography, electrocardiography, and echocardiography. Pediatrics. 1981;67:255-9. [pmid: 6454105].
23 Lurbe E. Hypertension and target organ damage in children and adolescents. J Hypertens. 2007;25:1998-2000. [pmid: 17885537].
24 Sun SS, Grave GD, Siervogel RM, Pickoff AA, Arslanian SS, Daniels SR. Systolic blood pressure in childhood predicts hypertension and metabolic syndrome later in life. Pediatrics. 2007;119:237-46. [pmid: 17272612].
25 Kaelber DC, Pickett F. Simple table to identify children and adolescents needing further evaluation of blood pressure. Pediatrics. 2009;123:e972-4. [pmid: 19414519].
26 Pickering TG, Hall JE, Appel LJ, et al. Recommendations for blood pressure measurement in humans: an AHA scientific statement from the Council on High Blood Pressure Research Professional and Public Education Subcommittee. J Clin Hypertens. 2005;7:102-9.
27 Whitlock EP, O'Connor EA, Williams SB, Beil TL, Lutz KW. Effectiveness of weight management interventions in children: a targeted systematic review for the USPSTF. Pediatrics. 2010;125:e396-418. [pmid: 20083531].
28 Haney EM, Huffman LH, Bougatsos C, Freeman M, Steiner RD, Nelson HD. Screening and treatment for lipid disorders in children and adolescents: systematic evidence review for the U.S. Preventive Services Task Force. Pediatrics. 2007;120:e189-214. [pmid: 17606543].
29 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
30 Leeflang MM, Deeks JJ, Gatsonis C, Bossuyt PM, Cochrane Diagnostic Test Accuracy Working Group. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149:889-97. [pmid: 19075208].
31 Stergiou GS, Nasothimiou E, Giovas P, Kapoyiannis A, Vazeou A. Diagnosis of hypertension in children and adolescents based on home versus ambulatory blood pressure monitoring. J Hypertens. 2008;26:1556-62. [pmid: 18622232].
32 Soergel M, Kirschstein M, Busch C, et al. Oscillometric twenty-four-hour ambulatory blood pressure values in healthy children and adolescents: a multicenter trial including 1141 subjects. J Pediatr. 1997;130:178-84. [pmid: 9042117].
33 Fixler DE, Laird WP. Validity of mass blood pressure screening in children. Pediatrics. 1983;72:459-63. [pmid: 6889060].
34 Berenson GS, Dalferes E Jr, Savage D, Webber LS, Bao W. Ambulatory blood pressure measurements in children and young adults selected by high and low casual blood pressure levels and parental history of hypertension: the Bogalusa Heart Study. Am J Med Sci. 1993;305:374-82. [pmid: 8506897].
35 Ewart CK, Harris WL, Iwata MM, Coates TJ, Bullock R, Simon B. Feasibility and effectiveness of school-based relaxation in lowering blood pressure. Health Psychol. 1987;6:399-416. [pmid: 3315645].
36 Fixler DE, Laird WP, Fitzgerald V, Stead S, Adams R. Hypertension screening in schools: results of the Dallas study. Pediatrics. 1979;63:32-6. [pmid: 440800].
37 Kelsall JE, Watson AR. Should school nurses measure blood pressure?. Public Health. 1990;104:191-4. [pmid: 2359839].
38 Michaud PA. Adolescent hypertension: a follow-up study in the community. Rev Epidemiol Sante Publique. 1989;37:23-8. [pmid: 2710975].
39 Miller FS 3rd, Record NB Jr. Hypertension control in rural Maine. Franklin County High Blood Pressure Program. J Maine Med Assoc. 1976;67:280-3. [pmid: 978056].
40 Moore WE, Eichner JE, Cohn EM, Thompson DM, Kobza CE, Abbott KE. Blood pressure screening of school children in a multiracial school district: the Healthy Kids Project. Am J Hypertens. 2009;22:351-6. [pmid: 19214168].
41 Rames LK, Clarke WR, Connor WE, Reiter MA, Lauer RM. Normal blood pressure and the evaluation of sustained blood pressure elevation in childhood: the Muscatine Study. Pediatrics. 1978;61:245-251. [pmid: 634679].
42 Reichman LB, Cooper BM, Blumenthal S, et al. Hypertension testing among high school students, I: surveillance procedures and results. J Chronic Dis. 1975;28:161-71. [pmid: 1123422].
43 Sailors EL. Project “Hypertension Alert”. J Sch Health. 1983;53:374-6. [pmid: 6555439].
44 Sinaiko AR, Gomez-Marin O, Prineas RJ. “Significant” diastolic hypertension in pre-high school black and white children. The Children and Adolescent Blood Pressure Program. Am J Hypertens. 1988;1:178-80. [pmid: 3401357].
45 Stern B, Heyden S, Miller D, Latham G, Klimas A, Pilkington K. Intervention study in high school students with elevated blood pressures: dietary experiment with polyunsaturated fatty acids. Nutr Metab. 1980;24:137-47. [pmid: 7443094].
46 Bao W, Threefoot SA, Srinivasan SR, Berenson GS. Essential hypertension predicted by tracking of elevated blood pressure from childhood to adulthood: the Bogalusa Heart Study. Am J Hypertens. 1995;8:657-65. [pmid: 7546488].
47 Beckett LA, Rosner B, Roche AF, Guo S. Serial changes in blood pressure from adolescence into adulthood. Am J Epidemiol. 1992;135:1166-77. [pmid: 1632426].
48 Gillman MW, Cook NR, Rosner B, et al. Identifying children at high risk for the development of essential hypertension. J Pediatr. 1993;122:837-46. [pmid: 8501557].
49 Hoq S, Chen W, Srinivasan SR, Berenson GS. Childhood blood pressure predicts adult microalbuminuria in African Americans, but not in whites: the Bogalusa Heart Study. Am J Hypertens. 2002;15:1036-41. [pmid: 12460698].
50 Juhola J, Magnussen CG, Viikari JS, et al. Tracking of serum lipid levels, blood pressure, and body mass index from childhood to adulthood: the Cardiovascular Risk in Young Finns Study. J Pediatr. 2011;159:584-90. [pmid: 21514597].
51 Lauer RM, Clarke WR, Mahoney LT, Witt J. Childhood predictors for high adult blood pressure. The Muscatine Study. Pediatr Clin North Am. 1993;40:23-40. [pmid: 8417407].
52 Li S, Chen W, Srinivasan SR, et al. Childhood cardiovascular risk factors and carotid vascular changes in adulthood. JAMA. 2003;290:2271-6. [pmid: 14600185].
53 Raitakari OT, Juonala M, Kahonen M, et al. Cardiovascular risk factors in childhood and carotid artery intima-media thickness in adulthood: the Cardiovascular Risk in Young Finns Study. JAMA. 2003;(290):2277-83. [pmid: 14600186].
54 Shear CL, Burke GL, Freedman DS, Webber LS, Berenson GS. Designation of children with high blood pressure—considerations on percentile cut points and subsequent high blood pressure: the Bogalusa Heart Study. Am J Epidemiol. 1987;125:73-84. [pmid: 3788956].
55 Juonala M, Viikari JS, Hutri-Kahonen N, et al. The 21-year follow-up of the Cardiovascular Risk in Young Finns Study: risk factor levels, secular trends and east-west difference. J Intern Med. 2004;255:457-68. [pmid: 15049880].
56 Stenn PG, Noce A, Buck C. A study of the labelling phenomenon in school children with elevated blood pressure. Clin Invest Med. 1981;4:179-81. [pmid: 7337989].
57 Batisky DL, Sorof JM, Sugg J, et al. Efficacy and safety of extended release metoprolol succinate in hypertensive children 6 to 16 years of age: a clinical trial experience. J Pediatr. 2007;150:134-9. [pmid: 17236889].
58 Berenson GS, Voors AW, Webber LS, et al. A model of intervention for prevention of early essential hypertension in the 1980s. Hypertension. 1983;5:41-54. [pmid: 6848468].
59 Berenson GS, Shear CL, Chiang YK, Webber LS, Voors AW. Combined low-dose medication and primary intervention over a 30-month period for sustained high blood pressure in childhood. Am J Med Sci. 1990;299:79-86. [pmid: 2301454].
60 Couch SC, Saelens BE, Levin L, Dart K, Falciglia G, Daniels SR. The efficacy of a clinic-based behavioral nutrition intervention emphasizing a DASH-type diet for adolescents with elevated blood pressure. J Pediatr. 2008;152:494-501. [pmid: 18346503].
61 Flynn JT, Newburger JW, Daniels SR, et al. A randomized, placebo-controlled trial of amlodipine in children with hypertension. J Pediatr. 2004;145:353-9. [pmid: 15343191].
62 Gregoski MJ, Barnes VA, Tingen MS, Harshfield GA, Treiber FA. Breathing awareness meditation and LifeSkills training programs influence upon ambulatory blood pressure and sodium excretion among African American adolescents. J Adolesc Health. 2011;48:59-64. [pmid: 21185525].
63 Hansen HS, Froberg K, Hyldebrandt N, Nielsen JR. A controlled study of eight months of physical training and reduction of blood pressure in children: the Odense Schoolchild Study. BMJ. 1991;303:682-5. [pmid: 1912915].
64 Howe PR, Cobiac L, Smith RM. Lack of effect of short-term changes in sodium intake on blood pressure in adolescent schoolchildren. J Hypertens. 1991;9:181-6. [pmid: 1849536].
65 Li JS, Flynn JT, Portman R, et al. The efficacy and safety of the novel aldosterone antagonist eplerenone in children with hypertension: a randomized, double-blind, dose-response study. J Pediatr. 2010;157:282-7. [pmid: 20400095].
66 Sinaiko AR, Gomez-Marin O, Prineas RJ. Effect of low sodium diet or potassium supplementation on adolescent blood pressure. Hypertension. 1993;21:989-94. [pmid: 8505112].
67 Sorof JM, Cargo P, Graepel J, et al. Beta-blocker/thiazide combination for treatment of hypertensive children: a randomized double-blind, placebo-controlled trial. Pediatr Nephrol. 2002;17:345-50. [pmid: 12042891].
68 Trachtman H, Frank R, Mahan JD, et al. Clinical trial of extended-release felodipine in pediatric essential hypertension. Pediatr Nephrol. 2003;18:548-53. [pmid: 12700955].
69 Trachtman H, Hainer JW, Sugg J, et al. Efficacy, safety, and pharmacokinetics of candesartan cilexetil in hypertensive children aged 6 to 17 years. J Clin Hypertens. 2008;10:743-50.
70 Wells TG, Portman R, Norman P, Haertter S, Davidai G, Fei W. Safety, efficacy, and pharmacokinetics of telmisartan in pediatric patients with hypertension. Clin Pediatr. 2010;49:938-46.
71 Frank GC, Farris RP, Ditmarsen P, Voors AW, Berenson GS. An approach to primary preventive treatment for children with high blood pressure in a total community. J Am Coll Nutr. 1982;1:357-74. [pmid: 7185868].
72 Batisky DL. Obesity and the role of lifestyle and dietary intervention in the management of pediatric hypertension. J Med Liban. 2010;58:171-4. [pmid: 21462848].
73 Hazan L, Hernandez Rodriguez OA, Bhorat AE, et al. A double-blind, dose-response study of the efficacy and safety of olmesartan medoxomil in children and adolescents with hypertension. Hypertension. 2010;55:1323-30. [pmid: 20385971].
74 Li JS, Berezny K, Kilaru R, et al. Is the extrapolated adult dose of fosinopril safe and effective in treating hypertensive children?. Hypertension. 2004;44:289-93. [pmid: 15262902].
75 Shahinfar S, Cano F, Soffer BA, et al. A double-blind, dose-response study of losartan in hypertensive children. Am J Hypertens. 2005;18:183-90. [pmid: 15752945].
76 Soffer B, Zhang Z, Miller K, Vogt BA, Shahinfar S. A double-blind, placebo-controlled, dose-response study of the effectiveness and safety of lisinopril for children with hypertension. Am J Hypertens. 2003;16:795-800. [pmid: 14553956].
77 Wells T, Frame V, Soffer B, et al. A double-blind, placebo-controlled, dose-response study of the effectiveness and safety of enalapril for children with hypertension. J Clin Pharmacol. 2002;42:870-80. [pmid: 12162469].
78 Smith PB, Li JS, Murphy MD, Califf RM, Benjamin DK Jr. Safety of placebo controls in pediatric hypertension trials. Hypertension. 2008;51:829-33. [pmid: 18285612].
79 Baker-Smith CM, Benjamin DK Jr, Califf RM, Murphy MD, Li JS, Smith PB. Cough in pediatric patients receiving angiotensin-converting enzyme inhibitor therapy or angiotensin receptor blocker therapy in randomized controlled trials. Clin Pharmacol Ther. 2010;87:668-71. [pmid: 20130570].
80 Falkner B, Gidding SS, Ramirez-Garnica G, Wiltrout SA, West D, Rappaport EB. The relationship of body mass index and blood pressure in primary care pediatric patients. J Pediatr. 2006;148:195-200. [pmid: 16492428].
81 Jung FF, Ingelfinger JR. Hypertension in childhood and adolescence. Pediatr Rev. 1993;14:169-79. [pmid: 8493186].
82 Hohn AR, Dwyer KM, Dwyer JH. Blood pressure in youth from four ethnic groups: the Pasadena Prevention Project. J Pediatr. 1994;125:368-73. [pmid: 8071743].
83 Rosner B, Cook N, Portman R, Daniels S, Falkner B. Blood pressure differences by ethnic group among United States children and adolescents. Hypertension. 2009;54:502-8. [pmid: 19652080].
84 Chiolero A, Cachat Fo, Burnier M, Paccaud F, Bovet P. Prevalence of hypertension in schoolchildren based on repeated measurements and association with overweight. J Hypertens. 2007;25:2209-17. [pmid: 17921814].
85 Liao CC, Su TC, Chien KL, et al. Elevated blood pressure, obesity, and hyperlipidemia. J Pediatr. 2009;155:79-83. [pmid: 19446850].
86 Jago R, Harrell JS, McMurray RG, Edelstein S, El Ghormli L, Bassin S. Prevalence of abnormal lipid and blood pressure values among an ethnically diverse population of eighth-grade adolescents and screening implications. Pediatrics. 2006;117:2065-73. [pmid: 16740849].
87 Mehta SK, Super DM, Anderson RL, et al. Parental hypertension and cardiac alterations in normotensive children and adolescents. Am Heart J. 1996;131:81-8. [pmid: 8554024].
88 Orchard TJ, Hedley AJ, Mitchell JR. The distribution and associations of blood pressure in an adolescent population. J Epidemiol Community Health. 1982;36:35-42. [pmid: 6978373].
89 Treiber FA, McCaffrey F, Musante L, et al. Ethnicity, family history of hypertension and patterns of hemodynamic reactivity in boys. Psychosom Med. 1993;55:70-7. [pmid: 8446745].
90 Zinner SH, Levy PS, Kass EH. Familial aggregation of blood pressure in childhood. N Engl J Med. 1971;284:401-4. [pmid: 5540477].
91 Ibsen KK. Blood-pressures in offspring of hypertensive parents. Acta Paediatr Scand. 1984;73:842-7. [pmid: 6524370].
92 de Visser DC, van Hooft IM, van Doornen LJ, Hofman A, Orlebeke JF, Grobbee DE. Anthropometric measures, fitness and habitual physical activity in offspring of hypertensive parents. Dutch Hypertension and Offspring Study. Am J Hypertens. 1994;7:242-8. [pmid: 8003275].
93 Watt GC, Foy CJ, Holton DW, Edwards HE. Prediction of high blood pressure in young people: the limited usefulness of parental blood pressure data. J Hypertens. 1991;9:55-8. [pmid: 1848260].
94 Martin RM, Ness AR, Gunnell D, Emmett P, Davey Smith G, Team AS. Does breast-feeding in infancy lower blood pressure in childhood? The Avon Longitudinal Study of Parents and Children (ALSPAC). Circulation. 2004;109:1259-66. [pmid: 14993142].
95 Wilson AC, Forsyth JS, Greene SA, Irvine L, Hau C, Howie PW. Relation of infant diet to childhood health: seven year follow up of cohort of children in Dundee Infant Feeding Study. BMJ. 1998;316:21-5. [pmid: 9451261].
96 Wang YC, Cheung AM, Bibbins-Domingo K, et al. Effectiveness and cost-effectiveness of blood pressure screening in adolescents in the United States. J Pediatr. 2011;158:257-64. [pmid: 20850759].
97 Woroniecki RP, Flynn JT. How are hypertensive children evaluated and managed? A survey of North American pediatric nephrologists. Pediatr Nephrol. 2005;20:791-7. [pmid: 15809834].
98 Lurbe E, Cremades B, Rodriguez C, Torro MI, Alvarez V, Redon J. Factors related to quality of ambulatory blood pressure monitoring in a pediatric population. Am J Hypertens. 1999;12:929-33. [pmid: 10509553].
99 Parati G, Stergiou GS. Self measured and ambulatory blood pressure in assessing the “white-coat” phenomenon. J Hypertens. 2003;21:677-82. [pmid: 12658008].
100 Stergiou GS, Karpettas N, Kapoyiannis A, Stefanidis CJ, Vazeou A. Home blood pressure monitoring in children and adolescents: a systematic review. J Hypertens. 2009;27:1941-7. [pmid: 19542894].
101 Acosta AA, McNiece KL. Ambulatory blood pressure monitoring: a versatile tool for evaluating and managing hypertension in children. Pediatr Nephrol. 2008;23:1399-408. [pmid: 18297314].
102 Lurbe E, Torro I, Alvarez V, et al. Prevalence, persistence, and clinical significance of masked hypertension in youth. Hypertension. 2005;45:493-8. [pmid: 15767467].
103 Verdecchia P, Reboldi GP, Angeli F, et al. Short- and long-term incidence of stroke in white-coat hypertension. Hypertension. 2005;45:203-8. [pmid: 15596572].
104 Stabouli S, Kotsis V, Toumanidis S, Papamichael C, Constantopoulos A, Zakopoulos N. White-coat and masked hypertension in children: association with target-organ damage. Pediatr Nephrol. 2005;20:1151-5. [pmid: 15947982].
105 Pickering TG, Eguchi K, Kario K. Masked hypertension: a review. Hypertens Res. 2007;30:479-88. [pmid: 17664850].
106 Lurbe E, Sorof JM, Daniels SR. Clinical and research aspects of ambulatory blood pressure monitoring in children. J Pediatr. 2004;144:7-16. [pmid: 14722512].
107 Stergiou GS, Yiannes NG, Rarra VC, Panagiotakos DB. Home blood pressure normalcy in children and adolescents: the Arsakeion School Study. J Hypertens. 2007;25:1375-9. [pmid: 17563558].