# DISCUSSION

## Summary of Review Findings

A summary of the evidence is provided in Table 9.

Table 9 Summary of Evidence

No. of Studies Overall quality rating | Limitations | Consistency | Primary care applicability | Summary of findings
Key Question 1. Is screening for hypertension in children/adolescents effective in delaying the onset of or reducing adverse health outcomes related to hypertension?
No studies | NA | NA | NA | NA
Key Question 2. What is the diagnostic accuracy of screening tests for elevated blood pressure in children/adolescents?
2 trials Quality of evidence: Poor | Studies were flawed or not directly applicable to an asymptomatic U.S. population; Only one included a comparison to a gold standard of ambulatory monitoring | Consistent | Low | Sensitivity and specificity of office-based screening for hypertension was 0.65 and 0.75 (positive predictive value 0.37) compared to ambulatory screening in one study of a referred population A second, school-based study comparing an initial positive screen to subsequent diagnosis of hypertension had similar sensitivity (0.72) and specificity (0.92) but the positive predictive value was lower (0.17)
Key Question 3. What is the association between hypertension in children/adolescents and hypertension and other intermediate outcomes in adults?
10 cohort studies Quality of evidence: Poor | Studies used different thresholds for defining elevated blood pressure and hence hypertension in childhood, and different definitions of hypertension in adulthood; Studies had methodologic shortcomings | Inconsistent | Moderate | Sensitivities and specificities of elevated blood pressure or hypertension from childhood to adult hypertension ranged from 0 to 0.66 and specificities of 0.77 to 1. PPVs ranged from 0.19 to 0.65. Five studies reported significant associations between elevated blood pressure in childhood and hypertension in adults, with ORs ranging from 1.1 to 4.5, and RRs of 1.5 to 9. The two studies which reported associations between childhood hypertension and carotid intima media thickness in young adults provided conflicting findings, while the single study which reported associations between childhood hypertension and microalbuminuria found a significant association only in black individuals
Key Question 4. What are the adverse effects of screening for hypertension in children/adolescents, including labeling and anxiety?
1 study Quality of evidence: Poor | Evidence limited to results from one, good-quality study | Not applicable (one study) | High | Children labeled as hypertensive did not miss more days of school in the year following diagnosis compared to pre-labeling or compared to non-hypertensive children. Other harms associated with screening were not reported
Key Question 5. What is the effectiveness of drug, nondrug, and combination therapies for treating primary hypertension in children/adolescents?
14 RCTs Quality of evidence: Poor | No drug study lasted more than 4 weeks For many studies, the proportion of children with secondary hypertension at baseline was high or unclear | Consistent | Moderate | Children achieving normotensive status (based on varying definitions) ranged from 15% to 86% in patients taking drug treatments and 11% to 48% in patients taking placebo Results showed significant reductions with some doses of some drugs in mean SBP, ranging from 2 to 10 mmHg, and mean DBP, ranging from 0.4 to 8 mmHg from baseline to followup; similarly, SBP reductions were 0 to 9 mmHg and DBP reductions were 0.5 to 10 mmHg between intervention and placebo groups. However reductions were often only at higher doses of active treatments, and studies only lasted for 4 weeks One study of a school-based drug plus lifestyle intervention reported a sustained reduction in blood pressure in the combination group that was significantly better than the control group Studies of non-drug therapies were limited and only one study of additional physical education classes in school compared to no extra classes reported a sustained mean reduction
Key Question 6. What is the effectiveness of drug, nondrug, and combination therapies initiated for the treatment of primary hypertension in children/adolescents for reducing blood pressure and other intermediate outcomes in adults?
No studies | NA | NA | NA | NA
Key Question 7. What is the effectiveness of drug, nondrug, and combination therapies initiated for the treatment of primary hypertension in children/adolescents for reducing adverse health outcomes in adults related to primary hypertension?
No studies | NA | NA | NA | NA
Key Question 8. What are the adverse effects of drug, nondrug, and combination therapies for treating primary hypertension in children/adolescents?
15 studies (13 RCTs, 2 FDA analyses) Quality of evidence: Fair | Numerous trials from Key Question 5 did not report comparative events rates between active treatment and placebo arms, and adverse event rates in general were not well-reported in most studies | Consistent | Moderate | Studies of drug treatments used to treat hypertension in children and adolescents mostly reported no differences between active treatments and placebo in adverse event rates or in withdrawals due to adverse events, except for one study where a combination of bisoprolol and hydrochlorothiazide was associated with lower adverse event rates than placebo Four studies reported serious adverse events, though with the exception of one case of syncope due to a dosing error, serious adverse events were generally not deemed treatment-related. Pooled FDA data found no significant difference between drug treatments and placebo in incidence of specific adverse events, including headache (the most commonly reported adverse event), cardiac events, gastrointestinal events and cough No studies reported on harms associated with non-drug treatments

DBP = diastolic blood pressure; FDA = U.S. Food and Drug Administration; NA = not applicable; OR = odds ratio; PPV = positive predictive value; RCT = randomized controlled trials; RR = relative risk; SBP = systolic blood pressure.

No studies addressed Key Question 1 to determine whether screening for hypertension in children and adolescents was effective at delaying the onset of or reducing the risk of health outcomes related to hypertension in children. In addition, no studies addressed Key Question 6 or 7 to provide evidence on the effectiveness of interventions for treating primary childhood hypertension for reducing blood pressure levels or other intermediate or clinical health outcomes in adulthood.

Only two studies provided evidence on the diagnostic accuracy of blood pressure screening (Key Question 2), with sensitivities of 0.65 and 0.72, specificities of 0.75 and 0.92, and positive predictive values of 0.37 and 0.17. One study involved children referred to a hypertension clinic in Greece and therefore may not be applicable to primary care settings in the United States. The other study involved school-based screening of 10th grade children, and therefore may not be generalizable to clinical settings or other age groups. Twelve additional studies provide data on the positive predictive value of screening for elevated blood pressure, which ranged widely from 4 to 53 percent. Taken together, these findings suggest that the sensitivity of blood pressure measurement to detect hypertension is moderate, and that a significant proportion of children who screen positive are likely to have normal blood pressure (i.e., the majority of children screened positive will be false positives). In addition to false-positive rates, the only evidence that explicitly examined the adverse effects of screening (Key Question 4) was obtained from a small study reporting that rates of school absenteeism did not change after children were identified as having elevated blood pressure. We found no evidence that examined other potential adverse effects of screening for hypertension.

Ten longitudinal studies provided evidence on the association between elevated blood pressure in childhood and hypertension, carotid intima media thickness, or microalbuminuria in adulthood (Key Question 3). All but two of the studies were based on longitudinal data from the United States, although methods to measure blood pressure and definitions of childhood and adult hypertension differed between studies. Although elevated blood pressure in childhood was significantly associated with hypertension in adults in four studies, with ORs ranging from 1.1 to 4.5 and relative risks from 1.5 to 9, the two studies that reported sensitivities and specificities of hypertension in childhood for adult hypertension provided widely differing estimates of 0.0 to 0.66 and 0.77 to 1.0, respectively. Only three studies examined the association between childhood hypertension and other intermediate outcomes related to hypertension in adults. The association of childhood hypertension and carotid intima media thickness was not clear from two studies. A single study found childhood hypertension was significantly associated with microalbuminuria in black adults but not white adults. We found no evidence for associations between hypertension in childhood and other intermediate or final hypertension-related outcomes in adulthood (e.g., left ventricular hypertrophy and other cardiovascular outcomes).

Fourteen studies provided evidence on the effectiveness of interventions to reduce blood pressure in young adolescents (Key Question 5); seven RCTs of monotherapy with drug interventions were small, of very short duration (≤4 weeks), on the lower spectrum of fair-quality, and were mostly limited to those with primary hypertension. All of the drug trials reported reductions in the absolute level of blood pressure and/or increased proportions of children achieving blood pressure <95th percentile for their age, sex, and height. However, the antihypertensive effects were of variable magnitude, were not consistently present for a given agent across both SBP and DBP, and were not always significantly different from placebo or baseline (or this difference was not reported). Moreover, none of the drugs were evaluated in more than one study. The mean age in the majority of the studies was 12 years, so generalizability of results to younger children is unknown. The only trial of combined drug and various lifestyle components that demonstrated evidence of sustained reduction of blood pressure after 6 months was an intensive, school-based intervention. Of six trials that assessed lifestyle interventions, only one, a small Danish school-based trial of increased number of exercise classes, reported a significant decrease in blood pressure after 8 months.

Drugs for treating primary hypertension in children were well-tolerated, with one of 13 studies showing significant differences in rates of adverse events and serious adverse events between active drug and placebo (Key Question 8). Harms studies were limited by quality and generalizability, as most enrolled a mixture of children with primary and secondary hypertension, used open-label periods to examine side effects, and had limited power to identify rare adverse events. We identified no studies reporting on harms associated with lifestyle interventions alone.

## Contextual Questions

### Contextual Question 1 What Are the Main Risk Factors for Primary Hypertension in Children/Adolescents?

According to evidence identified from a large number of epidemiological studies, numerous factors, both modifiable and not modifiable, have been linked with increased risk of primary hypertension in children, including obesity, low birth weight, lack of breastfeeding, sex, ethnicity, and family history of hypertension.4, 10, 11, 14, 80-82 The evidence for the strength and independence of these associations varies markedly.

The association of increased BMI with hypertension has been established in several large epidemiologic studies.11, 40, 80, 83-86 The most robust evidence comes from a large study by Rosner and colleagues who analyzed data from 11 separate studies with a total of 58,698 children and adolescents ages 1 to 17 years, of whom 59 percent were white, 31 percent black, and 11 percent Hispanic.83 The prevalence of systolic hypertension (≥95th percentile) in children who had normal weight (i.e., BMI <85th percentile) was 4.8 to 6.5 percent in boys and 4.8 to 5.3 percent in girls (depending on ethnic group), but in overweight children (BMI ≥85th percentile), hypertension was two to three times more frequent, occurring in 14 to 18 percent of boys and 13 to 16 percent of girls.83 A further study from primary care practices of 18,618 children ages 2 to 19 years, in whom 20 percent were overweight (BMI ≥95th percentile), found higher blood pressure was significantly associated with BMI in all age groups and both sexes, including those in the youngest age group.80 For example, the proportion of boys ages 2 to 5 years with SBP and/or DBP ≥95th percentile was 6 percent in those with BMI <85th percentile and 8 percent in those with BMI >95th percentile. In boys ages 6 to 10 years, corresponding proportions were 5 and 11 percent, 7 and 20 percent in boys ages 11 to 15 years, and 10 and 19 percent in boys ages 16 to 19 years. Sorof and colleagues reported that the prevalence of hypertension in adolescents was strongly and independently associated with increased BMI in 5,102 adolescents (mean age, 14 years); the prevalence of hypertension increased from 2 percent in those with BMI ≤5th percentile to 11 percent in those with BMI ≥95th percentile.11

The Rosner study also provides the most robust evidence on the associations between ethnicity and hypertension, as they were able to adjust for BMI and sex.83 In boys, the prevalence of elevated SBP (≥95th percentile) was not significantly different between black and white boys (OR, 0.96 [95% CI, 0.87 to 1.05]; p=0.39). In comparison, Hispanic boys had significantly higher SBP than white boys (OR, 1.49 [95% CI, 1.31 to 1.68]; p<0.001). For girls, both blacks and Hispanics had significantly higher rates of SBP than white girls (OR, 1.16 [95% CI, 1.06 to 1.28]; p=0.001 and OR, 1.24 [95% CI, 1.08 to 1.43]; p=0.003, respectively). After adjusting for BMI, Hispanic boys continued to have significantly higher rates of SBP (OR, 1.29 [95% CI, 1.14 to 1.47]; p<0.001), whereas there remained no significant difference between black and white boys. After adjusting for BMI in girls, neither black nor Hispanic children had significantly different rates of SBP elevation. In boys, the prevalence of elevated DBP (≥95th percentile) was significantly greater in black boys (OR, 1.16 [95% CI, 1.04 to 1.30]; p=0.008) and Hispanic boys (OR, 1.32 [95% CI, 1.12 to 1.55]; p<0.001) than white boys, and both remained significant after adjusting for BMI (OR, 1.13 [95% CI, 1.01 to 1.26] and OR, 1.19 [95% CI, 1.01 to 1.40], respectively; p=0.04 for both comparisons). The crude rates of DBP were also significantly higher in black girls than white girls (OR, 1.15 [95% CI, 1.04 to 1.28]; p=0.008), but there was no significant difference between Hispanic girls and white girls (OR, 1.05 [95% CI, 0.88 to 1.24]; p=0.59), and adjusting for BMI did not alter these associations.

It is unclear whether having one or both parents with hypertension increases the risk of hypertension in childhood or adolescence. Some small, cross-sectional studies have noted this association,87-90 while others have not.91, 92 Based on current evidence, an association, if present, would be small. The largest study we identified (N=864) was a community-based study of young people ages 16 to 24 years who were screened for blood pressure some 8 years after their parents had been screened for blood pressure. A total of 29 percent of adolescents who had at least one parent with blood pressure in the top 10 percent of the distribution had a blood pressure score in the top 20 percent of distribution, resulting in a sensitivity of 0.27 and specificity of 0.84 for predicting elevated blood pressure.93 The implications of this study are limited because NHBPEP definitions of hypertension were not used.

Breastfeeding has been shown to be protective against elevated blood pressure in several studies. A prospective cohort study of 7,276 children examined the association between type of infant feeding and blood pressure at age 7 years.94 Breastfeeding was associated with lower SBP (0.8 mm Hg [95% CI, 0.1 to 1.5]) and DBP (0.6 mm Hg [95% CI, 0.1 to 1.0]) after adjusting for multiple confounders. An association was also noted between breastfeeding in premature, low birth weight infants (<1850 g) and lower blood pressure when measured in adolescence. A similar association was reported in a another study of 301 children, in whom SBP at age 7 years was significantly higher in children who were exclusively bottle fed compared with those who received breast milk (mean, 94.2 mm Hg [range, 93.5 to 94.9] vs. 90.7 mm Hg [range, 89.9 to 91.7], respectively).95

### Contextual Question 2 What is the Prevalence of Secondary Hypertension in Asymptomatic Children/Adolescents in Primary Care Settings?

Evidence on the prevalence of secondary hypertension is dependent on the populations of children studied, and there appears to be no accurate prevalence rates for asymptomatic children in ambulatory settings. Most evidence comes from children referred to pediatric specialty clinics following the detection of hypertension by screening or incidentally, or in children diagnosed with other conditions (e.g., renal abnormalities) in whom hypertension had also been noted. Among these populations, the prevalence of secondary hypertension varies inversely with age.13, 17 In grade school-aged children (i.e., up to age 12 years), secondary hypertension accounts for 70 to 85 percent of cases.12, 13, 17 In children younger than age 12 years, up to 85 percent diagnosed with secondary hypertension have underlying renal disease, most commonly one of the renal parenchymal diseases (e.g., glomerulonephritis, renal scarring due to reflux nephropathy, polycystic kidney disease, and chronic renal failure) or renovascular diseases (e.g., fibromuscular dysplasia.).13, 17 Less common causes of secondary hypertension in children include aortic coarctation and endocrine disorders (e.g., phaeochromocytoma, hyperthyroidism) or relation to medications (e.g., oral contraceptives in adolescents, sympathomimetic drugs, dietary supplements).13, 17 By the time a child reaches adolescence, hypertension is predominantly primary (85% to 95% of cases); the prevalence of secondary hypertension in adolescents is about 5 percent.13, 96

### Contextual Question 3 What Are the Optimal Ages at Which to Initiate Screening and the Optimal Time Intervals at Which to Repeat Screening Children/Adolescents for Hypertension?

We identified no evidence on the optimal ages at which to initiate screening for hypertension or on ideal screening intervals. The American Academy of Family Physicians and other organizations recommend beginning routine screening at age 3 years,6, 7 but this recommendation is not based on empirical evidence.

## Limitations of the Review

We excluded nonEnglish-language articles, which could result in language bias. We did not search for studies published only as abstracts and could not formally assess for presence of publication bias with graphical or statistical methods because of small numbers of studies for each key question and differences in study design, populations, and outcomes assessed. We included observational studies for some key questions where trials were not available, which are more susceptible to bias and confounding than well-conducted randomized trials. When evidence from settings more applicable to practice in the United States was sparse or unavailable, we included studies conducted in other countries, which could limit applicability. We included some studies that enrolled a small-to-moderate proportion of individuals with secondary hypertension, as many studies did not clearly report the populations with primary and secondary hypertension.

## Emerging Issues/Next Steps

In adults, there is growing evidence for ambulatory blood pressure measurement and self-measured blood pressure (otherwise known as home monitoring) in diagnosis and monitoring in ambulatory and community settings. In adults, the importance of home monitoring is increasing, and these devices are now recommended in some settings for diagnosis of hypertension and monitoring of response to intervention. Advances in technology and electronic transmission of data also offer the potential to transmit blood pressure readings between patients' homes and clinicians' offices.

The evidence for the role of these devices in children is at an early stage. Approximately two thirds of pediatric nephrologists report that they use ambulatory blood pressure measurement in management of children with hypertension,97 and one study found that valid readings of ambulatory blood pressure measurement can be obtained in the majority (84%) of children ages 3 to 18 years.98 However, the current use and feasibility of ambulatory blood pressure measurement in pediatric practice in ambulatory settings is not known.

Ambulatory blood pressure measurement and home monitoring offer several potential advantages over clinic measures, such as the opportunity to gather a larger number of readings, and provide readings that are more representative of a child's blood pressure, at multiple points during the day and night and over multiple days. These readings may facilitate identifying children with patterns of blood pressure that may have diagnostic or prognostic significance, which cannot easily be identified with clinic-only measurements.99-102

White coat hypertension occurs when blood pressure readings obtained in a clinic setting are elevated, but readings obtained out of the clinic are normal. This has been reported to occur in between 1 and 62 percent of children. However, there is some evidence in adults to suggest that white coat hypertension may not be a benign condition, but may reflect underlying increased activity of the sympathetic nervous system and greater risk of cardiovascular outcomes than in those with normal blood pressure.103 In children, there are no data on long-term outcomes, and the association between ambulatory blood pressure measurement and intermediate outcomes, such as carotid intima media thickness and left ventricular hypertrophy, is uncertain at this time.101

A second condition that has been identified using multiple blood pressure readings is masked hypertension (also known as reverse white coat hypertension, or white coat normotension), which occurs when clinic blood pressure is normal, but blood pressure measured using ambulatory blood pressure measurement or home devices is elevated. The prevalence in children is estimated at 7 to 10 percent.102, 104 In adults, there is some evidence to suggest that masked hypertension is associated with elevated risk for cardiovascular outcomes,105 while in children, small studies suggest a possible association with intermediate outcomes, such as left ventricular hypertrophy, but there is no evidence on long-term outcomes.102, 104

The use of ambulatory blood pressure measurement or home monitoring could also potentially be useful for monitoring children with confirmed hypertension, including more accurate and more rapid titration of antihypertensive intervention and determining whether side effects of interventions are associated with levels of blood pressure.101 Its role in children is unknown, however, and there are currently several problems with obtaining and interpreting measurements from these devices. Few ambulatory blood pressure measurement and home devices have been validated for use in children, raising concerns regarding accuracy,101, 106 particularly at the lower levels of SBP and DBP.106 In addition, the measurements and pattern of readings from ambulatory blood pressure measurement and home devices need to be interpreted and compared with normative data. Unlike adults, in whom normative data for ambulatory blood pressure measurement have been correlated with end-organ damage and cardiovascular outcomes, the normative data on ambulatory blood pressure measurement in children are limited, may not be representative of current ambulatory blood pressure measurement devices, and are not from children in the United States.32, 106, 107 In addition, blood pressure norms may be changing due to the increasing prevalence of overweight and obesity in children and adolescents.

## Future Research

We suggest that large observational studies include blood pressure measures and other cardiovascular risk factors obtained in children and adolescents, and have followup periods of many decades, given the time needed to develop clinical sequelae of hypertension, such as cardiovascular disease.

Further evidence is needed on the effectiveness and comparative effectiveness of drug and lifestyle interventions to reduce blood pressure in children with primary hypertension. There is a major gap on the effectiveness of all currently available medications approved by the FDA for hypertension in children, including older medications. Given that most children with primary hypertension will potentially require blood pressure lowering intervention for decades, such studies should include longer followup periods to determine effectiveness in these populations, including those followed in primary care rather than specialty settings, and include drug monotherapy and combinations of antihypertensive drugs (such as stepped care regimens), including measures of long-term compliance. Improving the evidence for the safety of antihypertensive medications also requires further studies of all FDA-approved medications. Our finding of mixed outcomes of lifestyle interventions suggests the need for further studies, particularly in U.S. settings. Some of the lifestyle interventions included numerous components, so study designs that take account of such complex interventions and identify the components that provide the greatest relative benefit are needed. Given the link between BMI and hypertension, the rising levels of overweight and obese children suggest this is an urgent priority.

A further major gap in the evidence is the effectiveness of interventions for primary childhood hypertension for reducing the level and or proportion of blood pressure or other intermediate outcomes in adulthood, or for subsequent reduction of adverse health outcomes in adults.

Determining the effects of interventions to reduce blood pressure on adverse health outcomes (e.g., cardiovascular outcomes) would require extended followup periods and, again, would be logistically challenging. However, it would be possible to assess the effects of interventions on blood pressure in young adults and on intermediate outcomes, such as structural changes in the heart or vasculature.

The lack of data on diagnostic accuracy of blood pressure devices represents a major gap in the current evidence base. First, studies of the diagnostic accuracy of blood pressure screening in primary care or community settings (e.g., schools) of nonreferred populations, with wide age ranges and varying characteristics are needed, that follow both children who screen positive and those who screen negative in order to calculate all measures of diagnostic accuracy. In addition, evidence is needed on the number and frequency of readings needed to make a diagnosis, and the comparative effectiveness of different types of devices to measure blood pressure, including newer devices that obtain multiple readings in one visit, home-based devices, and ambulatory blood pressure measurement. As noted above, ambulatory blood pressure measurement offers several potential advantages over clinic-based devices, but evidence of its value and comparative effectiveness over other screening devices is lacking. Given the importance of identifying children with secondary hypertension during screening, the use of blood pressure screening devices that distinguish primary and secondary hypertension based on level or pattern of blood pressure are needed. Such studies should also assess the adverse effects of screening, including the immediate effects—such as parent/clinic time and discomfort for the child—as well as adverse effects of children with false-positive screening results, such as labeling, effects on school or sports participation, and need for followup due to a positive screening result.

Finally, the centiles used to define hypertension in children and adolescents are based on normative values, unlike in adults, where they are based on cardiovascular risk. We identified some evidence that elevated blood pressure levels in childhood are associated with increased risk of hypertension in adults, but evidence for its association with other markers of hypertension-related end-organ damage were very limited. Adequately-sized cohort studies with long followup periods might allow refinement of these centiles to define thresholds of blood pressure in children that are associated with different levels of risk for adverse health outcomes, permitting more accurate risk assessment.

## Conclusions

There is no direct evidence that screening for hypertension in children and adolescents reduces adverse health outcomes or delays the onset of hypertension. Blood pressure screening may be effective at identifying children with hypertension, though evidence is limited and false-positive rates were high. The presence of hypertension in childhood is associated with hypertension in adults, but with limited evidence for its association with end-organ damage markers in adults. Drug interventions for hypertension may be effective at lowering blood pressure with few serious side effects; however, studies of longer duration are needed to confirm results from short-term studies. Evidence on the effectiveness of combination drug and lifestyle interventions and lifestyle-only interventions is mixed, with most studies showing no sustained reduction in blood pressure. There is no evidence on whether treating hypertension in childhood affects subsequent intermediate or clinical outcomes in adulthood.