# RESULTS

## Key Question 1 Is Screening for Hypertension in Children/Adolescents Effective in Delaying the Onset of or Reducing Adverse Health Outcomes Related to Hypertension?

We identified no studies that examined the direct effect of screening for hypertension in children or adolescents in delaying the onset of or reducing adverse health outcomes related to hypertension.

## Key Question 2 What Is the Diagnostic Accuracy of Screening Tests for Elevated Blood Pressure in Children/Adolescents?

### Summary

Two studies provided evidence on the sensitivity and specificity of screening tests for elevated blood pressure. The studies employed different reference standards, but reported similar sensitivities (0.65 and 0.72) and specificities (0.75 and 0.92). Positive predictive values for both studies were low (0.37 and 0.17). Twelve other studies that did not meet inclusion criteria due to the inability to construct 2 × 2 tables and/or failure to apply a reference standard reported a wide range of positive predictive values (0.04 to 0.53).

### Evidence

We identified one fair-quality study that provided evidence on the diagnostic accuracy of clinic blood pressure measurements compared with ambulatory monitoring (Table 2, Appendixes B1 and B2).31 One hundred and five Greek children and adolescents (mean age, 13 years) who were referred to a specialty hypertension clinic were enrolled in a prospective study that compared the diagnostic accuracy of office, home, and ambulatory blood pressure measurement. For the purposes of this review, only office-based blood pressure was included as the index test, as home blood pressure monitoring is outside the scope of this report. Office blood pressure was measured three times at each of two clinic visits, and hypertension was diagnosed in those children with readings above the 95th percentile, according to published NHBPEP normative values.6 This was compared with a reference standard of 24-hour ambulatory monitoring at 20-minute intervals. Hypertension was again diagnosed in children with readings above the 95th percentile as a result of ambulatory blood pressure measurement, although authors used different normative values for ambulatory blood pressure measurement than the NHBPEP standards.32 Compared with ambulatory measurement, office-based blood pressure measurement had a sensitivity of 0.65 (95% CI, 0.45 to 0.80) and a specificity of 0.75 (95% CI, 0.63 to 0.84). The corresponding positive predictive value was 0.37 (95% CI, 0.28 to 0.47) and the negative predictive value was 0.63 (95% CI, 0.53 to 0.72). This study has some important limitations. All of the participants were referred for evaluation at a specialty clinic, and thus may not be representative of a true screened population of asymptomatic children. In addition, the use of different normative values according to testing method is a potential source of bias.

Table 2 Diagnostic Accuracy of Screening for Elevated Blood Pressure in Children and Adolescents

Study, Year | Screening test | Reference standard | Definition of a positive screening exam | Population | Sensitivity (95% CI) | Specificity (95% CI) | Positive predictive value (95% CI) | Negative predictive value (95% CI) | Quality rating
Fixler and Laird, 1983^33^ | Three measures with mercury manometer measured at least 4 weeks apart | Initial screening results compared to subsequent measures | Systolic or diastolic blood pressure ≥95th percentile based on normative levels for the study population | n=9,017; 8th graders with followup at 10th grade Mean age not reported; all were in 8th grade at time of initial screening 53% male 44% Black 42% White 14% Hispanic | Initial positive screen vs. subsequent screens: 0.72 (0.65 to 0.78) | Initial positive screen vs. subsequent screens: 0.92 (0.91 to 0.92) | Initial positive screen vs. subsequent screens: 0.17 (0.15 to 0.2) | Initial positive screen vs. subsequent screens: 0.993 (0.991 to 0.994) | Fair
Stergiou et al, 2008^31^ | Three averaged measurements with mercury sphygmomanometer, measured in nondominant arm in sitting position after 5 minutes at rest | 24-hour ambulatory measurements | Systolic or diastolic blood pressure ≥95th percentile based on U.S. normative blood pressure tables | n=102; 100% referred for screening Mean age 13 years (SD 3; range 6-18) 63% male Race not reported | Positive ambulatory result vs. positive clinic result: 0.65 (0.45 to 0.80) | Positive ambulatory result vs. positive clinic result: 0.75 (0.63 to 0.84) | Positive ambulatory result vs. positive clinic result: 0.37 (0.28 to 0.47) | Positive ambulatory result vs. positive clinic result: 0.63 (0.53 to 0.72) | Fair

CI = confidence interval; SD = standard deviation; U.S. = United States.

A second, fair-quality study selected a random sample of 10 percent of children whose initial (i.e., screening) blood pressure test was negative and who went on to have further blood pressure tests to assess if they were true negatives or false negatives (Table 2, Appendixes B1 and B2).33 Among tenth grade students (n = 9,017), the sensitivity and specificity of initial elevated blood pressure for persistent elevation of blood pressure were 0.72 (95% CI, 0.65 to 0.78) and 0.92 (95% CI, 0.91 to 0.92) respectively, but positive predictive value was limited at 0.17 (95% CI, 0.15 to 0.20). The school-based setting for this study may be useful for screening interventions, but the authors' use of a sample of children screening negative rather than the entire population of children screening negative to create the 2 × 2 tables may have caused bias in the diagnostic accuracy values derived from this study.

We identified 12 additional studies that compared one or more index measurements of blood pressure with subsequent reference measurements but failed to apply the reference tests to participants who initially screened negative (Appendix B3).34-45 These studies also did not meet our inclusion criteria for this key question, as they did not provide enough data to recreate 2 × 2 tables (or calculate sensitivity and specificity). Most studies were of school-based screening and were highly variable in defining a positive screening test. For example, some used a conventional cut-off point of greater than the 90th or 95th percentile based on NHBEP centiles to define hypertension, but others used cohort-specific data to define their own normative values.35, 36 Others used a lower threshold to define a positive screen (e.g., blood pressure greater than the 70th percentile44) or used absolute SBP and DBP values rather than percentiles to define a positive screening test.38, 39, 42, 43 Positive predictive values among the studies ranged from 0.04 to 0.53. The reason for this heterogeneity is unclear and did not appear to be related to the populations, prevalence of hypertension, method of testing, or thresholds used to define positive tests. Considered as a whole, only approximately one quarter (median positive predictive value, 0.26) of children and adolescents who initially screened positive were subsequently diagnosed with hypertension.

## Key Question 3 What Is the Association Between Hypertension in Children/Adolescents and Hypertension and Other Intermediate Outcomes in Adults?

### Summary

Longitudinal studies provided some evidence on the association between elevated blood pressure or hypertension in childhood and adulthood (seven studies), carotid intima media thickness (two studies), and microalbuminuria (one study). The studies used different thresholds for defining elevated blood pressure and hence hypertension in childhood, and different definitions of hypertension in adults. The sensitivities and specificities of elevated blood pressure or hypertension from childhood to adult hypertension ranged from 0 to 0.66 and 0.77 to 1, respectively. Positive predictive values (i.e., the probability of adult hypertension given the presence of hypertension in childhood) ranged from 0.19 to 0.65. Four studies reported significant associations between elevated blood pressure in childhood and hypertension in adults, with odds ratios (ORs) ranging from 1.1 to 4.5 and relative risks from 1.5 to 9. The two studies that reported associations between childhood hypertension and carotid intima media thickness in adulthood provided conflicting findings. One found a very weak but not independently significant association, whereas the other found no significant association in 12- to 17-year-olds. Childhood hypertension was significantly associated with microalbuminuria in black adults but not white adults in a single study. We found no evidence for associations between hypertension in childhood and other intermediate or final hypertension-related outcomes in adulthood (e.g., left ventricular hypertrophy and other cardiovascular outcomes).

### Evidence

We identified 10 studies that reported on the presence of hypertension (or elevated blood pressure) in children and the presence of hypertension or other intermediate outcomes in adulthood (Table 3, Appendix B4).24, 46-54 We did not formally quality-rate these studies, though characteristics related to study quality are included in Table 3. Many of the studies had methodological shortcomings, making interpretation and direct comparisons of results difficult. In some studies, it was unclear if blood pressure thresholds in childhood were cohort-specific or based on standardized values.24, 46, 49, 51, 52, 54 The definition of hypertension in childhood varied among the studies, with threshold values ranging from >80th percentile to >95th percentile, while three of the studies did not provide a definition of childhood hypertension.47, 52, 54 The studies drew data from five cohorts: the Bogalusa Heart Study,46, 49, 52, 54 the Muscatine Study,51 the Fels Longitudinal Study,24, 47 the Young Finns Study,50, 53 and a cohort of children in Boston.48 The studies reported either the association or diagnostic value of elevated childhood blood pressure in predicting hypertension,24, 46-48, 50, 51, 54 carotid intima media thickness,52, 53 or microalbuminuria49 in adults.

Table 3 Studies Tracking Hypertension and Other Outcomes From Childhood to Adulthood

Author, year Study name Followup | Definition of HTN in childhood | Definition of HTN in adulthood | Outcomes | Quality considerations
Author, year Study name Followup | Definition of HTN in childhood | Definition of HTN in adulthood | Outcomes | Enrollment | Attrition: % with complete data, % of original N at followup | Measurement method stated for both time periods? | Statistical analysis and adjusted variables
Blood Pressure Outcomes
Bao et al, 1995^46^ Bogalusa Heart Study 15 years | >80th percentile | SBP >140 mmHg or DBP >90 mmHg or ever treated for hypertension | Hypertension at followup, baseline highest SBP quintile vs. other SBP quintiles: 18% (54/301) vs. 5% (60/1204); Risk ratio 3.6; 95% CI 2.5 to 5.1 Hypertension at followup, baseline highest DBP quintile vs. other DBP quintiles: 15% (45/301) vs. 6% (72/1204); Risk ratio 2.5; 95% CI 1.8 to 3.6 | Unclear; data from 1,505 subjects who completed baseline and followup surveys (of 3,865 at baseline) | No loss (cohort selected based on availability of data; 39% of original cohort completed both surveys) | Yes | Logistic regression Age, race, sex, SBP, DBP, BMI, change in BMI
Beckett et al, 1992^47^ Fels Longitudinal Study 20 years | SBP not defined DBP >80 mmHg described as >90th percentile | DBP >90 mmHg | DBP 80 mmHg vs. 60 mmHg at age 15 and presence of hypertension at age 35: Males: Risk ratio 3.0; Females: Risk ratio 4.5 DBP 85 mmHg vs. 60 mmHg at age 15 and presence of hypertension at age 35: Males: Risk ratio 3.9; Females: Risk ratio 6.6 DBP 90 mmHg vs. 60 mmHg at age 15 and presence of hypertension at age 35: Males: Risk ratio 4.9; Females: Risk ratio 9.0 | Unclear; data from 523 subjects who completed baseline and followup surveys (of 976 at baseline) | No loss (cohort selected based on availability of data; 54% of original cohort completed both surveys) | No | N/A
Gillman et al, 1993^48^ Study not named 12 years | >90th percentile (SBP: 113 mmHg, within study) | >90th percentile (SBP: 139 mmHg, within study) | Positive predictive value, sensitivity, and specificity of BP at age 10 predicting BP>90th percentile at age 20: SBP, males: >75th percentile (108 mmHg): 0.26, 0.59, 0.80 >90th percentile (113 mmHg): 0.35, 0.33, 0.93 >95th percentile (117 mmHg): 0.44, 0.17, 0.97 >99th percentile (123 mmHg): 0.58, 0.04, >0.99 SBP, females: >75th percentile (108 mmHg): 0.27, 0.66, 0.79 >90th percentile (114 mmHg): 0.39, 0.36, 0.94 >95th percentile (118 mmHg): 0.48, 0.20, 0.98 >99th percentile (125 mmHg): 0.65, 0.04, >0.99 DBP, males: >75th percentile (68 mmHg): 0.21, 0.34, 0.82 >90th percentile (71 mmHg): 0.24, 0.16, 0.93 >95th percentile (73 mmHg): 0.27, 0.08, 0.97 >99th percentile (77 mmHg): 0.34, 0.01, >0.99 DBP, females: >75th percentile (67 mmHg): 0.19, 0.49, 0.77 >90th percentile (71 mmHg): 0.24, 0.23, 0.92 >95th percentile (74 mmHg): 0.30, 0.10, 0.98 >99th percentile (78 mmHg): 0.38, 0.02, >0.99 | Children from a single school in East Boston, Massachusetts; sampling method unclear | 6% (20/337) attrition | Yes | N/A
Juhola et al, 2011^50^ Cardio-vascular Risk in Young Finns Study 27 years Other publication: Juonala et al, 2004^55^ | ≥95th percentile | Unclear | Prehypertension or hypertension in adulthood and BP ≥95th percentile in childhood: Female, ages 6 and 9: OR 2.4 (95% CI 1.1-5.2) Female, ages 12, 15, and 18: OR 2.3 (95% CI 1.6-3.5) Males, ages 6 and 9: OR 2.8 (95% CI 1.5-5.1) Males, ages 12, 15, and 18: OR 2.1 (955 CI 1.5-3.1) PPV, sensitivity, specificity of BP >95% percentile in childhood and hypertension in adulthood – All ages 6-18: 0.44; 0.1; 0.97 | Finnish children and adolescents aged 3, 6, 9, 12, and 15 randomly sampled from 5 cities | 38.7% (1,392/3596) lost to followup by 27 years | Yes | Linear regression Age, sex, race, study year
Lauer et al, 1993^51^ Muscatine Study Duration of followup unclear | Unclear; results reported for >90th percentile | SBP or DBP >90th percentile (cohort specific) | 24% of children with BP >90th percentile had BP >90th percentile in adulthood; risk ratio 2.4 (p<0.001) 39% of children with SBP >90th percentile had SBP >80th percentile in adulthood; risk ratio 1.9 (p<0.001) 17% of children with DBP >90th percentile had DBP >90th percentile in adulthood; risk ratio 1.7 (p<0.001) 32% of children with DBP >90th percentile had DBP >80th percentile in adulthood; risk ratio 1.5 (p<0.001) | Unclear; data from 2,445 subjects who completed baseline and followup surveys (number at baseline NR) | No loss (cohort selected based on availability of data) | Yes | N/A
Shear et al, 1987^54^ Bogalusa Heart Study 8 years | Not reported | ≥140/90 mmHg | SBP ≥80th percentile at years 1,4 and 6 and hypertensive at followup: Sensitivity: 0.27; Specificity: 0.95 DBP ≥80th percentile at years 1,4 and 6 and hypertensive at followup: Sensitivity: 0.33; Specificity: 0.96 SBP ≥90th percentile at years 1,4 and 6 and hypertensive at followup: Sensitivity: 0.13; Specificity: 0.99 DBP ≥90th percentile at years 1,4 and 6 and hypertensive at followup: Sensitivity: 0.07; Specificity: 0.99 SBP ≥95th percentile at years 1,4 and 6 and hypertensive at followup: Sensitivity: 0.07; Specificity: 1.0 DBP ≥95th percentile at years 1,4 and 6 and hypertensive at followup: Sensitivity: 0.0; Specificity: 1.0 | Data from 1,501 subjects who completed baseline and followup surveys (of 4,238 subjects at baseline) | No loss (cohort selected based on availability of data; 35% of original subjects completed both surveys) | Yes | N/A
Sun et al, 2007^24^ Fels Longitudinal Study Duration of followup unclear | Least-squares means determined according to age and sex (absolute values not reported) | SBP >130 mmHg and/or DBP >85 mmHg | Odds of hypertension at >30 years of age given SBP exceeding criterion values at single examination in childhood: 5-7 year old males: 3.8 (95% CI 1.5-9.7) 5-7 year old females: 4.5 (95% CI 1.1-17.7) 8-13 year old males: 3.5 (95% CI 1.5-8.3) 8-13 year old females: 2.7 (95% CI 1.0-7.1) 14-18 year old males: 1.1 (95% CI 0.5-2.4) 14-18 year old females:3.8 (95% CI 1.2-12.7) | Unclear; data from 493 subjects who completed baseline and followup surveys (of 976 at baseline) | 8% loss to follow-up in Fels Longitudinal Study overall; data from 51% of original subjects | Yes | N/A
Other Outcomes
Hoq et al, 2002^49^ Bogalusa Heart Study 16 years | ≥90th percentile for age, ethnicity and sex | ≥90th percentile for age, ethnicity and sex | Microalbuminuria: Childhood SBP - Blacks: regression coefficient 0.016 (p=0.05); Whites: regression coefficient -0.002 (p=0.78) Annual change in SBP from childhood to adulthood - Blacks: regression coefficient 0.315 (p=0.002); Whites: regression coefficient -0.045 (p=0.55) Childhood DBP- Blacks: regression coefficient 0.026 (p=0.012); Whites: regression coefficient -0.002 (p=0.761) Annual change in DBP from childhood to adulthood - Blacks: regression coefficient 0.292 (p=0.016); Whites: regression coefficient 0.063 (p=0.5) | Unclear; data from 2,122 subjects who completed baseline and followup surveys (of 3,865 at baseline) | Cohort selected based on availability of data; data from 55% of original subjects | Yes | Logistic regression Sex, childhood age, BMI, BP, annual change in BP
Li et al, 2003^52^ Bogalusa Heart Study 22 years | Not reported | Not reported | Odds of carotid intima media thickness in upper quartile given SBP risk factor (not defined): Childhood (4-17 years): 1.00 (95% CI 0.80-1.25) | Unclear; data from 486 subjects who completed baseline and followup surveys and carotid artery ultrasound (of 3,865 at baseline) | NR (94% [486/516] had data available); data from 13% of original subjects) | Yes | Logistic regression Age, race, sex
Raitakari et al, 2003^53^ Cardiovascular Risk in Young Finns Study 21 years | ≥80th percentile | ≥80th percentile | Relationship between SBP >80th percentile at age 12-18 (mean age 14.9 years) and carotid intima media thickness 21 years later: regression coefficient 0.013 (SE 0.003); p<0.001 | Finnish children and adolescents aged 3, 6, 9, 12, and 15 randomly sampled from 5 cities | 38% (1,367/3596) lost to follow-up by 21 years | Yes | Logistic regression Age, sex

BMI = body mass index; BP = blood pressure; CI = confidence interval; DBP = diastolic blood pressure; NA = not applicable; NR = not reported; OR = odds ratio; PPV = positive predictive value; SBP = systolic blood pressure; SE = standard error.

Elevated blood pressure or hypertension. The most direct evidence on presence of hypertension in childhood and incidence of hypertension in adulthood comes from analysis of data from the Cardiovascular Risk in Young Finns Study.50 This well-conducted, longitudinal study enrolled 3,596 children in Finland ages 3 to 18 years and provided followup for 2,204 participants at 30 to 45 years. Prehypertension or hypertension—defined according to NHBPEP charts—at ages 3 to 9 years was significantly predictive of hypertension in adulthood in both men (OR, 2.8 [95% CI, 1.5 to 5.1]) and women (OR, 2.4 [95% CI, 1.1 to 5.2]). Results were similar for measures in older children and adolescents (ages 12 to 18 years). A second, smaller (n=493) analysis of data from the Fels Longitudinal Study used age- and sex-based least squares means (rather than standardized charts) to retrospectively determine the presence of hypertension in childhood and its association with hypertension in adulthood.24 Results from this study were consistent with the Finnish study, finding that children with blood pressure readings that exceeded study-determined thresholds were significantly more likely to be hypertensive in adulthood. ORs ranged from 3.5 to 3.8 for boys ages 5 to 13 years and from 2.7 to 4.5 for girls ages 5 to 18 years. The exception is for boys ages 14 to 18 years, in whom high blood pressure was not significantly predictive of hypertension in adulthood (OR, 1.1 [95% CI, 0.5 to 2.4]).24

Studies used a variety of thresholds to differentiate between normal and elevated blood pressure in childhood and the accuracy of these measures in predicting high blood pressure or hypertension in adulthood. One study of 317 children with blood pressure measures at age 10 years and followup at age 20 years found blood pressure cut-offs between >75th percentile and >99th percentile in childhood provided moderate sensitivity (up to 0.66) and high specificity (up to >0.99), as well as moderate positive predictive value (up to 0.65) for predicting blood pressure >90th percentile in adulthood.48 Overall, positive predictive values for blood pressure >90th percentile in adulthood ranged from 0.21 (in men) and 0.19 (in women) to 0.58 and 0.65, depending on the cut-off used in childhood in this study. In comparison, a study of data from the Bogalusa Heart Study (a longitudinal study of Louisiana school children)46 used a cohort-specific cut-off of >80th percentile to define childhood hypertension. An earlier analysis of Bogalusa Heart Study data found that using a blood pressure cut-off of >80th percentile in children provided the best balance of sensitivity and specificity for predicting hypertension in adulthood compared with higher thresholds, though sensitivity was low (range, 0.0 to 0.33 for SBP and DBP) regardless of cut-off.54

Three studies reported the incidence of elevated blood pressure in childhood and subsequent risk of hypertension in adulthood.46, 47, 51 An analysis of Bogalusa Heart Study data found that after 15 years of followup, children (age range, 5 to 14 years; mean age not reported) in the highest quintile of SBP and DBP at baseline were about three times more likely to be hypertensive as adults when compared with children in the lower three quintiles (risk ratio, 3.6 [95% CI, 2.5 to 5.1] and 2.5 [95% CI, 1.8 to 3.6], respectively).46 Results from two other studies were consistent, finding that higher SBP or DBP in childhood increased risk of hypertension in adulthood, though one study compared a higher with lower DBP at baseline and incidence of hypertension in adulthood,47 and the other reported absolute rates of elevated blood pressure in adulthood among children with blood pressure readings above the cohort-specific 90th percentile.51

Other intermediate outcomes. Two studies reported on incidence of carotid intima media thickness in adulthood and its relationship to blood pressure in childhood.52, 53 One study (n=3,596) found that SBP >80th percentile in adolescence was very mildly associated with presence of carotid intima media thickness in adulthood (regression coefficient, 0.013; p<0.001), though its clinical significance is unclear.53 The second study (n=486) found no association between an undefined childhood SBP risk and incidence of carotid intima media thickness in adulthood (highest quintile vs. lower three quintiles: OR, 1 [95% CI, 0.8 to 1.25]).52

A third study of 2,122 children from the Bogalusa Heart Study examined the association of childhood blood pressure (mean age, 10 years) with microalbuminuria in adulthood (mean age, 26 years).49 In black participants, regression modeling found that SBP, DBP, and the annual change in SBP and DBP from childhood to adulthood were independent predictors of development of microalbuminuria. However, neither SBP, DBP, nor annual changes in these measures were significantly associated with microalbuminuria in white participants.

We identified no studies analyzing associations between elevated blood pressure or hypertension in childhood and other intermediate outcomes in adulthood (e.g., left ventricular hypertrophy and other cardiovascular outcomes).

## Key Question 4 What Are the Adverse Effects of Screening for Hypertension in Children/Adolescents, Including Labeling and Anxiety?

We identified one good-quality study meeting inclusion criteria for Key Question 4.^56^ In this comparative, prospective study in Ontario, Canada, 85 children ages 10 to 18 years with SBP at or above the 85th percentile for their age and sex were enrolled. These children were identified as having elevated blood pressure after repeat screening of a population-based cohort. Eighty-five age- and sex-matched children from the same community were identified as controls. Rates of school absenteeism did not change significantly in the year after the children were identified as having elevated blood pressure compared with preidentification rates and also when compared with the control group (both total and illness days increased in both groups; p>0.05 for between-group differences). Personality testing (assertiveness and type A characteristics) of a subset of the study subject pairs did not predict change in absenteeism. No other measures of adverse effects associated with screening were reported in this study.

## Key Question 5 What Is the Effectiveness of Drug, Nondrug, and Combination Interventions for Treating Primary Hypertension in Children/Adolescents?

### Summary

Fourteen randomized, controlled trials (RCTs) of interventions for hypertension in children and adolescents met inclusion criteria, including seven drug trials, one trial of a drug combined with a lifestyle intervention, and six trials of lifestyle interventions. All of the drug trials, none of which examined the same drugs, reported short-term reductions in the absolute level of blood pressure and/or increased proportions of children achieving blood pressure <95th percentile for their age, sex, and height. The antihypertensive effects were of variable magnitude and not consistently present for a given agent, varied for SBP and DBP, and were not always significantly different from placebo (or this difference was not reported). None of the drug trials were longer than 4 weeks in duration. The one trial of a drug combined with a lifestyle modification in a school setting showed long-term effectiveness, but was an intensive intervention. Lifestyle modification was largely ineffective among the trials, although one school-based trial of increased number of physical education classes demonstrated statistically significant reductions in blood pressure when compared with untreated controls. A full review of the effectiveness of treatment for the individual causes of secondary hypertension is beyond the scope of this review; therefore, this key question focuses on the treatment of primary hypertension.

### Evidence

Fourteen RCTs (in 15 publications) of treatment for hypertension in children and adolescents met inclusion criteria (Appendix B5),35, 57-70 including seven drug trials (Table 4), one trial of a drug combined with a lifestyle intervention (two publications; Table 5), and six trials of lifestyle interventions (Table 6). We did not identify any observational studies that met our inclusion criteria. All trials were rated fair-quality; however, the majority of the studies were on the lower end of the continuum of fair-quality studies, mainly due to inadequate reporting of randomization, concealment of treatment allocation, and lack of information about blinding of outcome assessors and/or care providers (Appendix B6). None of the trials had a fatal flaw that would downgrade them to poor quality. The proportion of children with primary hypertension reported in the included studies ranged from 31^61^ to 56 percent.65 Other included studies attempted to exclude participants with secondary hypertension, but most failed to report the proportion of participants with primary or secondary hypertension.35, 57, 58, 60, 63, 64, 66, 68-70

Table 4 Drug Interventions for Hypertension in Children and Adolescents

Author, year Quality rating | Study design Setting Duration | N | Demographics | Treatment/ Intervention | Proportion of patients achieving ≤95th percentile of BP for age, gender, and height | Blood pressure outcomes (SBP, DBP mmHg)
Batisky et al, 2007^57^ Fair | RCT Clinical trial from 28 centers U.S. 4 weeks | 140 | Mean age 13 (SD 2.8) years 70% male 26% black Mean SBP: 132 mmHg Mean DBP: 78 mmHg 74% BMI ≥95% percentile | Group A: Metoprolol extended-release (ER) 0.2 mg/kg Group B: Metoprolol ER 1.0 mg/kg Group C: Metoprolol ER 2.0 mg/kg Group D: placebo | Groups A-C pooled: 46% (95% CI 37 to 55) Group B: 26% (95% CI 8 to 44) | Mean change from baseline, SBP: Group A: -5.2 (95% CI -7.7 to -2.6) Group B: -7.7 (95% CI -11.3 to -4.0) Group C: -6.3 (95% CI -8.7 to -3.8) Group D: -1.9 (95% CI -5.5 to 1.8) Mean change from baseline, DBP: Group A: -3.1 (95% CI -5.7 to -0.5) Group B: -4.9 (95% CI -8.6 to -1.3) Group C: -7.5 (95% CI -10.0 to -5.0) Group D: -2.1 (95% CI -5.7 to 1.5)
Flynn et al, 2004^61^ Fair | RCT crossover Clinical trial from 49 centers in North and South America 4 weeks | 268 | Mean age 12 (SD 3.3) years Mean SBP: 137.9 (SD 12.7) mmHg Mean DBP: 74.2 (SD 11.6) mmHg 31.3% (84/268) primary hypertension | Study Phase 2 (included placebo comparison) Group A: Amlodipine 2.5 mg/day Group B: Amlodipine 5.0 mg/day Group C: placebo | [underlined: SBP ≤95% percentile] Group A: 40% Group B: 35% Group C: 30% [underlined: DBP ≤95% percentile] Group A: 42% Group B: 75% Group C: 48% | Phase 2 results Mean change from baseline, SBP: Group A: -6.9 +12.5 (p=0.05 vs. placebo) Group B: -8.7 +13.3 (p=0.01 vs. placebo) Group C: -3.6 +12.7 Mean change from baseline, DBP: Group A: -4.2 (p=NS) Group B: -4.4 (p=NS) Group C: -0.4
Li et al, 2010^65^ Fair | RCT Clinical trial in 43 centers in the US, India, South Africa, Russia, and Dominican Republic 4 weeks | 304 | Mean age not reported (53% <12 years) 63% male 35% black 57% white 11% Hispanic 8% Asian 56% primary hypertension | Study Phase B (included placebo comparison) Group A: Eplerenone 25 mg once daily Group B: Eplerenone 25 mg twice daily Group C: Eplerenone 25 mg bid for 2 weeks followed by 50 mg bid for 4 weeks Group D: placebo | NR | Phase B results Least squares mean change from baseline, SBP: Group A: No statistically significant change Group B: 2.76 (95% CI -5.5 to 0; p=0.048 vs. placebo) Group C: No statistically significant change Least squares mean change from baseline, DBP: No statistically significant changes in any group
Sorof et al, 2002^67^ Fair | RCT Clinical trial from 22 centers in U.S. and Brazil 4 weeks | 94 | Mean age 14 years 57% male 43% white 41% black 14% Hispanic 1% Asian 1% multiracial Mean BMI 28 | Group A: Bisoprolol fumarate (B) 2.5 + hydrochlorothiazide (HT) 6.25 Group B: B 5 mg + HT 6.25 mg Group C: B 10 mg + HT 6.25 mg Group D: placebo | NR | Least squares mean change from baseline, SBP: Groups A-C pooled: -9.3 (p=0.5 vs. placebo) Group D: -4.9 Least squares mean change from baseline, DBP: Groups A-C pooled: -7.2 (p=0.01 vs. placebo) Group D: -2.7
Trachtman et al, 2003^68^ Fair | RCT Clinical trial at 30 sites in the U.S. 3 weeks | 133 | Mean age 12 years (SD 3) 60% male 39% black | Group A: 2.5 mg felodipine extended-release (ER) Group B: 5 mg felodipine ER Group C: 10 mg felodipine ER, titrated to target dose Group D: placebo | BP ≤90th percentile Group A: 15% Group B: 18% Group C: 19% Group D: 11% | Mean difference SBP at follow-up, vs. placebo (95% CI): Group A: -0.71 (-4.8 to 3.38; p=NS) Group B: -0.06 (-4.6 to 3.3; p=NS) Group C: -1.73 (-6.58 to 3.13; p=NS) Mean difference DBP at follow-up, vs. placebo (95% CI): Group A: -2.07 (-6.82 to 2.69; p=NS) Group B: -4.64 (-9.18 to 0.09; p<0.05) Group C: 1.31 (-3.56 to 6.11; p=NS)
Trachtman et al, 2008^69^ Fair | RCT Clinical trial at 42 sites in U.S. and Europe 4 weeks | 240 | Mean age not reported (29% <12 years; 71% >12 years) 71% male 69% BMI ≥95th percentile 47% black 45% white | Group A: Candesartan 2/4 mg Group B: Candesartan 8/16 mg Group C: Candesartan 16/32 mg Group D: placebo | Group A: 54% Group B: 62% Group C: 65% Group D: 31% | Least squares mean change from baseline, SBP: Groups A-C: -10.22 (p<0.0001 vs. placebo) Group D: -3.66 Least squares mean change from baseline, DBP: Groups A-C: -6.56 (p=0.0029 vs. placebo) Group D: -1.8
Wells et al, 2010^70^ Fair | RCT Clinical trial at 16 centers in U.S., Brazil, and Mexico 4 weeks | 77 | Mean age: 14 years (SD 3 years) 57% male 51% white 37% black | Group A: Telmisartan 1 mg/kg/day (low-dose group) Group B: Telmisartan 1 mg/kg/day, titrated up to 2 mg/k/day after 1 week (high-dose group) Group C: placebo | Group A: 50% (6 to <12 years); 68% (12 to <18 years) Group B: 86% (6 to <12 years); 79% (12 to <18 years) Group C: 33% (6 to <12 years); 27% (12 to <18 years) | Adjusted mean difference SBP at follow-up, versus placebo (95% CI): Group A: -3.6 (CI -9.2 to 1.9, p=NS) Group B -8.5 (-14 to -3.0, p=0.0027) Adjusted mean difference DBP at follow-up, versus placebo: Group A: -4.5 (-9.5, 0.4, p=NS) Group B: -4.8 (-9.7 to 0, p=0.051)

BMI = body mass index; BP = blood pressure; CI = confidence interval; DBP = diastolic blood pressure; NR = not reported; RCT = randomized controlled trial; SBP = systolic blood pressure; SE = standard error.

Table 5 Drug Combined With Lifestyle Interventions for Hypertension in Children and Adolescents

Author, year Quality rating | Study design Setting Duration | N | Demographics | Treatment/Intervention | Blood pressure outcomes (SBP, DBP mmHg)
Berenson et al, 1983^58^ Fair Other publication: Frank et al, 1982^71^ | RCT School-based 6 months | 150 | NR | ADAPT Program Group A: Propranolol 20-40 mg + chlorthalidone 6.25-12.5 mg + nutrition education and promotion of dietary modification Group B: Hypertensive control group | Mean change from baseline, SBP: Group A: -7.6 Group B: -3.0 Mean change from baseline, DBP: Group A: -6.9 Group B: -3.9
Berenson et al, 1990^59^ Fair Continuation of Berenson et al, 1983^58^ | RCT School-based 30 months | 150 | Mean age 12 years 55% male 47% white Mean SBP 117.7 Mean DBP 78.1 | Same as above | Adjusted mean difference, SBP: Group A vs. Group B: -3.6 (SD 1.12; p<0.01) Adjusted mean difference DBP: Group A vs. Group B: -1.7 (SD 0.82; p<0.05)

ADAPT = A Dietary/Exercise Alteration Program Trial; BMI = body mass index; BP = blood pressure; CI = confidence interval; DASH = Dietary Approaches to Stop Hypertension; DBP = diastolic blood pressure; NR = not reported; RCT = randomized controlled trial; SBP = systolic blood pressure; SD = standard deviation.

Table 6 Lifestyle Interventions for Hypertension in Children and Adolescents

Author, year Quality rating | Study design Setting Duration | N | Demographics | Treatment/ Intervention | Blood pressure outcomes (SBP, DBP mmHg)
Diet
Couch et al, 2008^60^ Fair | RCT Cincinnati Children's Hospital Medical Center, U.S. 6 months | 57 | Mean age 14 years 63% male Mean SBP 128.7 Mean DBP 80.5 | Group A: DASH-type diet modified for adolescent population + counseling Group B: Counseling alone | Mean difference at follow-up, SBP: Group A vs. Group B: 0.1 Mean difference at follow-up, DBP: Group A vs. Group B: -1.2 Proportion achieving normotensive status: Group A 61% vs. Group B 44%; p=0.36
Howe et al, 1991^64^ Fair | RCT crossover School-based Adelaide, Australia 2 phases of 4 weeks each | 103 | Mean age 13 years (range 11-14) Mean SBP 115.0 Mean DBP 60.1 | Group A: Low-sodium diet (<75 mmol/day) + counseling Group B: High-sodium (>150 mmol/day) diet + counseling | No significant differences in SBP or DBP between diets; baseline values not reported
Sinaiko et al, 1993^66^ Fair | RCT St. Paul and Minneapolis public schools, U.S. 3 years | 210 | Mean age 13 years 50% male Mean SBP 113.8 Mean DBP 65.1 | Group A: Low sodium diet (<70 mmol/day) Group B: Potassium chloride supplementation Group C: Participant's normal diet + placebo | Changes in SBP: Boys: No significant differences in rates of increase in SBP between low sodium, potassium supplement, and placebo groups Girls: Significant difference in SBP between low sodium group (slight overall decrease) and the placebo group (significant increase from baseline). No other differences between groups. Changes in DBP: Boys: No significant differences in rates of increase in BP between low sodium, potassium supplement, and placebo groups Girls: The low sodium group was the only group that had rates of increase in DBP compared to placebo that were significantly greater than zero.
Exercise
Hansen et al, 1991^63^ Fair | RCT Odense, Denmark School-based 8 months | 137 | Mean age not reported (range 9-11); other demographic characteristics not reported | Group A: Three extra lessons per week of an ordinary school physical education (PE) program Group B: No extra PE lessons | Mean difference at follow-up, SBP: Group A vs. Group B: -6.5 Mean difference at follow-up, DBP: Group A vs. Group B: -3.6
Meditation
Gregoski et al, 2011^62^ Fair | RCT School-based 3 months | 166 | Mean age 15 years 59% female 100% Black Mean SBP 118.9 Mean DBP 63.6 | Group A. Breathing awareness meditation (BAM) Group B. LifeSkills training: Group C. Health education control | Mean 24-hour SBP at 3-month follow-up: Group A vs. Group B vs. Group C: 116.6 vs. 119.8 vs. 121.0; Group A vs. Group B: p=0.13; Group A vs. Group C: p=0.05 Mean 24-hour DBP at 3-month follow-up: Group A vs. Group B vs. Group C: 66.3 vs. 68.2 vs. 68.7; p>0.05 for all comparisons (not statistically significant)
Progressive Muscle Relaxation
Ewart et al, 1987^35^ Fair | RCT 2 large Baltimore City public high schools 9 months | 159 | BMI range: 19.0-31.2 kg/m2 Mean age 15 years (range 13-17 years) 60% male 55% black | Group A: Progressive muscle relaxation (12 weeks, 15-20 minutes, 4 days per week) provided in school Group B: Control (no intervention) | No significant differences between SBP and DBP between treatment and control groups

BP = blood pressure; DBP = diastolic blood pressure; NR = not reported; RCT = randomized controlled trial; SBP = systolic blood pressure; SD = standard deviation.

Table 7 summarizes the effect of treatment on blood pressure as the mean difference from baseline and/or placebo, as reported, for all intervention types.

Table 7 Effect of Interventions on Blood Pressure: Mean Difference From Baseline and/or Placebo, as Reported

Author, Year Duration | Interventions | Baseline SBP and DBP (mmHg) | | Followup SBP and DBP (mmHg) | | Mean difference, baseline versus followup (mmHg) | | Mean difference at followup, intervention versus placebo (mmHg)
Author, Year Duration | Interventions | SBP | DBP | SBP | DBP | SBP | DBP | SBP | DBP
Drug
Batisky et al, 2007^72^ 4 weeks | Metoprolol 0.2 mg/kg | 131.4 | 76.3 | 126.2 | 73.2 | -5.2 | -3.1 | -4.6 | -6.1
Batisky et al, 2007^72^ 4 weeks | Metoprolol 1.0 mg/kg | 135 | 81 | 127.3 | 76.1 | -7.7 | -4.9 | -3.5 | -3.2
Batisky et al, 2007^72^ 4 weeks | Metoprolol 2.0 mg/kg | 130.60 | 76.7 | 124.3 | 69.2 | -6.3 | -7.5 | -0.2 | -10.1
Batisky et al, 2007^72^ 4 weeks | placebo | 132.7 | 81.4 | 130.8 | 79.3 | -1.9 | -2.1
Flynn et al, 2004^61^ 4 weeks | Amlodipine 2.5 mg | 137.9^*^ | 74.2^*^ | Not reported | | -6.9 | -4.2 | Not reported
Flynn et al, 2004^61^ 4 weeks | Amlodipine 5 mg | 137.9^*^ | 74.2^*^ | Not reported | | -8.7 | -4.4 | Not reported
Flynn et al, 2004^61^ 4 weeks | placebo | 137.9^*^ | 74.2^*^ | Not reported | | -3.6 | -0.4
Li et al, 2010^65^ 4 weeks | Eplerenone 25 mg | 125.0 | 71.3 | 124.1 | 70.7 | -0.9 | -0.6 | -5.4 | 0.8
Li et al, 2010^65^ 4 weeks | Eplerenone 50 mg | 125.7 | 70.9 | 126.2 | 70.9 | 0.5 | 0.0 | -3.3 | 1.0
Li et al, 2010^65^ 4 weeks | Eplerenone 100 mg | 128.1 | 70.3 | 127.0 | 69.4 | -1.1 | -0.9 | -2.5 | -0.5
Li et al, 2010^65^ 4 weeks | placebo (mean, all arms) | 128.7 | 70.4 | 129.5 | 69.9 | 0.8 | -0.5
Sorof et al, 2002^67^ 4 weeks | Bisoprolol + hydrochlorothiazide (all doses) | 133.8 | 83.0 | 124.0 | 76.0 | -9.8 | -7.0 | -4.5 | -3.5
Sorof et al, 2002^67^ 4 weeks | placebo | 133.8 | 81.8 | 128.5 | 79.5 | -5.3 | -2.3
Trachtman et al, 2003^68^ 3 weeks | Felodipine 2.5 mg | Not reported | | | | | | -0.7 | -2.1
Trachtman et al, 2003^68^ 3 weeks | Felodipine 5 mg | Not reported | | | | | | -0.1 | -4.6
Trachtman et al, 2003^68^ 3 weeks | Felodipine 10 mg | Not reported | | | | | | -1.1 | 1.3
Trachtman et al, 2003^68^ 3 weeks | placebo | Not reported | 83.1 | Not reported | 81.0 | Not reported | -2.1
Trachtman et al, 2008^69^ 4 weeks | Candesartan (all doses) | Not reported | | | | -10.2 | -6.6 | Not reported
Trachtman et al, 2008^69^ 4 weeks | placebo | Not reported | | | | -3.7 | -1.8
Wells et al, 2010^70^ 4 weeks | Telmisartan, low-dose | 132.0 | 79.0 | 123.0 | 71.3 | -9.7 | -8.1 | -3.6 | -4.2
Wells et al, 2010^70^ 4 weeks | Telmisartan, high-dose | 131.0 | 78.4 | 117.0 | 70.6 | -14 | -7.8 | -8.5 | -4.9
Wells et al, 2010^70^ 4 weeks | placebo | 130.0 | 78.4 | 126.0 | 75.5 | -6 | -3.5
Drug Plus Lifestyle
Berenson et al, 1983^58^ 6 months | Intervention | 116.6 | 77.7 | 109.0 | 70.8 | -7.6 | -6.9 | -6.5 | -3.6
Berenson et al, 1983^58^ 6 months | Control | 118.5 | 78.3 | 115.5 | 74.4 | -3.0 | -3.9
Berenson et al, 1990^59^ 30 months^†^ | Intervention | 116.6 | 77.7 | 118.0 | 73.5 | 1.4 | -4.2 | -3.6 | -1.7
Berenson et al, 1990^59^ 30 months^†^ | Control | 118.5 | 78.5 | 122.0 | 75.2 | 3.5 | -3.3
Lifestyle
Couch et al, 2008^60^ 6 months | DASH diet | 129.4 | 80.4 | 120.1 | 75.2 | -9.3 | -5.2 | 0.1 | -1.2
Couch et al, 2008^60^ 6 months | Routine care | 124.3 | 81.7 | 120.0 | 76.4 | -4.3 | -5.3
Ewart et al, 1987^35^ 9 months | Relaxation training | 127.0 | 79.1 | 118.6 | 72.9 | -8.4 | -6.2 | -2.3 | -3.1
Ewart et al, 1987^35^ 9 months | Control (no intervention) | 126.5 | 80.4 | 120.9 | 76.0 | -5.6 | -4.4
Gregoski et al, 2011^62^ 3 months | Meditation | 119.4 | 68.1 | 116.6 | 66.3 | -2.8 | -1.8 | -4.4 | -2.4
Gregoski et al, 2011^62^ 3 months | LifeSkills training | 119.6 | 68.0 | 119.8 | 68.2 | 0.2 | 0.2 | -1.2 | -0.5
Gregoski et al, 2011^62^ 3 months | Regular health education | 121.4 | 69.3 | 121.0 | 68.7 | -0.4 | -0.6
Hansen et al, 1991^63^ 3 months | Extra PE classes | Not reported | | | | | | -4.9 | -3.8
Hansen et al, 1991^63^ 3 months | No extra classes | Not reported
Howe et al, 1991^64^ 4 weeks | Low sodium diet | 115.0^*^ | 60.1^*^ | 112.6 | 59.1 | Not reported | | -1.2 | -0.9
Howe et al, 1991^64^ 4 weeks | High sodium diet | 115.0^*^ | 60.1^*^ | 113.8 | 60 | Not reported

* Values for total cohort; data not stratified according to treatment group.

† Continuation of Berenson 1983 study.

Drug interventions. The seven included trials of drug interventions all examined different drugs (Tables 4 and 7; Appendix B5), therefore meta-analysis was not possible. Drugs included extended-release metoprolol succinate,57 candesartan,69 telmisartan,70 amlodipine,61 extended-release felodipine,68 eplerenone,65 and bisoprolol fumarate/hydrochlorothiazide combination.67 The included studies typically involved two phases, an initial RCT lasting up to 4 weeks in which the active drug (in different doses) was compared with placebo, followed in some trials by a longer period of up to 1 year of observation providing only safety data. None of the studies provided outcomes of efficacy beyond 4 weeks. The number of participants in the studies ranged from 77 to 304, and all studies were conducted in clinic settings in various countries; most, but not all, included at least one site in the United States.

Percentage achieving normotensive blood pressure. Overall ranges for children achieving normotensive status (based on varying definitions) ranged from 15 to 86 percent in patients taking drug treatments and 11 to 48 percent in patients taking placebo. The following studies reported the percentages of participants achieving blood pressure <95th percentile (or the <90th percentile68) for their age, sex, and height: extended-release metoprolol succinate, 46 percent (compared with placebo, 26%; p values not reported);57 amlodipine: SBP, 33.3 percent, DBP, 45 percent for primary hypertension (compared with placebo: SBP, 29.4%, DBP, 47.6%; p-values not reported);61 15.2 to 19.4 percent for various doses of extended-release felodipine (compared with 11.4% for placebo; p-values not reported);68 candesartan, 54 to 65 percent for various doses (compared with placebo, 33.3%; p<0.05);69 and telmisartan, 79.2 to 85.7 percent for high dose (compared with placebo, 27.3% to 33.3%; p=0.10) and 50.0 to 68.2 percent for low dose (compared with placebo but values not reported; p=0.325), depending on the child's age.70

Mean reductions in blood pressure. With the exception of one outlier, the results of the included studies showed significant reductions with some doses of some drugs in mean SBP ranging from 2 to 10 mm Hg, and from 0.4 to 8 mm Hg mean DBP, from baseline to followup. Similarly, SBP reductions were 0 to 9 mm Hg and DBP reductions were 0.5 to 10 mm Hg between intervention and placebo groups. One study of eplerenone 50 mg per day reported a small mean increase in SBP and no change in DBP, and for all studies, some doses of active interventions were not effective and various drugs were only effective for SBP and not DBP, or vice versa.

Drug combined with lifestyle interventions. One trial (in two publications) examined an intervention that combined education, support, and dietary change with a propranolol/chlorthalidone drug combination58, 59 (Tables 5 and 7; Appendix B5).

The school-based ADAPT (A Dietary/Exercise Alteration Program Trial), which included a propranolol/chlorthalidone drug combination, was the only trial identified that showed effectiveness in reducing blood pressure over a long followup period.58, 59 The intervention included a program consisting of nutrition education and promotion of diet modification to children and parents (i.e., educational materials, cooking classes for parents, individual dietary consultations, pledges, t-shirt rewards), expanded community availability of low-sodium foods in grocery stores, restaurants, and school lunches, and a school-based exercise component. Berenson et al. found that both SBP and DBP decreased significantly between baseline and 6-month followup (SBP, -7.6 mm Hg [p<0.0001]; DBP, -6.9 mm Hg [p<0.01]) compared with the control group. These results were not sustained 30 months after treatment, at which time SBP had increased from baseline values in both the intervention (+1.4 mm Hg) and control groups (+3.5 mm Hg), though DBP values remained lower than baseline values (-4.2 and -3.3 mm Hg, respectively).

The trial had methodologic flaws, including unclear loss to followup.58, 59

Lifestyle interventions. Six trials of lifestyle interventions were identified, the majority of which included support related to the interventions (e.g., regular check-ins) in addition to dietary, exercise, meditation, and progressive muscle relaxation35, 60, 62-64, 66 (Tables 6 and 7; Appendix B5) only one of which demonstrated statistically significant reductions in blood pressure when compared with untreated controls.63

One small school-based trial from Denmark compared the effects of three classes of physical education in addition to the existing two physical education classes (i.e., total of five classes per week) for a period of 8 months. Hypertensive children randomized to the additional exercise group had a significant SBP decrease of 4.9 mm Hg and a DBP decrease of 3.8 mm Hg compared with the usual level of physical education classes after 8 months (p<0.05 for both).63

Another trial comparing children randomized to a low-sodium diet combined with personalized support and/or potassium chloride supplementation or usual care found that the low-sodium portion of the intervention was only effective in reducing blood pressure for girls compared with placebo, but not for boys at 36-month followup.66

Other studies of dietary changes,60, 64 meditation,62 and progressive muscle relaxation35 reported no difference in blood pressure changes between intervention and control groups.

## Key Question 6 What Is the Effectiveness of Drug, Nondrug, and Combination Interventions Initiated for the Treatment of Primary Hypertension in Children/Adolescents for Reducing Blood Pressure and Other Intermediate Outcomes in Adults?

We identified no studies that reported on the effectiveness of treatments for primary childhood hypertension and subsequent reduction of blood pressure or other intermediate outcomes in adulthood.

## Key Question 7 What Is the Effectiveness of Drug, Nondrug, and Combination Interventions Initiated for the Treatment of Primary Hypertension in Children/Adolescents for Reducing Adverse Health Outcomes in Adults Related to Primary Hypertension?

We identified no studies that reported on the effectiveness of treatments for primary childhood hypertension and subsequent reduction of adverse health outcomes in adulthood.

## Key Question 8 What Are the Adverse Effects of Drug, Nondrug, and Combination Interventions for Treating Primary Hypertension in Children/Adolescents?

### Summary

Drug interventions for treating primary hypertension in children appear to be well-tolerated, though high-quality data are lacking in this population, as most studies enrolled a mixture of children with primary and secondary hypertension. Across one good-quality and 10 fair-quality studies, there were no significant differences between treated and untreated children in either the proportion experiencing an adverse event or in withdrawals due to adverse events, and serious adverse events were rarely reported. One additional fair-quality trial noted that a combination of bisoprolol and hydrochlorothiazide was associated with lower adverse event rates than placebo. Pooled data from numerous RCTs found no difference between active treatments and placebo groups in incidence of specific harms, including headache, cardiac events, gastrointestinal events, and cough. Evidence on adverse events associated with interventions that combined drug and lifestyle modifications is extremely limited. A study of a combination of drug and lifestyle interventions reported no serious adverse events in the active treatment group compared with untreated children. We identified no studies reporting on harms associated with nondrug treatments.

### Evidence

Drug interventions. Eleven RCTs57, 61, 65, 68-70, 73-77 of drug monotherapy and one trial of combination drug therapy67 reported safety data (Table 8). One study was rated good-quality;73 the remainder were of fair-quality, primarily due to failure to adequately report method of randomization and allocation concealment and lack of details about blinding (Appendix B6). All were dose-ranging studies that included a placebo arm or a placebo washout phase. Four of the studies included only primary hypertension patients,57, 68-70 while the other studies enrolled a mix of patients with primary and secondary hypertension.61, 65, 67, 73-77 The number of children enrolled in the studies ranged from 76 to 304, mean ages ranged from 12 to 17 years, and duration of followup for harms data ranged from 4 weeks to 1 year (in studies with open-label phases).

Table 8 Harms of Interventions for Hypertension in Children and Adolescents

Author, Year Quality rating | Relevancy (best information reported) | Type of study Setting Duration | Mean age (SD) | # randomized or analyzed | Intervention | Adverse events (AEs)
Drug
Batisky et al, 2007^57^ Fair | Inclusion criteria of primary hypertension only | RCT Clinical trial from 28 centers U.S. 4 week long dose-ranging study 52 week long safety study | 12.5 (2.8) | 144 randomized in dosing study 100 analyzed in safety study | ER metoprolol succinate 0.2 to 2.0 mg/kg Placebo 52-week open-label study: 25 mg or 12.5 mg once daily at investigator discretion; increase every 2 weeks until maximum of 200 mg once daily | 4-week dose-ranging study: 1 withdrawal due to AEs Heart rate decreased by 6.5 beats/min in 1.0 mg/kg group (compared to increase of 5.4 bpm in placebo group), fatigue noted by 1 patient each in the 0.2, 1.0 and 2.0 mg/kg groups) 52-week safety study: 5 withdrawals due to AEs (1 each of fatigue, nightmares, anxiety, dizziness, asthma) Serious AEs: 2/100 (2%; 1 pneumonia and 1 menometrorrhagia) Other AEs: Headache: 30% Upper respiratory tract infection: 20% Cough: 19% Nasopharyngitis: 13% Pharyngolaryngeal pain: 12% Fatigue: 9% Diarrhea: 7% Dizziness: 6%
Flynn et al, 2004^61^ Fair | 31% primary hypertension | RCT crossover Clinical trial from 49 centers in North and South America 2 4-week phases | 12.1 (3.3) | 268 randomized; 84 with primary hypertension | Amlodipine 2.5 to 5.0 mg/day Placebo | Withdrawals due to AEs: 12/268, of which 6 considered by study investigators to be study drug-related (3 worsening hypertension, 1 facial edema, 1 finger edema and rash, 1 premature ventricular contractions) Serious AEs: 5/268 (2%; 1 each: urinary tract infection, gastroenteritis and hypovolemia, pulmonary edema, bilateral pneumonia, pancreatitis)
Hazan et al, 2010^73^ Good | Hypertensive primary hypertension in 128+97/302; Patients with clinically significant medical condition or chronic disease, malignant hypertension or severe hypertension excluded | RCT clinical trial at 61 sites; 2 cohorts based on race, 2 week washout period Phase 1: 3 week dosing study Phase 2: 2 week withdrawal study | 12.2 (2.97) | 422 screened 302 randomized to 2 cohorts | Olmesartan medoxomil | Any adverse event: olmesartan 33/93 (36%) vs. placebo 27/89 (30) Incidence of specific AEs not reported; headache reported “most common”
Li et al, 2004^74^ Fair | Hypertensive (20.9% with renal etiology, otherwise not reported), or high-normal blood pressure in the presence of associated clinical condition such as diabetes mellitus | Dose-ranging RCT; 78 clinical centers in U.S., Russia, Israel Phase A: 10-day run-in Phase B: 4 week dose-ranging Phase C: 2 week withdrawal vs. placebo Phase D: 1 year open-label safety phase | 12.1 (2.6) | 376 screened 255 eligible 253 randomized | Fosinopril | Overall study withdrawals across all 4 phases of study due to AEs: 5/253 (2%) Phase C: Incidence of AEs similar between placebo (33.9%) and combined fosinopril treatment groups (34.3%) Phase D: Specific AEs: Headache: 51/253 (20%) Nasopharyngitis: 24/253 (10%) Cough: 23/253 (9%) Pharyngitis: 22/253 (9%) Abdominal pain: 16/253 (6%)
Li et al, 2010^65^ Fair | 56% primary hypertension 22% obesity-related hypertension 17% renal-related hypertension | RCT clinical trial in 43 centers in the U.S., India, South Africa, Russia, and Dominican Republic Phase A: 6 week dosing study (no placebo) Phase B: 4 week placebo-controlled study | Age <12 years: 52.6% | 304 randomized | Eplerenone 25 mg once daily, 25 mg twice daily, or 25 mg twice daily for 2 weeks then 50 mg twice daily for 4 weeks Placebo | Phase A: Any AE: low-dose 38% vs. middle-dose 31% vs. high-dose 40% 274 reports of mild AEs, mainly headache and upper respiratory tract infections 106 reports of moderate AEs 18 reports of severe AEs (4 possibly or definitely related to treatment: migraine, fatigue, bronchitis, headache) 4 permanent discontinuations, 3 of which were considered treatment-related: hypotension, hypertension, fatigue Phase B: No significant differences in AE frequencies between active therapy and placebo; 8 patients had worsening hypertension during this phase, including 2 in the high dose group that were withdrawn from the study
Shahinfar et al, 2005^75^ Fair | Hypertension; “more than 50% had underlying kidney disease” (secondary hypertension) but no further details reported | Dose-ranging RCT: Phase 1 randomized to 3 different doses, Phase 2 randomized washout; 43 clinical centers in North and South America (including U.S.), Europe, Africa 36 days | 12 (3.1) | 175 randomized | Losartan | Withdrawals due to AEs: 1/175 (<1%) Drug-related AEs: 14/175 (8%), of which headache (5) was most common event Comparison of AE in Phase 2 between active drug and control not reported
Soffer et al, 2003^76^ Fair | Hypertension; unclear severity of underlying kidney disease (study entry required glomerural filtration rate ≥30 ml/min/1.73 m^2^) | Dose-ranging RCT Phase 1 randomized to 3 different doses, Phase 2 randomized washout Multisite (number and location not reported); 29 days | Mean not reported 47% <6 to 12 years, 53% 13 to 16 years | 115 randomized | Lisinopril | Withdrawals due to AEs: 1/115 (<1%) Drug-related AEs: 14/115 (12%) Headache: 4/115 (4%) Gastrointestinal (abdominal pain, diarrhea, nausea and/or vomiting): 2/115 (2%) Dizziness: 2/115 (2%) Cough: 1/115 (<1%)
Sorof et al, 2002^67^ Fair | Excluded severe hypertension and correctable secondary hypertension | RCT clinical trial from 22 centers in U.S. and Brazil 2 week run-in, 8 week titration period, 4 week dose maintenance period, 2 week tapering period | 13.8 (3.1) | 94 randomized (62 treatment + 32 placebo) | Bisoprolol fumarate/hydrochlorothiazide combination (B/HT) (n=62): B 2.5 mg/HT 6.25 mg B 5 mg/HT 6.25 mg B 10 mg/HT 6.25 mg Placebo (n=32) | B/HT group had fewer overall AEs than placebo group, 33/62 (53%) vs. 24/32 (75%) (p=0.047) and fewer serious AEs, 1/62 (2%) vs.5/32 (16%) (p=0.016) B/HT group: Most common AE was headache (26%) 1 patient had severe hypertension, and discontinued the study. Placebo group:Most common AE was headache (31%) 2 patients had severe hypertension, and discontinued the study
Trachtman et al, 2003^68^ Fair | Excluded secondary hypertension | RCT Clinical trial at 30 sites in the U.S. 1 to 3 week screening period, 2 to 3 week dose titration period, 3 week maintenance study | 12.1 (2.7) | 133 randomized | ER felodipine 2.5 mg (n=33), 5 mg (n=340, or 10 mg (n=31), titrated to target dose over 2-3 weeks, depending on dosage Placebo (n=35) | 1 withdrawal due to “heart racing”; heart rate was 96 bpm and ECG normal; and 1 withdrawal due to vomiting the first dose (5 mg) % reporting AEs: placebo 66% and 64%, 56%, and 77% in the felodine ER 2.5 mg, 5.0 mg, and 10 mg groups, respectively Most common AEs were headaches (33%), respiratory infections (12%), and nausea (10%) Pedal edema was noted in 2 (2%) of patients
Trachtman et al, 2008^69^ Fair | Excluded secondary hypertension; Other hypertensives, except for other angiotension receptor blockers, were permitted | RCT clinical trial at 42 sites in U.S. and Europe 4 week trial and 1 year open-label study | % Age >12 years: 70.8% | 240 randomized | 4 week trial: Candesartan doses 2, 8, and 16 mg/day for those <50 kg, and 4, 16, and 32 mg/day for those ≥50 kg Placebo Open label study: Candesartan at 4 or 8 mg/day to start, but later adjusted to control blood pressure | 3/240 patients in the 4 week trial and 5/233 patients in the 52 week study discontinued due to AEs, specifically hypotension, arm fracture, dizziness, headache, low white blood cell count, and progression of underlying renal disease (2 patients) Most common AEs: headache, upper respiratory infection, dizziness, cough, and sore throat
Wells et al, 2002^77^ Fair | Severe or symptomatic hypertension excluded | Dose-ranging RCT 2 week dose ranging phase and 2 week placebo controlled washout phase | Median 12 years | 110 enrolled | Enalapril | Drug-related AEs: 12/110 (11%) Dizziness: 4/110 (4%) Headache: 2/110 (2%) Cough: 3/110 (3%) No incidence of renal failure, angioedema or hyperkalemia 5 laboratory AEs possibly, probably or definitely related to study drug
Wells et al, 2010^70^ Fair | Excluded secondary hypertension | RCT clinical trial at 16 centers in U.S., Brazil, and Mexico 4 weeks, after 2 week washout period | 14 (2.5) | 115 enrolled 77 randomized | Telmisartan low dose (1 mg/kg/day) (n=30) and high dose (1 mg/kg/day titrated up to 2 mg/k/day after 1 week) (n=31) Placebo (n=16) | Any adverse event: High dose patients: 41.9% Low dose patients: 41.7% Placebo patients: 31.3% (significance not reported) 2 patients discontinued due to AEs, both in the high dose group: 1 patient who experienced a serious AE (near syncope and moderate increase in blood urea nitrogen and serum creatinine) who received an excessive dose in error; and 1 patient due to moderate-intensity dizziness, weakness, and headache
Drug Plus Lifestyle
Berenson et al, 1983^58^ Fair | BP >90th percentile for height, Control group with blood pressure <80th percentiles and the 50 to 60th percentile for comparison (based on centiles derived from study) Excluded children with evidence of secondary hypertension | “Close to clinical trial” School-based 6 months | 12 | 150 (50 high blood pressure treatment group, 50 high blood pressure comparison group, 50 medium blood pressure comparison group) | Group A: Propranolol 20 mg/day for children < 40kg, 40 mg/day for those >40 kg + Chlorthalidone 6.25 mg per day for children <40kg, 12.5 mg/day for those >40 kg + nutrition education and promotion of dietary modification to children and parents Group B (high blood pressure elevation at baseline): No treatment Group C (medium BP elevation at baseline): No treatment | AEs reported as very low incidence with no major complications 1 temporary withdrawal from active treatment due to nightmares
Other Clinical Studies (FDA Analyses)
Baker-Smith et al, 2010^79^ Not rated for quality | Mild to moderate hypertension | Non-systematic review and meta-analysis of data from 8 trials submitted to FDA between 1998 and 2005 (original studies not cited) 2 weeks (median) | 13 | 1,299 analyzed (42% placebo + 58% active drug) | ACEs [6 datasets] and ARBs [2 datasets], including benazepril (n=85), enalapril (n=101), fosinopril (n=222), lisinopril (n=104), quinapril (n=112), ramipril (n=217), irbesartan (n=293), losartan (n=165) Dosages not reported | Subjects who reported cough in the cohort receiving active drugs (21/748, 2.8%) vs. placebo (14/551, 2.5%), p=0.86 Subjects who reported cough in the ACE group: (17/524, 3.2%); ARB group (4/224, 1.8%), p=0.34
Smith et al, 2008^78^ Not rated for quality | Unclear; severe hypertension and significant renal disease excluded | Non-systematic review and meta-analysis of data from 10 RCTs submitted to FDA between 1998 and 2005 (original studies not cited) 2 to 4 weeks (varied by trial) | 12.1 | 1,707 analyzed (685 placebo, 1,022 active treatments) | Active treatments (n=1,022; mean doses not reported): Amlodipine (n=258), Benazepril (n=85), Enalapril (n=101), Felodipine (n=133), Fosinopril (n=235), Irbesartan (n=295), Lisinopril (n=104), Losartan (n=165), Quinapril (n=112), Ramilpril (n=219) Placebo (n=685) | Placebo vs. active treatment : No significant difference between groups for any AEs Any AE: 235/685 (34%) vs. 382/1,022 (37%) Hypertension: 3/685 (4%) vs. 1/1,022 (>1%) Hypotension: 0/235 (0%) vs. 3/1,022 (>1%) Cardiac: 8/685 (1%) vs. 16/1,022 (2%) Neuropsychological: 13/685 (2%) vs. 26/1,022 (3%) Headache: 113/685 (17%) vs. 179/1,022 (18%) Syncope: 15/685 (2%) vs. 31/1,022 (3%) Gastrointestinal: 54/685 (8%) vs. 90/1,022 (9%) Asthma: 11/685 (2%) vs. 12/1,022 (1%) Elevated LFT: 7/685 (1%) vs. 7/1,022 (>1%) Muscle aches: 11/685 (2%) vs. 17/1,022 (2%)

ACE = angiotensin-converting enzyme inhibitors; AE = adverse events; ARB = angiotensin receptor blockers; bpm = beats per minute; B/HT = bisoprolol fumarate/hydrochlorothiazide; ECG = electrocardiograph; ER = extended release; FDA = United States Food and Drug Administration; LFT = liver function test; RCT = randomized controlled trial; SD = standard deviation.

Adverse event data were often poorly reported, and many did not include data from placebo arms/phases but rather reported longer-term data on active treatments only from open-label study phases. Five studies of monotherapy reported similar proportions of patients experiencing any adverse event between active treatment (range, 27% to 77%) and placebo (range, 25% to 66%) arms.65, 68, 70, 73, 74 One study of a combination of bisoprolol plus hydrochlorothiazide compared with placebo found that children taking bisoprolol plus hydrochlorothiazide had lower overall rates of any adverse events compared with children taking placebo (53% vs. 75%; p=0.05) after 12 weeks of followup.67 Withdrawals due to adverse events ranged from 0 to 7 percent in children receiving active treatments57, 61, 67-70, 73-77 and 0 to 6.2 percent in placebo groups,57, 67, 69, 70, 73, 74 though, again, not all studies reported events in placebo groups/phases. Serious harms were rarely reported. One study reported two cases of patients with serious harms (pneumonia and metometrorrhagia) taking metoprolol57 and one study reported one serious adverse event (near syncope and elevated creatinine) in a patient who received an incorrect dose of telmisartan. A third study reported eight cases of serious adverse events in 304 patients, though none were considered to be treatment related.65 A fourth study reported fewer serious adverse events, most commonly severe hypertension, in the active treatment group than the placebo group (2% vs. 16%; p=0.02).67 No deaths were reported in any of the studies.

Headache was described as the most common specific adverse event in most studies, with rates ranging from 2 to 33 percent in children receiving active treatments among the studies that reported data.57, 67, 68, 70, 74, 77 Only two studies included comparative rates for placebo, with no incidence of headache noted in those patients compared with 11 percent of active treatment patients in one study70 and 31 versus 26 percent (placebo vs. combination treatment) in another study.67 Other commonly reported adverse events associated with active treatments were cough, upper respiratory infection, and gastrointestinal events, including nausea and diarrhea, though specific rates were not always reported.57, 61, 67-70, 74-77

More detailed data on specific adverse events associated with drug treatments for childhood hypertension are available from two analyses of trials submitted to the U.S. Food and Drug Administration (FDA) over a 7-year period. Neither study met criteria for systematic review and conclusions from included data are potentially subject to bias, as there was inadequate reporting of searches, inclusion criteria, quality rating, and methods used to pool data. One study provided an analysis of a series of patient-level data from 1,707 children (mean age, 12 years; 62% male) from 10 placebo-controlled RCTs submitted to the FDA.78 Event rates were pooled for all active treatments—including amlodipine, benazepril, enalapril, felodipine, fosinopril, irbesartan, lisinopril, losartan, quinapril, and ramipril—and compared with placebo rates. Overall adverse event rates were similar between active treatment groups and placebo groups among the included studies (0.83 vs. 0.76 per patient, respectively; p=0.37). There were no significant differences between active treatments and placebo for any adverse event, including headache (47% vs. 48%; p=0.68), cardiac events (16% vs. 8%; p=0.5), gastrointestinal events (24% vs. 23%; p=0.51), syncope (8% vs. 6%; p=0.35), asthma (12% vs. 11%; p=0.58), and elevated liver function tests (7% vs. 7%; p=0.51).78 The second FDA study compared the incidence of cough in hypertensive children (mean age, 13 years; 61% male) treated with active interventions (n=748) or placebo (n=551).79 Based on data from eight placebo-controlled trials, there was no difference in incidence of cough between active treatment (3% of patients) or placebo groups (3% of patients; p=0.86) among the included studies.

Drug combined with lifestyle interventions. One fair-quality trial (ADAPT) reported no adverse events in children treated with propanolol plus chlorthalidone in addition to lifestyle intervention focusing on dietary modification and exercise compared with untreated children58 (Table 8).

Lifestyle interventions. We did not identify any studies of lifestyle modification interventions that reported adverse events.