# INTRODUCTION

## Purpose and Prior USPSTF Recommendation

The purpose of this systematic evidence review is for the U.S. Preventive Services Task Force (USPSTF) to update its recommendation on screening for high blood pressure in children and adolescents to prevent cardiovascular disease. In 2003, the USPSTF found poor evidence that routine blood pressure measurement accurately identifies children and adolescents at increased risk for cardiovascular disease, and poor evidence to determine whether treatment of elevated blood pressure in children or adolescents decreases the incidence of cardiovascular disease. As a result, the USPSTF could not determine the balance of benefits and harms of routine screening for high blood pressure in children and adolescents, which resulted in an I recommendation.1, 2

Recent data from the National Health and Nutrition Examination Survey suggest that mean blood pressure levels are rising steadily in children,3 as is the prevalence of childhood hypertension.4 This may be due to the increase in the prevalence of obesity and overweight among children,4, 5 which is highly correlated with high blood pressure (see Contextual Question 1 below). Screening of asymptomatic children has the potential to detect hypertension at earlier stages, so that interventions can be initiated which, if effective, could reduce the adverse health effects of childhood hypertension in both childhood and adulthood, including cardiovascular disease and end-organ damage.5 This report summarizes recent and older evidence on screening and diagnostic accuracy of screening tests for high blood pressure in children, the effectiveness and harms of treatment for screen-detected, primary childhood hypertension, and the tracking of hypertension from childhood to adulthood.

## Condition Definition

The National High Blood Pressure Education Program (NHBPEP) and the National Heart, Lung, and Blood Institute (NHBLI) define prehypertension and hypertension in children based on centiles according to age, height, and sex.6-8 Prehypertension is defined as systolic blood pressure (SBP) or diastolic blood pressure (DBP) readings at or above the 90th percentile but less than the 95th percentile. Hypertension is defined as SBP or DBP readings at or above the 95th percentile. Hypertension is categorized as stage 1 (SBP or DBP from the 95th to 99th percentile, plus 5 mm Hg) or stage 2 (SBP or DBP above the 99th percentile, plus 5 mm Hg).7

The NHBPEP provides detailed guidance on optimal blood pressure measurement techniques,6 including recommendations on type of sphygmomanometer and appropriate cuff size. Blood pressure measurement should be performed in a controlled environment after 5 minutes of rest, with the child or adolescent seated with their right arm supported at heart level. Screening programs need to ensure that children and adolescents with elevated blood pressure readings have followup measurements to confirm (or exclude) the presence of hypertension. The NHBPEP also recommends that measurements should be obtained over time at multiple clinic visits, and at least three consistent, elevated readings are required for a diagnosis of prehypertension or hypertension.6 Children whose blood pressure is elevated on at least three occasions need to be assessed by a health care provider regarding the need for further investigations and to discuss management strategies.

## Prevalence and Burden of Disease

The prevalence of hypertension in the general (asymptomatic) population of children is between 1 and 5 percent,9, 10 while children with a higher body mass index (BMI) (>95th percentile) have a higher prevalence (about 11%).11 Younger children with hypertension are more likely to have an underlying condition causing the hypertension (i.e., secondary hypertension, see Contextual Question 2, below), while older children and adolescents are more likely to have primary hypertension.12, 13

The prevalence of hypertension in children in the United States has increased by about 1 to 2 percent over recent decades,4 and longitudinal population-based studies of blood pressure data between 1963 and 2002 suggest that the increase is largely attributable to the rise in childhood obesity.4, 14 In addition, some authors have suggested that a significant proportion of children with hypertension are not currently diagnosed.15, 16

Childhood hypertension, particularly stage 2, is thought to cause damage to end-organs adversely affected by elevated blood pressure, mainly the cardiovascular, renal, and cerebrovascular systems. Children with stage 2 hypertension usually require drug interventions to reduce the risk of end-organ damage.7

## Etiology and Natural History

Hypertension can be secondary to an underlying disorder or a primary condition (primary hypertension).

Primary hypertension has been linked with numerous potential risk factors, including BMI, parental history of hypertension, nutrition, race, and sex (see Contextual Question 1, below). The proportion of children with primary hypertension whose blood pressure subsequently returns to normal without treatment or other changes in lifestyle is unknown. However, a proportion of children who have elevated blood pressure in childhood will continue to experience elevated blood pressure in adulthood, a phenomenon known as tracking (see Key Question 3, below).

Secondary hypertension can be caused by a large number of underlying conditions in children, most commonly renal parenchymal disease (e.g., glomerulonephritis, renal scarring due to reflux nephropathy, polycystic kidney disease, and chronic renal failure) or renovascular disease (e.g., fibromuscular dysplasia.).13, 17 Less common causes of secondary hypertension in children include aortic coarctation (10% to 20%) and endocrine disorders (e.g., pheochromocytoma, hyperthyroidism) or are related to medications (e.g., oral contraceptives in adolescents, sympathomimetic drugs, dietary supplements).13, 17 In children with secondary hypertension, elevated blood pressure is unlikely to be the only clinical manifestation of the underlying disorder, and the type of treatment is directly related to the type of hypertension (and in some cases, correction of any underlying disorder). In some cases, treatment of the underlying cause may allow blood pressure levels to return to normal levels, while in other cases, elevated blood pressure may track into adulthood.

The clinical sequelae of elevated blood pressure are either due to the effects of sustained blood pressure over a longer period of time or, less commonly, to the presence of extremely high levels of blood pressure for a short period (known as hypertensive emergency). Sustained elevation of blood pressure in adults is an established risk factor for multiple conditions, including cardiovascular and cerebrovascular disorders and renal impairment. However, in children these are remote events, and therefore intermediate measures of target end-organ damage have been proposed, including physical alterations to the structure of vascular walls (e.g., early atherosclerosis, thickening of arteries) and the heart (e.g., increase in left ventricle mass) and altered renal function (e.g., microalbuminuria). The evidence for the independent causal effect of hypertension (over and above obesity, for example) on several of these markers is growing but remains unclear, as does the extent to which these regress when levels of blood pressure are reduced with antihypertensive intervention.18-23

The clinical sequelae of extremely high levels of blood pressure elevation over even short periods of time are well known, and include hypertensive encephalopathy, renal impairment, cardiac failure, and cerebrovascular accidents. For this reason, very high levels of blood pressure constitute an urgent situation and may require immediate intervention to correct underlying causes and to lower blood pressure to avoid end-organ damage.

## Rationale for Screening/Screening Strategies

The rationale for screening children and adolescents for elevated blood pressure is that if hypertension can be identified at an early stage, then interventions could be initiated to decrease the level of blood pressure in affected individuals, decreasing the rate of progression of hypertension from children to adults, and thus reducing the personal and public health burden of hypertension24 and the resulting cardiovascular outcomes. In addition, treatment may be beneficial to children during childhood. Because hypertension is often asymptomatic, screening identifies children with elevated blood pressure who may not otherwise have been diagnosed. The same screening tests are used to identify both primary and secondary hypertension.

There are a number of strategies that could be used to screen children and adolescents for elevated blood pressure, including measurement of blood pressure during routine visits to health care facilities, such as for well-child examinations and preparticipation physicals for sports, or during acute-care appointments. Other strategies could include school-based screening programs or screening in other community settings.

## Interventions/Treatment

Stage 1 hypertension in children is treated with drug and lifestyle interventions, although drugs are not recommended as first-line therapy.6 Lifestyle interventions for hypertension include weight reduction in children who are overweight or obese coupled with increased physical activity and limited salt intake, as well as education and counseling. The NHBPEP recommends drug treatments for children with stage 2 hypertension or for hypertension that does not respond to lifestyle modification.6 Numerous drug interventions have been approved to treat hypertension in children, including diuretics, angiotensin-converting enzyme inhibitors, angiotensin receptor blockers, beta blockers, and vasodilators (Table 1). Interventions for secondary hypertension depend upon the underlying cause and therefore vary greatly.

Table 1 Drug Interventions for Hypertension in Children and Adolescents

Drug class | Drug | Dosing
ACE inhibitors | Benazepril | Starting dose: 0.2 mg/kg/day up to 10 mg/day Maximum dose: 0.6 mg/kg/day up to 40 mg/day
ACE inhibitors | Enalapril | Starting dose: 0.08 mg/kg/day up to 5 mg/day Maximum dose: 0.6 mg/kg/day up to 40 mg/day
ACE inhibitors | Fosinopril | Weight >50 kg: 5-10 mg/day, maximum 40 mg/day
ACE inhibitors | Lisinopril | Starting dose: 0.07 mg/kg/day up to 5 mg/day Maximum dose: 0.6 mg/kg/day up to 40 mg/day
ARBs | Irbesartan | Age 6-12 years: 75-150 mg/day Age ≥13 years: 150-300 mg/day
ARBs | Losartan | Starting dose: 0.7 mg/kg/day up to 50 mg/day Maximum dose: 1.4 mg/kg/day up to 100 mg/day
Beta blockers | Propanolol | Starting dose: 1-2 mg/kg/day Maximum dose: 4 mg/kg/day up to 640 mg/day
Beta blockers | Amlodipine | Age 6-17 years: 2.5-5 mg/day
Central alpha-agonists | Clonidine | 0.2-2.4 mg/day
Diuretics | HCTZ | 1-3 mg/kg/day; maximum 50 mg/day
Vasodilator | Hydralazine | 0.75-7.5 mg/kg/day; maximum 200 mg/day
Vasodilator | Minoxidil | Age <12 years: 0.2 mg/kg/day; maximum 50 mg/day Age ≥12 years: 5 mg/day; maximum 100 mg/day

Source: National High Blood Pressure Education Program Working Group on High Blood Pressure in Children and Adolescents, 2004.^6^

ACE = angiotensin-converting enzyme; ARBs = angiotensin receptor blockers.

## Current Clinical Practice

Current screening practice for elevated blood pressure typically involves measurement of blood pressure in office-based health care settings as part of well-child or sports preparticipation examinations, often in conjunction with other vital signs and growth parameters. NHBPEP centile charts are then used to interpret SBP and DBP levels and categorize them as normal, prehypertension, or hypertension based on a child's age, height, and sex. A simplified version has been proposed that has only one threshold value of abnormal SBP and DBP by sex, for each year of the child's life from age 3 to 18 years.25

As stated earlier, the NHBPEP recommends repeating blood pressure measurements on two more occasions in children in whom a single elevated SBP or DBP reading has been noted. This is to ensure that subsequent clinical actions are taken based on blood pressure values that are truly elevated, rather than values that are falsely elevated due to either measurement error or anxiety and discomfort in the child (known as “white coat hypertension”). Compliance with this practice in clinical settings in the United States is not known. Based on a cohort study of 14,187 children seen in outpatient departments in the United States, of whom 507 (3.6%) had elevated blood pressures, only one quarter of children (131 [26%]) had a diagnosis of hypertension documented in their electronic health record, suggesting that repeat blood pressure measures had not been obtained in the majority to confirm or exclude hypertension.16

The subsequent clinical workup of children in whom hypertension has been diagnosed aims to identify possible underlying causes of hypertension, detect comorbid conditions, and determine the presence of any target end-organ damage. The NHBPEP recommends a structured approach to identifying possible underlying causes, with a workup that includes history, physical examination, laboratory testing, and imaging. A more detailed search for underlying causes and evaluation for end-organ damage should be used in children who are at greatest risk of secondary hypertension, including those in younger age groups and those with stage 2 hypertension.7 The initial management of children with confirmed hypertension is directed at identifying and correcting any underlying causes and controlling or monitoring blood pressure. Clinical decisions regarding initiation of therapy depend on the level of blood pressure, presence of end-organ damage, comorbid conditions, and associated risk factors. Lifestyle intervention options including alterations to diet, exercise, and weight loss are recommended as the initial approach in most children. Several classes of drugs are approved for treatment of hypertension in children. Drugs are usually initiated in children with symptomatic hypertension, end-organ damage, stage 1 hypertension that does not respond to nondrug intervention, and stage 2 hypertension.

## Recommendations of Other Groups

Numerous organizations, including the American Heart Association,26 the NHBPEP,6 and the NHBLI's Expert Panel on Integrated Guidelines for Cardiovascular Health and Risk Reduction in Children and Adolescents8 recommend routine screening of asymptomatic children for high blood pressure during office visits beginning at age 3 years, and confirmation with at least two subsequent measures prior to a diagnosis of hypertension.6, 8 The American Academy of Family Physicians contend that there is insufficient evidence for or against routine screening for high blood pressure in children and adolescents.7 The American Academy of Pediatrics does not have a specific policy statement on screening asymptomatic, general-risk children and adolescents for hypertension.