# EVIDENCE AND QUALITY TABLES

Appendix B1 Diagnostic Accuracy of Screening Tests for Elevated Blood Pressure

Appendix B2 Quality Assessment of Diagnostic Accuracy Studies

Appendix B3 Other Studies of Diagnostic Accuracy

Appendix B4 Studies Tracking Hypertension and Other Outcomes From Childhood to Adulthood

Appendix B5 Interventions for Hypertension in Children and Adolescents

Appendix B6 Quality Assessment of Intervention and Harms Studies