# DETAILED METHODS

## Appendix A1 Search Strategies

### Screening

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)
1. Hypertension/ or hypertension.mp.
2. prehypertension.mp.
3. pre-hypertension.mp.
4. 2 or 3
5. high blood pressure.mp.
6. or/1-5
7. Mass Screening/
8. 6 and 7
9. limit 8 to (english language and humans)
10. limit 9 to “all child (0 to 18 years)”
11. 9 and (child$ or pediatri$ or adolescen$ or school-age).mp.
12. 10 or 11

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. Hypertension/ or hypertension.mp.
2. prehypertension.mp.
3. pre-hypertension.mp.
4. 2 or 3
5. high blood pressure.mp.
6. or/1-5
7. Mass Screening/
8. 6 and 7
9. 8 and (child$ or pediatri$ or school or adolescen$ or teen$).mp.

### Diagnostic Accuracy

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)
1. Hypertension/
2. prehypertension.mp. or Prehypertension/
3. 1 or 2
4. Blood Pressure Determination/
5. sensitivity.mp.
6. specificity.mp.
7. 5 and 6
8. “Sensitivity and Specificity”/
9. 7 or 8
10. 3 and 9
11. 4 and 9
12. 10 or 11
13. limit 12 to “all child (0 to 18 years)”

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. Hypertension/
2. prehypertension.mp. or Prehypertension/
3. 1 or 2
4. Blood Pressure Determination/
5. sensitivity.mp.
6. specificity.mp.
7. 5 and 6
8. “Sensitivity and Specificity”/
9. 7 or 8
10. 3 and 9
11. 4 and 9
12. 10 or 11
13. 12 and (child$ or pediatr$ or school or adolescen$ or teen$).mp.

### Tracking

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE
1. “cardiovascular risk in young finns”.mp.
2. “bogalusa heart”.mp.
3. muscatine.mp.
4. (“childhood determinants of adult health” or cdah).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
5. or/1-4
6. 5 and (child$ or pediatric$ or adolescen$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
7. blood pressure.mp. or Blood Pressure/
8. Hypertension/ or hypertension.mp.
9. 7 or 8
10. 9 and (child$ or pediatric$ or adolescen$).mp.
11. 10 and adult$.mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
12. Longitudinal Studies/
13. 11 and 12
14. 6 or 13
15. “Amsterdam Growth and Health Longitudinal Study”.mp.
16. 15 and (child$ or pediatric$ or adolescen$).mp.
17. 14 or 16
18. 17 not pregnancy.mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
19. 17 not infan$.mp. [mp=title, abstract, original title, name of substance word, subject heading word, protocol supplementary concept, rare disease supplementary concept, unique identifier]
20. 18 or 19
21. limit 20 to (english language and humans)
22. Atherosclerosis/
23. Vascular Diseases/
24. Albuminuria/
25. Cerebrovascular Disorders/
26. Hypertrophy, Left Ventricular/
27. Hypertension/
28. or/22-27
29. 21 and 28

### Interventions

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)
1. Hypertension/dh, de, dt, pc, rt, rh, su, th [Diet Therapy, Drug Effects, Drug Therapy, Prevention & Control, Radiotherapy, Rehabilitation, Surgery, Therapy]
2. Weight Loss/
3. Exercise/
4. dietary modification.mp. or Food Habits/
5. Diet, Sodium-Restricted/
6. Angiotensin-Converting Enzyme Inhibitors/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
7. Angiotensin II Type 1 Receptor Blockers/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
8. Labetalol/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
9. Adrenergic beta-Antagonists/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
10. Atenolol/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
11. Bisoprolol/ad, ae, tu [Administration & Dosage, Adverse Effects, Therapeutic Use]
12. Metoprolol/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
13. Propranolol/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
14. Calcium Channel Blockers/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
15. Amlodipine/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
16. Felodipine/ad, ae, tu, to [Administration & Dosage, Adverse Effects, Therapeutic Use, Toxicity]
17. Isradipine/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
18. Nifedipine/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
19. Clonidine/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
20. Diuretics/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
21. Hydrochlorothiazide/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
22. Chlorthalidone/ad, ae, tu, to [Administration & Dosage, Adverse Effects, Therapeutic Use, Toxicity]
23. Furosemide/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
24. Spironolactone/ad, ae, tu, to [Administration & Dosage, Adverse Effects, Therapeutic Use, Toxicity]
25. Triamterene/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity] (
26. Amiloride/ad, ae, tu, to [Administration & Dosage, Adverse Effects, Therapeutic Use, Toxicity]
27. Adrenergic alpha-Antagonists/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
28. Doxazosin/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
29. Prazosin/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
30. Vasodilator Agents/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
31. Hydralazine/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
32. Minoxidil/ad, ae, po, tu [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use]
33. Captopril/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
34. Enalapril/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
35. Fosinopril/ad, ae, tu, to [Administration & Dosage, Adverse Effects, Therapeutic Use, Toxicity]
36. Lisinopril/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
37. Losartan/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
38. (benazepril or quinapril or irbesartan or terazosin).mp.
39. or/2-38
40. Hypertension/
41. 39 and 40
42. 1 or 41
43. limit 42 to (english language and humans)
44. limit 43 to “all child (0 to 18 years)”

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1. Weight Loss/
2. Exercise/
3. dietary modification.mp. or Food Habits/
4. Diet, Sodium-Restricted/
5. Angiotensin-Converting Enzyme Inhibitors/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
6. Angiotensin II Type 1 Receptor Blockers/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
7. Labetalol/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
8. Adrenergic beta-Antagonists/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
9. Atenolol/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
10. Bisoprolol/ad, ae, tu [Administration & Dosage, Adverse Effects, Therapeutic Use]
11. Metoprolol/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
12. Propranolol/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
13. Calcium Channel Blockers/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
14. Amlodipine/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
15. Felodipine/ad, ae, tu, to [Administration & Dosage, Adverse Effects, Therapeutic Use, Toxicity]
16. Isradipine/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
17. Nifedipine/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
18. Clonidine/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
19. Diuretics/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
20. Hydrochlorothiazide/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
21. Chlorthalidone/ad, ae, tu, to [Administration & Dosage, Adverse Effects, Therapeutic Use, Toxicity]
22. Furosemide/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
23. Spironolactone/ad, ae, tu, to [Administration & Dosage, Adverse Effects, Therapeutic Use, Toxicity]
24. Triamterene/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
25. Amiloride/ad, ae, tu, to [Administration & Dosage, Adverse Effects, Therapeutic Use, Toxicity]
26. Adrenergic alpha-Antagonists/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
27. Doxazosin/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
28. Prazosin/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
29. Vasodilator Agents/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
30. Hydralazine/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
31. Minoxidil/ad, ae, po, tu [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use]
32. Captopril/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
33. Enalapril/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
34. Fosinopril/ad, ae, tu, to [Administration & Dosage, Adverse Effects, Therapeutic Use, Toxicity]
35. Lisinopril/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
36. Losartan/ad, ae, po, tu, to [Administration & Dosage, Adverse Effects, Poisoning, Therapeutic Use, Toxicity]
37. (benazepril or quinapril or irbesartan or terazosin).mp.
38. or/1-37
39. Blood Pressure/
40. 38 and 39

### Systematic Reviews

Database: EBM Reviews - Cochrane Database of Systematic Reviews
1. hypertension.ti.
2. blood pressure.ti.
3. 1 or 2
4. 3 and (child$ or pediatri$ or school or adolescen$ or teen$).mp.
5. 4 not (neonat$ or newborn or infan$).ti.
6. 5 not (pregnan$ or postpartum).ti.

## Appendix A2 Inclusion and Exclusion Criteria

| Key Questions | Inclusion Criteria | Exclusion Criteria
Settings | All KQs | Primary care clinics, well-child/adolescent visits, school or community-based screening | Pediatric specialty/subspecialty clinics, inpatient or long-term care settings, emergency or urgent care facilities
Populations | KQs 1, 2 & 4: | Asymptomatic, otherwise healthy children and adolescents, ages 0-18, with no known diagnosis of hypertension | Pregnant adolescents Majority of study population includes secondary hypertension
Populations | KQs 3, 5-8: | Primary hypertension defined as average blood pressure between 95^th^ centile and 5mmHg above the 99^th^ percentile | Pregnant adolescents Majority of study population includes secondary hypertension
Interventions | KQs 1-4: | Blood pressure measurements using auscultatory or oscillometric devices that can be performed in a primary care clinic | 24 hour or ambulatory blood pressure measurements, home-based blood pressure measurements; Diagnostic tests or investigations used to identify or confirm possible causes of secondary hypertension
Interventions | KQs 5-8: | Drug: Antihypertensive medications which are currently FDA-approved for use in children/adolescents Lifestyle: Diet, exercise, etc. | Interventions for treatment of secondary hypertension Interventions where hypertension was not a primary objective of the study (e.g., weight loss studies)
Outcomes | KQs 4, 5 & 6: | Blood pressure Left ventricular hypertrophy (defined using left ventricular mass index and/or measures of left ventricular geometry) Urinary albumin excretion (microalbuminuria) Intima-medial thickness (measured at carotid and/or femoral arteries) Retinal vascular changes | Measures of cognitive function Blood pressure variability, such as diurnal variations, or nocturnal blood pressure dipping Arterial wall dysfunction, including measures of arterial stiffness, pulse wave velocity, augmentation index Metabolic measures, namely glucose tolerance or other measures of impaired glucose tolerance, insulin levels, lipid profiles, homocysteine levels Uric acid levels Inflammatory markers including C-reactive protein Changes in weight or body mass index
Outcomes | KQs 1 & 7: | Severe visual impairment Stage IV or V chronic kidney disease Cardiovascular events, including ischemic heart disease, heart failure Cerebrovascular events, including haemorrhagic and thrombotic stroke, hypertensive encephalopathy Mortality (all-cause and disease-specific) | -
Outcomes | KQ 2 | Measures of predictive validity of screening studies (e.g., predictive value, likelihood ratios, sensitivity, specificity) | Studies that do not provide enough data to recreate 2 × 2 tables or calculate sensitivity and specificity Studies that do not employ a true reference standard for comparison
Outcomes | KQ 3 | Measures of association (e.g., odds, odds ratio; risk ratio, sensitivity, specificity, correlation or regression coefficients) | -
Outcomes | KQ 8 | Side effects of hypertension treatments for interventions | -
Study Designs | KQ 1 | RCTs, controlled clinical trials, observational studies with a comparison group (e.g., comparative cohort and case-control studies), and systematic reviews | -
Study Designs | KQ 2 | Studies of predictive validity that compare to a reference standard (i.e., ambulatory monitoring) | -
Study Designs | KQ 3 | Longitudinal cohort and epidemiology studies | -
Study Designs | KQs 4 & 8 | RCTs, controlled clinical trials, observational studies with a comparison group (e.g., large cohort and case-control studies), and systematic reviews. If none, uncontrolled before-after studies | -
Study Designs | KQs 5, 6, 7 | RCTs, controlled clinical trials, observational studies with a comparison group (e.g., large cohort and case-control studies), and systematic reviews | -

KQ = key question.

## Appendix A3 Literature Flow Diagram

* Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

† Other sources include reference lists, suggested by peer reviewers, etc.

‡ Some articles are included for more than one Key Question.

§ Twelve of these studies did not provide enough data to recreate 2 × 2 tables or calculate sensitivity and specificity.

FDA = United States Food and Drug Administration; RCT = randomized controlled trial.

This figure is a flow chart that summarizes the search and selection of articles. Abstracts of potentially relevant articles were identified through bibliographic databases, including MEDLINE, the Cochrane Central Register of Controlled Trials, and the Cochrane Database of Systematic Reviews, as well as through other sources, including expert reviewers and reference lists. There were 6,435 abstracts of potentially relevant articles reviewed. After excluding 5,376 abstracts and articles that were not relevant to the key questions, 1,059 full-text articles were retrieved for further review. A total of 1,024 full-text articles were excluded for the following reasons: wrong population, including secondary hypertension, adults only, etc. (550 articles); wrong intervention (22 articles); wrong outcome (122 articles); wrong study design for key question (38 articles); systematic review, not directly used (3 articles); no original data (215 articles); not English language (2 articles); inadequate duration (23 articles); sample size too small (30 participants or less) (19 articles); and no or inadequate reference standard (30 articles). For the last category, 12 of these studies did not provide enough data to recreate 2 × 2 tables or calculate sensitivity and specificity. Thirty-four unique studies, in 35 publications, were included in the review. Note that some articles were included for more than one key question. For Key Question 1, no studies were included. For Key Question 2, 2 trials were included. For Key Question 3, 10 cohort studies were included. For Key Question 4, 1 study was included. For Key Question 5, 14 randomized, controlled trials in 15 publications were included. For Key Question 6, no studies were included. For Key Question 7, no studies were included. For Key Question 8, 13 trials and 2 FDA analyses were included.

## Appendix A4 Excluded Studies

### Wrong Population

Abbey LM. Screening for hypertension in the dental office. J Am Dent Assoc. 1974;88(3):563-7. [pmid: 4521264].
Acker CG, Greenberg A. Angioedema Induced by the Angiotensin II Blocker Losartan. N Engl J Med. 1995;333(23):1572. [pmid: 7477189].
Adeniran SA, Toriola AL. Effects of different running programmes on body fat and blood pressure in schoolboys aged 13-17 years. J Sports Med Phys Fitness. 1988;28:267-73. [pmid: 3068419].
Adler S. Methyldopa-Induced Decrease in Mental Activity. JAMA. 1974;230(10):1428-9. [pmid: 4479647].
Adolphe AB, Vlachakis ND, Rofman BA, Brescia D, Zellner SR. Long-term open evaluation of amlodipine vs hydrochlorothiazide in patients with essential hypertension. Int J Clin Pharmacol Res. 1993;13(4):203-10. [pmid: 8150546].
Agents VACSGoA. Effects Morbidity of Treatment on in Hypertension. JAMA. 1970;213(7):1143-52. PMID: N/A. [pmid: 4914579].
Agnoletti G, Bonnet C, Bonnet D, Sidi D, Aggoun Y. Mid-term effects of implanting stents for relief of aortic recoarctation on systemic hypertension, carotid mechanical properties, intimal medial thickness and reflection of the pulse wave. Cardiol Young. 2005;15(3):245-50. [pmid: 15865825].
Akbartabartoori M, Lean MEJ, Hankey CR. The associations between current recommendation for physical activity and cardiovascular risks associated with obesity. Eur J Clin Nutr. 2008;62(1):1-9. [pmid: 17342166].
Alagappan A, Malloy MH. Systemic hypertension in very low-birth weight infants with bronchopulmonary dysplasia: incidence and risk factors. Am J Perinatol. 1998;15(1):3-8. [pmid: 9475679].
Alcocer L, Novoa G, Sotres D. Quinapril in the treatment of hypertension in primary care centers. Clin Ther. 1993;15(6):1021-30. [pmid: 8111799].
Alderman MH, Cohen H, Madhavan S. Diabetes and cardiovascular events in hypertensive patients. Hypertension. 1999;33(5):1130-4. [pmid: 10334799].
Ambrosio GB, Dissegna L, Zamboni S, Santonastaso P, Canton G, Dal Palù C. Psychological effects of hypertension labelling during a community survey. A two-year follow-up. J Hypertens Suppl. 1984;2(3):s171-3. [pmid: 6599664].
Ameling EH, de Korte DF, Man 't Veld AJi. Impact of Diagnosis and Treatment of Hypertension on Quality of Life: A Double-Blind, Randomized, Placebo-Controlled, Cross-Over Study of Betaxolol. J Cardiovasc Pharmacol. 1991;18(5):752-60. [pmid: 1723773].
Anderson JW, Liu C, Kryscio RJ. Blood pressure response to transcendental meditation: a meta-analysis. Am J Hypertens. 2008;21(3):310-6. [pmid: 18311126].
Anderson MW, deShazo RD. Studies of the mechanism of angiotensin-converting enzyme (ACE) inhibitor-associated angioedema: The effect of an ACE inhibitor on cutaneous responses to bradykinin, codeine, and histamine. J Allergy Clin Immunol. 1990;85(5):856-8. [pmid: 2185292].
Andrejak M, Santoni JP, Carre A, Deruyttere M, Magometschnigg D, Gotzen R, et al. A double-blind comparison of perindopril and hydrochlorothiazide-amiloride in mild to moderate essential hypertension. Fundam Clin Pharmacol. 1991;5(3):185-92. [pmid: 1682228].
Ardissino G, Daccò V, Testa S, Bonaudo R, Claris-Appiani A, Taioli E, et al. Epidemiology of Chronic Renal Failure in Children: Data From the ItalKid Project. Pediatrics. 2003;111(4):e382-e7. [pmid: 12671156].
Arguedas JA, Perez MI, Wright JM. Treatment blood pressure targets for hypertension. Cochrane Database of Systematic Reviews. 2009;(1). [pmid: 19588353].
Asmar RG, London GM, O'Rourke ME, Safar ME, Coordinators RP. Investigators. Improvement in blood pressure, arterial stiffness and wave reflections with a very-low-dose perindopril/indapamide combination in hypertensive patient: a comparison with atenolol. Hypertension. 2001;38(4):922-6. [pmid: 11641310].
Austen KF. Disorders of immune-mediated therapy. Isselbacher KJ, Braunwald E, Wilson JD, Martin JB, Fauci AS, Kasper DL, editors. Harrison's principles of internal medicine. 13th ed. New York. McGraw-Hill. 1994:1630-8. PMID: N/A.
Baeiulis V. Antiproteinuric effect of verapamil in children with glomerulonephritis. Pediatr Nephrol. 2000;14:C 64. PMID: N/A.
Bagga A, Mudigoudar BD, Hari P, Vasudev V. Enalapril dosage in steroid-resistant nephrotic syndrome. Pediatr Nephrol. 2004;19(1):45-50. [pmid: 14648339].
Bagga OP, Gandhi A. A comparative study of the effect of Transcendental Meditation (T.M.) and Shavasana practice on cardiovascular system. Indian Heart J. 1983;35(1):39-45. [pmid: 6343229].
Bakker R, Rifas-Shiman SL, Kleinman KP, Lipshultz SE, Gillman MW. Maternal calcium intake during pregnancy and blood pressure in the offspring at age 3 years: a follow-up analysis of the Project Viva cohort. Am J Epidemiol. 2008;168(12):1374-80. [pmid: 18945693].
Bald M, Holder M, Zieger M, Vochem M, Leichter HE. Increased renal echogenicity in a preterm neonate. Kidneys with tubular dysplasia due to exposure to candesartan during pregnancy. Pediatr Nephrol. 2005;20(11):1664-5. 6. 8. [pmid: 16082550].
Barnes VA, Davis HC, Murzynowski JB, Treiber FA. Impact of meditation on resting and ambulatory blood pressure and heart rate in youth. Psychosom Med. 2004;66(6):909-14. [pmid: 15564357].
Barnes VA, Treiber FA, Davis H. Impact of Transcendental Meditation® on cardiovascular function at rest and during acute stress in adolescents with high normal blood pressure. J Psychosom Res. 2001;51(4):597-605. [pmid: 11595248].
Barnes VA, Treiber FA, Johnson MH. Impact of transcendental meditation on ambulatory blood pressure in African-American adolescents. Am J Hypertens. 2004;17(4):366-9. [pmid: 15062892].
Bateman DN, Dean CR, Mucklow JC, Bulpitt CJ, Dollery CT. Atenolol and chlorthalidone in combination for hypertension. Br J Clin Pharmacol. 1979;7(4):357-63. [pmid: 375958].
Becque MD, Katch VL, Rocchini AP, Marks CR, Moorehead C. Coronary Risk Incidence of Obese Adolescents: Reduction by Exercise Plus Diet Intervention. Pediatrics. 1988;81(5):605. [pmid: 3357722].
Bell GM, Fananapazir L, Anderton JL. Comparison of single and divided daily dose spironolactone in the control of hypertension. Br J Clin Pharmacol. 1981;12(4):585-8. [pmid: 7295494].
Ben-Dov IZ, Kark JD, Mekler J, Shaked E, Bursztyn M. The white coat phenomenon is benign in referred treated patients: a 14-year ambulatory blood pressure mortality study. J Hypertens. 2008;26(4):699-705. [pmid: 18327079].
Benz J, Oshrain C, Henry D, Avery C, Chiang Y, Gatlin M. Valsartan, a new angiotensin II receptor antagonist: a double-blind study comparing the incidence of cough with lisinopril and hydrochlorothiazide. J Clin Pharmacol. 1997;37(2):101-7. [pmid: 9055135].
Bergbrant A, Hansson L, Jern S. Correspondence between screening and intra-arterial blood pressures in young men with borderline hypertension. J Intern Med. 1993;234(2):201-9. [pmid: 8340744].
Bergendahl HT, Eksborg S, Lonnqvist PA. Low-dose intravenous clonidine in children: plasma concentrations and haemodynamic response. Acta Anaesthesiol Scand. 1997;41(3):381-4. [pmid: 9113184].
Berkowitz RI, Fujioka K, Daniels SR, Hoppin AG, Owen S, Perry AC, et al. Effects of sibutramine treatment in obese adolescents: a randomized trial. [Summary for patients in Ann Intern Med. 2006;145(2):I16; PMID: 16847286]. Ann Intern Med. 2006;145(2):81-90. [pmid: 16847290].
Berkowitz RI, Wadden TA, Tershakovec AM, Cronquist JL. Behavior therapy and sibutramine for the treatment of adolescent obesity: a randomized controlled trial. JAMA. 2003;289(14):1805-12. [pmid: 12684359].
Bernink PJ, Prager G, Schelling A, Kobrin I. Antihypertensive properties of the novel calcium antagonist mibefradil (Ro 40-5967): a new generation of calcium antagonists? Mibefradil International Study Group. Hypertension. 1996;27(3 Pt 1):426-32. [pmid: 8698449].
Bianchetti M, Ammenti A, Avolio L, Bettinelli A, Bosio M, Fossali E, et al. Prescription of drugs blocking the renin-angiotensin system in Italian children. Pediatr Nephrol. 2007;22(1):144-8. [pmid: 17089178].
Bifano E, Post EM, Springer J, Williams ML, Streeten DH. Treatment of neonatal hypertension with Captopril. J Pediatr. 1982;100(1):143-6. [pmid: 7035633].
Black HR, Graff A, Shute D, Stoltz R, Ruff D, Levine J, et al. Valsartan, a new angiotensin II antagonist for the treatment of essential hypertension: efficacy, tolerability and safety compared to an angiotensin-converting enzyme inhibitor, lisinopril. J Hum Hypertens. 1997;11(8):483-9. [pmid: 9322828].
Blessing DL, Keith RE, Williford HN. Blood lipid and physiological responses to endurance training in adolescents. Pediatr Exerc Sci. 1995;7:192-202. PMID: N/A.
Bobby JJ, Emami JM, Farmer RD, Newman CG. Operative survival and 40 year follow up of surgical repair of aortic coarctation. Br Heart J. 1991;65(5):271-6. [pmid: 2039672].
Bohm M, Reil JC, Danchin N, Thoenes M, Bramlage P, Volpe M. Association of heart rate with microalbuminuria in cardiovascular risk patients: data from I-SEARCH. J Hypertens. 2008;26(1):18-25. [pmid: 18090536].
Bolbrinker J, Huber M, Scholze J, Kreutz R. Pharmacokinetics and safety of olmesartan medoxomil in combination with either amlodipine or atenolol compared to respective monotherapies in healthy subjects. Fundam Clin Pharmacol. 2009;23(6):767-74. [pmid: 19659504].
Borghi C, Dormi A, Ambrosioni E, Gaddi A, Brisighella Heart Study working p. Relative role of systolic, diastolic and pulse pressure as risk factors for cardiovascular events in the Brisighella Heart Study. J Hypertens. 2002;20(9):1737-42. [pmid: 12195113].
Borghi C, Dormi A, L'Italien G, Lapuerta P, Franklin SS, Collatina S, et al. The relationship between systolic blood pressure and cardiovascular risk--results of the Brisighella Heart Study. J Clin Hypertens. 2003;5(1):47-52. [pmid: 12556653].
Borghi C, Dormi A, Veronesi M, Sangiorgi Z, Gaddi A, Brisighella Heart Study Working P. Association between different lipid-lowering treatment strategies and blood pressure control in the Brisighella Heart Study. Am Heart J. 2004;148(2):285-92. [pmid: 15308998].
Borzova NV, Gorbachenkov AA. Regression of left ventricular hypertrophy and improvement of its diastolic function in patients with arterial hypertension under influence of antihypertensive therapy. Kardiologiia. 2008;48(6):44-50. CN-00650768. [pmid: 18729836].
Bos-Thompson MA, Hillaire-Buys D, Muller F, Dechaud H, Mazurier E, Boulot P, et al. Fetal toxic effects of angiotensin II receptor antagonists: case report and follow-up after birth. Ann Pharmacother. 2005;39(1):157-61. [pmid: 15590878].
Bouchireb K, Boyer O, Bonnet D, Brunelle F, Decramer S, Landthaler G, et al. Clinical features and management of arterial hypertension in children with Williams-Beuren syndrome. Nephrol Dial Transplant. 2010;25(2):434-8. [pmid: 19815602].
Boutouyrie P, Achouba A, Trunet P, Laurent S, Group ET. Amlodipine-valsartan combination decreases central systolic blood pressure more effectively than the amlodipine-atenolol combination: the EXPLOR study. Hypertension. 2010;55(6):1314-22. [pmid: 20404219].
Bovet P, Chiolero A, Madeleine G, Gabriel A, Stettler N. Marked increase in the prevalence of obesity in children of the Seychelles, a rapidly developing country, between 1998 and 2004. Int J Pediatr Obes. 2006;1(2):120-8. [pmid: 17907325].
Bramlage P, Pittrow D, Lehnert H, Hofler M, Kirch W, Ritz E, et al. Frequency of albuminuria in primary care: a cross-sectional study. Eur J Cardiovasc Prev Rehabil. 2007;14(1):107-13. [pmid: 17301635].
Breckenridge A, Preger L, Dollery CT, Laws JW. Hypertension in the young. Q J Med. 1967;36(144):549-63. [pmid: 6077231].
Briggs G, Nageotte M. Fatal fetal outcome with the combined use of valsartan and atenolol. Ann Pharmacother. 2001;35(7):859-61. [pmid: 11485133].
Brosnan CA, Upchurch SL, Meininger JC, Hester LE, Johnson G, Eissa MA. Student nurses participate in public health research and practice through a school-based screening program. Public Health Nurs. 2005;22(3):260-6. [pmid: 15982200].
Brown NJ, Nadeau JH. Does Race Predispose to Angiotensin-Associated Angioneurotic Edema?. Ann Intern Med. 1993;119(12):1224. [pmid: 8239260].
Brown NJ, Ray WA, Snowden M, Griffin MR. Black Americans have an increased rate of angiotensin converting enzyme inhibitor-associated angioedema. Clin Pharmacol Ther. 1996;60(1):8-13. [pmid: 8689816].
Brunet P, Jaber K, Berland Y, Baz M. Anaphylactoid reactions during hemodialysis and hemofiltration: role of associating AN69 membrane and angiotensin I-converting enzyme inhibitors. Am J Kidney Dis. 1992;19(5):444-7. [pmid: 1585932].
Bryant JG, Garett HL, Dean MS. Coronary heart disease: the beneficial effects of exercise to children. J La State Med Soc. 1984;136(5):15-7. [pmid: 6563052].
Budd GM, Hayman LL, Crump E, Pollydore C, Hawley KD, Cronquist JL, et al. Weight Loss in Obese African American and Caucasian Adolescents: Secondary Analysis of a Randomized Clinical Trial of Behavioral Therapy Plus Sibutramine. J Cardiovasc Nurs. 2007;22(4):288-96. [pmid: 17589281].
Buranakitjaroen P, Phoojaroenchanachai M, Saravich S. Hypertension study among attendants at the Board of Investment Fair 2000. J Med Assoc Thai. 2006;89(5). [pmid: 17718244].
Burgess E, Muirhead N, de Cotret PR, Chiu A, Pichette V, Tobe S, et al. Supramaximal Dose of Candesartan in Proteinuric Renal Disease. J Am Soc Nephrol. 2009;20(4):893-900. [pmid: 19211712].
Burris JF, Allenby KS, Mroczek WJ. The effect of amlodipine on ambulatory blood pressure in hypertensive patients. Am J Cardiol. 1994;73(3):39A-43A. [pmid: 8310975].
Burris JF, Ames RP, Applegate WB, Ram CV, Davidov ME, Mroczek WJ. Double-blind comparison of amlodipine and hydrochlorothiazide in patients with mild to moderate hypertension. J Cardiovasc Pharmacol. 1988;12(7). [pmid: 2467140].
Caballero R, Pirmohamed R, Wright JA. Use of alpha-methyl-tyrosine for refractory hypertension in a child with neuroblastoma. Crit Care Med. 1992;20(7):1060-2. [pmid: 1352196].
Cade R, Mars D, Wagemaker H, Zauner C, Packer D, Privette M, et al. Effect of aerobic exercise training on patients with systemic arterial hypertension. Am J Med. 1984;77(5):785-90. [pmid: 6496532].
Cadnapaphornchai MA, Fick-Brosnahan GM, Duley I, Johnson AM, Strain JD, DeGroff CG, et al. Design and baseline characteristics of participants in the study of antihypertensive therapy in children and adolescents with autosomal dominant polycystic kidney disease (ADPKD). Contemporary clinical trials. 2005;26(2):211-22. [pmid: 15837441].
Cadnapaphornchai MA, McFann K, Strain JD, Masoumi A, Schrier RW. Prospective change in renal volume and function in children with ADPKD. Clin J Am Soc Nephrol. 2009;4(4):820-9. [pmid: 19346430].
Calabrese EJ, Tuthill RW. The Massachusetts blood pressure study, part 3. Experimental reduction of sodium in drinking water: effect on blood pressure. Toxicol Ind Health. 1985;1(1):19-34. [pmid: 3842544].
Callis L, Vila A, Castellanos J, Gras X. Long-term treatment with captopril in paediatric patients with severe hypertension and chronic renal failure. Postgrad Med J. Suppl 1. 1986;62:106-7. [pmid: 3317336].
Carr JA, Amato JJ, Higgins RSD. Long-term results of surgical coarctectomy in the adolescent and young adult with 18-year follow-up. Ann Thorac Surg. 2005;79(6):1950-5. discussion 5-6. [pmid: 15919290].
Carre A, Zannad F, Vasmant D. The French multicentre study of ramipril in ambulatory patients with mild-to-moderate hypertension. Clin Physiol Biochem. 1992;9(3):105-12. [pmid: 1302160].
Carroll J, Shamiss A, Zevin D, Levi J, Rosenthal T. Twenty-four-hour blood pressure monitoring during treatment with extended-release felodipine versus slow-release nifedipine: cross-over study. J Cardiovasc Pharmacol. 1995;26(6):974-7. [pmid: 8606536].
Casiglia E, Mazza A, Tikhonoff V, Basso G, Martini B, Scarpa R, et al. Therapeutic profile of manidipine and lercanidipine in hypertensive patients. Adv Ther. 2004;21(6):357-69. [pmid: 15856859].
Chamontin B, Amar J, Barthe P, Salvador M. Blood pressure measurements and left ventricular mass in young adults with arterial hypertension screened at high school check-up. J Hum Hypertens. 1994;8(5):357-61. [pmid: 8064783].
Chandar J, Abitbol C, Montané B, Zilleruelo G. Angiotensin blockade as sole treatment for proteinuric kidney disease in children. Nephrol Dial Transplant. 2007;22(5):1332-7. [pmid: 17299000].
Chanoine JP, Hampl S, Jensen C, Boldrin M, Hauptman J. Effect of orlistat on weight and body composition in obese adolescents: a randomized controlled trial. [Erratum appears in JAMA. 2005;294(12):1491]. JAMA. 2005;293(23):2873-83. [pmid: 15956632].
Charlon V, Dollow S, Fidel J, Hoglund C, Honkanen T, Kobrin I, et al. Reproducibility of angiotensin converting enzyme inhibitor induced cough. A double-blind randomised study. Br J Clin Pharmacol. 1995;39(2):125-9. [pmid: 7742149].
Charlson ME, Alderman M, Melcher L. Absenteeism and labelling in hypertensive subjects: Prevention of an adverse impact in those at high risk. Am J Med. 1982;73(2):165-70. [pmid: 7114071].
Cheraskin E, Ringsdorf WM Jr., Barrett RA. The Birmingham (Alabama) 1964 diabetes detection drive. VI. Frequency of reported hypertension. Ala J Med Sci. 1968;5(2):225-7. [pmid: 5675832].
Cherney D, Straus S. Management of Patients With Hypertensive Urgencies and Emergencies. J Gen Intern Med. 2002;17(12):937-45. [pmid: 12472930].
Chevalier RL. Developmental Renal Physiology of the Low Birth Weight Pre-Term Newborn. J Urol. 1996;156(2, Supplement 1):714-9. [pmid: 8683767].
Chobanian AV, Bakris GL, Black HR, Cushman WC, Green LA, Izzo JL Jr, et al. Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation and Treatment of High Blood Pressure. Hypertension. 2003;42(6):1206-52. [pmid: 14656957].
Christofaro DG, Fernandes RA, Polito MD, Romanzini M, Ronque ER, Gobbo LA, et al. A comparison between overweight cutoff points for detection of high blood pressure in adolescents. J Pediatr. 2009;85(4):353-8. [pmid: 19668911].
Chung KF, Lalloo UG. Diagnosis and management of chronic persistent dry cough. Postgrad Med J. 1996;72(852):594-8. [pmid: 8977940].
Clementy J, Schwebig A, Mazaud C, Justal A, Bricaud H. Comparative study of the efficacy and tolerance of capozide and moduretic administered in a single daily dose for the treatment of chronic moderate arterial hypertension. Postgrad Med J. 1986;62(1):132-4. [pmid: 3534848].
Cléroux J, Péronnet F, de Champlain J. Effects of exercise training on plasma catecholamines and blood pressure in labile hypertensive subjects. Eur J Appl Physiol. 1987;56(5):550-4. [pmid: 3653096].
Cocco G, Ettlin T, Baumeler HR. The effect of amlodipine and enalapril on blood pressure and neurohumoral activation in hypertensive patients with Ribbing's disease (multiple epiphysal dystrophy). Clin Cardiol. 2000;23(2):109-14. [pmid: 10676602].
Collins R, Peto R, MacMahon S, Hebert P, Fiebach NH, Eberlein KA, et al. Blood pressure, stroke, and coronary heart disease. Part 2, Short-term reductions in blood pressure: overview of randomised drug trials in their epidemiological context. Lancet. 1990;335(8693):827-38. [pmid: 1969567].
Cooper R, Van Horn L, Liu K, Trevisan M, Nanas S, Ueshima H, et al. A randomized trial on the effect of decreased dietary sodium intake on blood pressure in adolescents. J Hypertens. 1984;2(4):361-6. [pmid: 6530546].
Costa FV, Ambrosioni E, Montebugnoli L, Paccaloni L, Vasconi L, Magnani B. Effects of a low-salt diet and of acute salt loading on blood pressure and intralymphocytic sodium concentration in young subjects with borderline hypertension. Clin Sci. Suppl 7. 1981;61:21s-3s. [pmid: 7032811].
Cottier C, Shapiro K, Julius S. Treatment of mild hypertension with progressive muscle relaxation. Predictive value of indexes of sympathetic tone. Arch Intern Med. 1984;144(10):1954-8. [pmid: 6385893].
Cox RM, Anderson JM, Cox P. Defective embryogenesis with angiotensin II receptor antagonists in pregnancy. BJOG. 2003;110(11):1038-40. [pmid: 14592593].
Crowther JH. Stress management training and relaxation imagery in the treatment of essential hypertension. J Behav Med. 1983;6(2):169-87. [pmid: 6352951].
Curtis Ellison R, Capper AL, Stephenson WP, Goldberg RJ, Hosmer DW, Humphrey KF, et al. Effects on blood pressure of a decrease in sodium use in institutional food preparation: The exeter-andover project. J Clin Epidemiol. 1989;42(3):201-8. [pmid: 2709080].
Czaczkes WJ, Steinwell A, Popvtzer MM. Selective screening for occult renal diseases and hypertension. Isr J Med Sci. 1981;17(4):292-4. [pmid: 7239877].
Daae LN, Westlie L. A 5-year comparison of doxazosin and atenolol in patients with mild-to-moderate hypertension: effects on blood pressure, serum lipids, and coronary heart disease risk. Blood Press. 1998;7(1):39-45. [pmid: 9551876].
Daniels SR, Long B, Crow S, Styne D, Sothern M, Vargas-Rodriguez I, et al. Cardiovascular Effects of Sibutramine in the Treatment of Obese Adolescents: Results of a Randomized, Double-Blind, Placebo-Controlled Study. Pediatrics. 2007;120(1):e147-e57. [pmid: 17576783].
De Caro E, Spadoni I, Crepaz R, Saitta M, Trocchio G, Calevo MG, et al. Stenting of aortic coarctation and exercise-induced hypertension in the young. [Erratum appears in Catheter Cardiovasc Interv. 2010;75(7):1143 Note: Mg, Calevo [corrected to Calevo, Maria Grazia]]. Catheter Cardiovasc Interv. 2010;75(2):256-61. [pmid: 20095012].
De Caro E, Trocchio G, Smeraldi A, Calevo MG, Pongiglione G. Aortic arch geometry and exercise-induced hypertension in aortic coarctation. Am J Cardiol. 2007;99(9):1284-7. [pmid: 17478158].
De Silva DG, Fernando AJ, Law F, Jayantha UK. Experience with sublingual nifedipine in paediatric hypertensive emergencies. Ceylon Med J. 1995;40(4):166-7. [pmid: 8689712].
Delucchi A, Cano F, Rodriguez E, Wolff E, Gonzalez X, Cumsille MA. Enalapril and prednisone in children with nephrotic-range proteinuria. Pediatr Nephrol. 2000;14(12):1088-91. [pmid: 11045392].
Denzer C, Reithofer E, Wabitsch M, Widhalm K. The outcome of childhood obesity management depends highly upon patient compliance. Eur J Pediatr. 2004;163(2):99-104. [pmid: 14691718].
Diehl KL, Wernze H. Angioneurotic edema caused by angiotensin-converting enzyme inhibitors. Dtsch Med Wochenschr. 1992;117(19):727-32. [pmid: 1315673].
Dieterle T, Battegay E, Bucheli B, Martina B. Accuracy and ‘range of uncertainty’ of oscillometric blood pressure monitors around the upper arm and the wrist. Blood Press Monit. 1998;3(6):339-46. [pmid: 10212375].
Dilmen U, Caglar MK, Senses DA, Kinik E. Nifedipine in hypertensive emergencies of children. Am J Dis Child. 1983;137(12):1162-5. [pmid: 6637932].
Dluhy RG, Anderson B, Harlin B, Ingelfinger J, Lifton R. Glucocorticoid-remediable aldosteronism is associated with severe hypertension in early childhood. J Pediatr. 2001;138(5):715-20. [pmid: 11343049].
Donati-Genet P, Bianchetti MG. Modulators on the renin-angiotensin-aldosterone system and cough in childhood. Pediatr Nephrol. 1996;10:545-6. [pmid: 8865265].
Dorst KG, Kordes M, Vetter H, Losse H. Sodium restriction in young people. Report of an interventive study. Die Medizinische Welt. 1982;33(25):943. [pmid: 7109948].
Dossing M, Kelstrup L, Hilden T. The social and psychological consequences of being long-term treated for moderate and severe hypertension. Acta Medica Scandinavica - Supplementum. 1979;626:58-60. [pmid: 285598].
Doyle DB, Lauterbach W, Samargo P, Robinson C, Ludwig W. Age- and sex-biased underdetection of hypertension in a rural clinic. Fam Pract Res J. 1991;11(4):395-404. [pmid: 1767686].
Duncan DE, Scott RB, Castro O. A mobile unit as an adjunct to a community outreach program of education, screening, and counseling for sickle cell disease, nutritional anemia, and hypertension. J Natl Med Assoc. 1982;74(10):969-77. [pmid: 7143470].
Duncan JJ, Farr JE, Upton SJ, Hagan RD, Oglesby ME, Blair SN. The Effects of Aerobic Exercise on Plasma Catecholamines and Blood Pressure in Patients With Mild Essential Hypertension. JAMA. 1985;254(18):2609-13. [pmid: 4057469].
Efstratopoulos AD, Meikopoulos M, Voyaki S. Frequency of cough during therapy with ACE inhibitors in Greek hypertensives. J Hum Hypertens. 1993;7(6):607-9. [pmid: 8114058].
Eicken A, Pensl U, Sebening W, Hager A, Genz T, Schreiber C, et al. The fate of systemic blood pressure in patients after effectively stented coarctation. Eur Heart J. 2006;27(9):1100-5. [pmid: 16434415].
Ejima Y, Hasegawa Y, Sanada S, Miyama N, Hatano R, Arata T, et al. Characteristics of young-onset hypertension identified by targeted screening performed at a university health check-up. Hypertension Research Clinical & Experimental. 2006;29(4):261-7. [pmid: 16778333].
Elkasabany AM, Urbina EM, Daniels SR, Berenson GS. Prediction of adult hypertension by K4 and K5 diastolic blood pressure in children: the Bogalusa Heart Study. J Pediatr. 1998;132(4):687-92. [pmid: 9580771].
Elliott WJ. Higher incidence of discontinuation of angiotensin converting enzyme inhibitors due to cough in black subjects. Clin Pharmacol Ther. 1996;60(5):582-8. [pmid: 8941032].
Ellis D, Moritz ML, Vats A, Janosky JE. Antihypertensive and renoprotective efficacy and safety of losartan. A long-term study in children with renal disorders. Am J Hypertens. 2004;17(10):928-35. [pmid: 15485756].
Ellis D, Vats A, Moritz ML, Reitz S, Grosso MJ, Janosky JE. Long-term antiproteinuric and renoprotective efficacy and safety of losartan in children with proteinuria. J Pediatr. 2003;143(1):89-97. [pmid: 12915830].
Erlingsdottir A, Indridason OS, Thorvaldsson O, Edvardsson VO. Blood pressure in children and target-organ damage later in life. Pediatr Nephrol. 2010;25(2):323-8. [pmid: 19946710].
Evans JH, Shaw NJ, Brocklebank JT. Sublingual nifedipine in acute severe hypertension. Arch Dis Child. 1988;63(8):975-7. [pmid: 3270332].
Ewart CK, Young DR, Hagberg JM. Effects of school-based aerobic exercise on blood pressure in adolescent girls at risk for hypertension. Am J Public Health. 1998;88(6):949-51. [pmid: 9618627].
Faigenbaum AD, Zaichkowsky LD, Westcott WL. The effects of twice-a-week strength training program on children. Pediatr Exerc Sci. 1993;5:339-46. PMID: N/A.
Farpour-Lambert NJ, Aggoun Y, Marchand LM, Martin XE, Herrmann FR, Beghetti M. Physical activity reduces systemic blood pressure and improves early markers of atherosclerosis in pre-pubertal obese children. J Am Coll Cardiol. 2009;54(25):2396-406. [pmid: 20082930].
Farsang C, Kapocsi J, Kiss I, Torok E, Kerkovits G, Hollo J, et al. Hungarian Isradipine Study (HIS): long-term (3-year) effects on blood pressure and plasma lipids. Am J Hypertens. 1994;7(7 Pt 2):56S-60S. [pmid: 7946181].
Florin AA, Harkness JP, Collins JG, Burton MH. Heart screening in the Newark Model Cities area: a feasibility study. Am J Public Health. 1971;61(6):1130-9. [pmid: 4258628].
Flynn JT, Meyers KE, Neto JP, de Paula Meneses R, Zurowska A, Bagga A, et al. Efficacy and safety of the Angiotensin receptor blocker valsartan in children with hypertension aged 1 to 5 years. Hypertension. 2008;52(2):222-8. [pmid: 18591457].
Flynn JT, Smoyer WE, Bunchman TE. Treatment of hypertensive children with amlodipine. Am J Hypertens. 2000;13(10):1061-6. [pmid: 11041159].
Flynn JT, Warnick SJ. Isradipine treatment of hypertension in children: a single-center experience. Pediatr Nephrol. 2002;17(9):748-53. [pmid: 12215829].
Flynn JT. Efficacy and safety of prolonged amlodipine treatment in hypertensive children. Pediatr Nephrol. 2005;20(5):631-5. [pmid: 15785942].
Flynn JT. Impact of ambulatory blood pressure monitoring on the management of hypertension in children. Blood Press Monit. 2000;5(4):211-6. [pmid: 11035862].
Foerster EC, Greminger P, Siegenthaler W, Vetter H, Vetter W. Atenolol versus pindolol: side-effects in hypertension. Eur J Clin Pharmacol. 1985;28:89-91. [pmid: 4054195].
Fogari R, Zoppi A, Tettamanti F, Malamani GD, Tinelli C, Salvetti A. Effects of nifedipine and indomethacin on cough induced by angiotensin-converting enzyme inhibitors: a double-blind, randomized, cross-over study. J Cardiovasc Pharmacol. 1992;19(5):670-3. [pmid: 1381763].
Forfang K, Rostad H, Sørland S. Coarctation of the aorta. Follow-up of 218 patients operated on after 13 years of age. Acta Medica Scandinavica - Supplementum. 1981;645:15-22. [pmid: 6940420].
Fossum E, Hoieggen A, Reims HM, Moan A, Rostrup M, Eide I, et al. High screening blood pressure is related to sympathetic nervous system activity and insulin resistance in healthy young men. Blood Press. 2004;13(2):89-94. [pmid: 15182111].
Fox AJ, Lalloo UG, Belvisi MG, Bernareggi M, Chung KF, Barnes PJ. Bradykinin-evoked sensitization of airway sensory nerves: A mechanism for ACE-inhibitor cough. Nat Med. 1996;2(7):814-7. [pmid: 8673930].
Fox E, Taylor H, Andrew M, Han H, Mohamed E, Garrison R, et al. Body mass index and blood pressure influences on left ventricular mass and geometry in African Americans: The Atherosclerotic Risk In Communities (ARIC) Study. Hypertension. 2004;44(1):55-60. [pmid: 15184348].
Franco RJ, Sampaio M, Balbi AL, Martin LC, Luna RL. An open comparative study of captopril + hydrochlorothiazide versus chlorthalidone for the treatment of mild and moderate primary hypertension. Arq Bras Cardiol. 1992;59(5):423-7. [pmid: 1340743].
Franscini LMD, Von Vigier RO, Pfister R, Casaulta-Aebischer C, Fossali E, Bianchetti MG. Effectiveness and safety of the angiotensin II antagonist irbesartan in children with chronic kidney diseases. Am J Hypertens. 2002;15(12):1057-63. [pmid: 12460701].
Freeman DH Jr., Ostfeld AM, Hellenbrand K, Richards VA, Tracy R. Changes in the prevalence distribution of hypertension: Connecticut adults 1978-79 to 1982. J Chronic Dis. 1985;38(2):157-64. [pmid: 3972958].
Friedman A, Chesney RW, Ball D, Goodfriend T. Effective use of captopril (angiotensin I-converting enzyme inhibitor) in severe childhood hypertension. J Pediatr. 1980;97(4):664-7. [pmid: 6999143].
Frishman WH, Brobyn R, Brown RD, Johnson BF, Reeves RL, Wombolt DG. Amlodipine versus atenolol in essential hypertension. Am J Cardiol. 1994;73(3):50A-4A. [pmid: 8279377].
Frishman WH, Hainer JW, Sugg J, Group MFS. A factorial study of combination hypertension treatment with metoprolol succinate extended release and felodipine extended release results of the Metoprolol Succinate-Felodipine Antihypertension Combination Trial (M-FACT). Am J Hypertens. 2006;19(4):388-95. [pmid: 16580575].
Frishman WH, Schoenberger JA, Gorwit JI, Bedsole GD, Cubbon J, Poland MP. Multicenter comparison of dilevalol to placebo in patients with mild hypertension. Am J Hypertens. 1988;1(3 Pt 3):295S-9S. [pmid: 3046631].
Fujinaga S, Kaneko K, Ohtomo Y, Yamashiro Y. Acute renal failure induced by an angiotensin II receptor antagonist in a 14-year-old boy with reflux nephropathy. Pediatr Nephrol. 2006;21(4):601-2. [pmid: 16534606].
Gale CR, Batty GD, Deary IJ. Locus of control at age 10 years and health outcomes and behaviors at age 30 years: the 1970 British Cohort Study. Psychosom Med. 2008;70(4):397-403. [pmid: 18480188].
Garbus SB, Reynolds JL. A community effort: the New Orleans hypertension screening project. J La State Med Soc. 1975;127(7):251-6. [pmid: 1165418].
García-Morales LM, Berber A, Macias-Lara CC, Lucio-Ortiz C, Del-Rio-Navarro BE, Dorantes-Alvárez LM. Use of sibutramine in obese mexican adolescents: A 6-month, randomized, double-blind, placebo-controlled, parallel-group trial. Clin Ther. 2006;28(5):770-82. [pmid: 16861099].
Gardiner HM, Celermajer DS, Sorensen KE, Georgakopoulos D, Robinson J, Thomas O, et al. Arterial reactivity is significantly impaired in normotensive young adults after successful repair of aortic coarctation in childhood. Circulation. 1994;89(4):1745-50. [pmid: 8149540].
Gartenmann AC, Fossali E, von Vigier RO, Simonetti GD, Schmidtko J, Edefonti A, et al. Better renoprotective effect of angiotensin II antagonist compared to dihydropyridine calcium channel blocker in childhood. Kidney Int. 2003;64(4):1450-4. [pmid: 12969165].
Gauthier B, Trachtman H. Short-acting nifedipine. Pediatr Nephrol. 1997;11(6):786-7. [pmid: 9438668].
Genest J, Kuchel O, Leduc G, Granger P, Boucher R, Rojo-Ortega JM, et al. Screening programs for hypertension. Can Med Assoc J. 1974;111(2):147-9. [pmid: 4841837].
Ghannem H, Harrabi I, Ben Abdelaziz A, Gaha R, Mrizak N. Clustering of cardiovascular risk factors among obese urban schoolchildren in Sousse, Tunisia. East Mediterr Health J. 2003;9(1-2):70-7. [pmid: 15562735].
Gidding SS, Rocchini AP, Beekman R, Szpunar CA, Moorehead C, Behrendt D, et al. Therapeutic effect of propranolol on paradoxical hypertension after repair of coarctation of the aorta. N Engl J Med. 1985;312(19):1224-8. [pmid: 3887159].
Gilders RM, Voner C, Dudley GA. Endurance training and blood pressure in normotensive and hypertensive adults. Med Sci Sports Exerc. 1989;21(6):629-36. [pmid: 2626084].
Gillman MW, Hood MY, Moore LL, Nguyen US, Singer MR, Andon MB. Effect of calcium supplementation on blood pressure in children. J Pediatr. 1995;127(2):186-92. [pmid: 7636641].
Gillum RF, Elmer PJ, Prineas RJ. Changing sodium intake in children. The Minneapolis Children's Blood Pressure Study. Hypertension. 1981;3(6):698-703. [pmid: 7298122].
Gimpel C, Wuhl E, Arbeiter K, Drozdz D, Trivelli A, Charbit M, et al. Superior consistency of ambulatory blood pressure monitoring in children: implications for clinical trials. J Hypertens. Aug. 2009;27(8):1568-74. [pmid: 19550356].
Giordano U, Cifra B, Giannico S, Turchetta A, Calzolari A. Mid-term results, and therapeutic management, for patients suffering hypertension after surgical repair of aortic coarctation. Cardiol Young. 2009;19(5):451-5. [pmid: 19674497].
Giordano U, Giannico S, Turchetta A, Hammad F, Calzolari F, Calzolari A. The influence of different surgical procedures on hypertension after repair of coarctation. Cardiol Young. 2005;15(5):477-80. [pmid: 16164785].
Giorgi G, Legramante JM, Fioravanti G, Paies G, Legramante A. A comparative study of doxazosin versus atenolol in mild-to-moderate hypertension. Am Heart J. 1988;116(6 Pt 2):1801-5. [pmid: 2904754].
Glynn LG, Murphy AW, Smith SM, Schroeder K, Fahey T. Interventions used to improve control of blood pressure in patients with hypertension. Cochrane Database of Systematic Reviews. 2010;(3). [pmid: 20238338].
Glynn LG, Murphy AW, Smith SM, Schroeder K, Fahey T. Self-monitoring and other non-pharmacological interventions to improve the management of hypertension in primary care: a systematic review. Br J Gen Pract. 2010;60(581):e476-88. [pmid: 21144192].
Godoy-Matos A, Carraro L, Vieira A, Oliveira J, Guedes EP, Mattos L, et al. Treatment of obese adolescents with sibutramine: a randomized, double-blind, controlled study. J Clin Endocrinol Metab. 2005;90(3):1460-5. [pmid: 15613431].
Goldberg AI, Dunlay MC, Sweet CS. Safety and tolerability of losartan potassium, an angiotensin II receptor antagonist, compared with hydrochlorothiazide, atenolol, felodipne ER, and angiotensin-converting enzyme inhibitors for the treatment of systemic hypertension. Am J Cardiol. 1995;75(12):793-5. [pmid: 7717281].
Golley RK, Magarey AM, Baur LA, Steinbeck KS, Daniels LA. Twelve-Month Effectiveness of a Parent-led, Family-Focused Weight-Management Program for Prepubertal Children: A Randomized, Controlled Trial. Pediatrics. 2007;119(3):517-25. [pmid: 17332205].
Gomez-Marin O, Prineas RJ, Sinaiko AR. The Sodium-Potassium Blood Pressure Trial in Children. Design, recruitment, and randomization: the children and adolescent blood pressure program. Control Clin Trials. 1991;12(3):408-23. [pmid: 1651211].
Graf C, Rost SV, Koch B, Heinen S, Falkowski G, Dordel S, et al. Data from the StEP TWO programme showing the effect on blood pressure and different parameters for obesity in overweight and obese primary school children. Cardiol Young. 2005;15(3):291-8. [pmid: 15865832].
Gragnoli G, Righi GA, Turchetti V, Mondillo S, Kristodhullu A. Evaluation of the antihypertensive effect and tolerability of nadolol administered alone or in association with bendroflumethiazide. Minerva Med. 1984;75(43):2609-15. [pmid: 6392936].
Graney WF. Clinical experience with a once-daily, extended-release formulation of diltiazem in the treatment of hypertension. Am J Med. 1992;93(2A):56S-64S. [pmid: 1519637].
Gregory KWP, Davis RC. Angioedema of the Intestine. N Engl J Med. 1996;334(25):1641. PMID: N/A. [pmid: 8628360].
Griffin L, Kee JL, Waters L. Reducing blood pressure in the potentially hypertensive young adult. J Am Coll Health. 1990;38(4):193-4. [pmid: 2299055].
Grobbee DE, Hofman A, Roelandt JT, Boomsma F, Schalekamp MA, Valkenburg HA. Sodium restriction and potassium supplementation in young people with mildly elevated blood pressure. J Hypertens. 1987;5(1):115-9. [pmid: 3295034].
Grobbee DE, Hofman A. Effect of calcium supplementation on diastolic blood pressure in young people with mild hypertension. Lancet. 1986;2(8509):703-7. [pmid: 2876183].
Group ET, Wuhl E, Trivelli A, Picca S, Litwin M, Peco-Antic A, et al. Strict blood-pressure control and progression of renal failure in children. N Engl J Med. 2009;361(17):1639-50. [pmid: 19846849].
Group INS. Efficacy and safety of intravenous nicardipine in the control of postoperative hypertension. IV Nicardipine Study Group. Chest. 1991;99(2):393-8. [pmid: 1989801].
Group MRFITR. Multiple Risk Factor Intervention Trial. JAMA. 1982;248(12):1465-77. [pmid: 7050440].
Grun A, Francillon A, Bodin F, Heath R, Muller M, Boutelant S. A comparison of the efficacy and tolerability of a new angiotensin II antagonist, valsartan, with enalapril in patients with mild-to-moderate essential hypertension. Eur Heart J. 1995;16(supplement):61. PMID: N/A. [pmid: 7737224].
Guitard C, Sassano P, Tzincoca C, Duchiez J, Safar ME. Placebo-controlled crossover comparison of spirapril at 3, 6, 12 and 24 mg once daily in mild to severe essential hypertension. Blood Press Suppl. 1994;2:61-8. [pmid: 8061848].
Guthrie R, Reggi DR, Plesher MM, Saini RK, Battikha JP. Efficacy and safety of fosinopril/hydrochlorothiazide combinations on ambulatory blood pressure profiles in hypertension. Fosinopril/Hydrochlorothiazide Investigators. Am J Hypertens. 1996;9(4 Pt 1):306-11. [pmid: 8722432].
Gutin B, Owen S. Role of exercise intervention in improving body fat distribution and risk profile in children. Am J Hum Biol. 1999;11(2):237-47. [pmid: 11533947].
Guul SJ, Os I, Jounela AJ. The efficacy and tolerability of enalapril in a formulation with a very low dose of hydrochlorothiazide in hypertensive patients resistent to enalapril monotherapy. Am J Hypertens. 1995;8(7):727-31. [pmid: 7546499].
Hagberg JM, Montain SJ, Martin Iii WH, Ehsani AA. Effect of exercise training in 60- to 69-year-old persons with essential hypertension. Am J Cardiol. 1989;64(5):348-53. [pmid: 2756880].
Halbert JA, Silagy CA, Finucane P, Withers RT, Hamdorf PA, Andrews GR. The effectiveness of exercise training in lowering blood pressure: a meta-analysis of randomised controlled trials of 4 weeks or longer. J Hum Hypertens. 1997;11(10):641-9. [pmid: 9400906].
Hall S, Prescott RI, Hallman RJ, Dixon S, Harvey RE, Ball SG. A comparative study of carvedilol, slow-release nifedipine, and atenolol in the management of essential hypertension. J Cardiovasc Pharmacol. 1991;18(4). [pmid: 1721977].
Halpern NA, Goldberg M, Neely C, S RN, Goldberg JS, Floyd J, Gabrielson G, et al. Postoperative hypertension: A multicenter, prospective, randomized comparison between intravenous nicardipine and sodium nitroprusside. Crit Care Med. 1992;20(12):1637-43. [pmid: 1458938].
Hammond JJ, Cutler SA. A comparison of isradipine and felodipine in Australian patients with hypertension: focus on ankle oedema. The Physician's Study Group. Blood Press. 1993;2(3):205-11. [pmid: 8205314].
Hanafy S, Pinsk M, Jamali F. Effect of obesity on response to cardiovascular drugs in pediatric patients with renal disease. Pediatr Nephrol. 2009;24(4):815-21. [pmid: 19083022].
Hansson L, Westerlund A, Aberg H, Karlberg BE. A comparison of the antihypertensive effect of atenolol (ICI 66 082) and propranolol. Eur J Clin Pharmacol. 1976;09(5-6):361-5. [pmid: 786662].
Hardes GR, Leeder SR. Screening for hypertension: a survey in the Hunter health region 1976-77. Aust Fam Physician. 1979;8(11):1152-5. [pmid: 534467].
Hardin DS, Hebert JD, Bayden T, Dehart M, Mazur L. Treatment of childhood syndrome X. Pediatrics. 1997;100(2):E5. [pmid: 9233976].
Harper SJ, Moorhouse J, Abrams K, Jurewicz A, Nicholson M, Horsburgh T, et al. The beneficial effects of oral nifedipine on cyclosporin-treated renal transplant recipients — a randomised prospective study. Transpl Int. 1996;9(2):115-25. [pmid: 8639252].
Harris KA, Holly RG. Physiological response to circuit weight training in borderline hypertensive subjects. Med Sci Sports Exerc. 1987;19(3):246-52. [pmid: 3600238].
Hart W, Clarke RJ. ACE inhibition versus calcium antagonism in the treatment of mild to moderate hypertension: a multicentre study. Ireland-Netherlands Lisinopril-Nifedipine Study Group. Postgrad Med J. 1993;69(812):450-5. [pmid: 8208641].
Hartung H, Heininger K, Schafer B, Toyka K. Substance P and astrocytes: stimulation of the cyclooxygenase pathway of arachidonic acid metabolism. FASEB J. 1988;2(1):48-51. [pmid: 2446942].
Hasebe N, Kikuchi K, Group NCS. Controlled-release nifedipine and candesartan low-dose combination therapy in patients with essential hypertension: the NICE Combi (Nifedipine and Candesartan Combination) Study. J Hypertens. 2005;23(2):445-53. [pmid: 15662234].
Hasler C, Nussberger J, Maillard M, Forclaz A, Brunner HR, Burnier M. Sustained 24-hour blockade of the renin-angiotensin system: A high dose of a long-acting blocker is as effective as a lower dose combined with an angiotensin-converting enzyme inhibitor. Clin Pharmacol Ther. 2005;78(5):501-7. [pmid: 16321616].
Hassan W, Malik S, Akhras N, Amri MA, Shoukri M, Fawzy ME. Long-term results (up to 18 years) of balloon angioplasty on systemic hypertension in adolescent and adult patients with coarctation of the aorta. Clin Cardiol. 2007;30(2):75-80. [pmid: 17326072].
He FJ, MacGregor GA. Effect of longer-term modest salt reduction on blood pressure. Cochrane Database of Systematic Reviews. 2009;(1). [pmid: 15266549].
Hedner T, Samuelsson O, Lunde H, Lindholm L, Andrén L, Wiholm BE. Angio-oedema in relation to treatment with angiotensin converting enzyme inhibitors. Br Med J. 1992;304(6832):941-6. [pmid: 1581715].
Heffernan A, Carty A, O'Malley K, Bugler J. A within-patient comparison of debrisoquine and methyldopa in hypertension. Br Med J. 1971;1(5740):75-8. [pmid: 5539179].
Herman RJ, Pylypchuk GB, Evans BL. Prevalence and Incidence of Cough in Patients on Treatment with Angiotensin Converting Enzyme Inhibitors (ACE-I). Clin Pharmacol Ther. 1996;59(2):139. PMID: N/A.
Herman RJ, Walker R, Pylypchuk GB, Khouri M, Evans BL. Angiotensin converting enzyme inhibitors (ACE-I) and cough, not all hwo cough have the ACE-I cough. Clin Invest Med. 1995;18(6):1372. PMID: N/A.
Hiner LB, Falkner B. Renovascular hypertension in children. Pediatr Clin North Am. 1993;40(1):123-40. [pmid: 8417400].
Hofman A, Hazebroek A, Valkenburg HA. A randomized trial of sodium intake and blood pressure in newborn infants. JAMA. 1983;250(3):370-3. [pmid: 6343656].
Hogg RJ, Delucchi A, Sakihara G, Wells TG, Tenney F, Batisky DL, et al. A multicenter study of the pharmacokinetics of lisinopril in pediatric patients with hypertension. Pediatr Nephrol. 2007;22(5):695-701. [pmid: 17216247].
Hollar D, Lombardo M, Lopez-Mitnik G, Hollar TL, Almon M, Agatston AS, et al. Effective multi-level, multi-sector, school-based obesity prevention programming improves weight, blood pressure, and academic performance, especially among low-income, minority children. J Health Care Poor Underserved. 2010;21(2 Suppl):93-108. [pmid: 20453379].
Holtz H, Heinrich J, Duck KD, Ruhling K, Heller R, Schauer I. Effectiveness of different intervention measures in children and adolescents with hypertension and lipid metabolism disorders. Z Gesamte Inn Med. 1983;38(23):644-9. [pmid: 6670341].
Holwerda NJ, Fogari R, Angeli P, Porcellati C, Hereng C, Oddou-Stock P, et al. Valsartan, a new angiotensin II antagonist for the treatment of essential hypertension: efficacy and safety compared with placebo and enalapril. J Hypertens. 1996;14(9):1147-51. [pmid: 8986917].
Hosie J, Bremner AD, Fell PJ, James IG, Saul PA, Taylor SH. Comparison of early side effects with amlodipine and nifedipine retard in hypertension. Cardiology. 1992;80(1):54-9. [pmid: 1534716].
Houben H, Thien T, de Boo T, Lemmens W, Binkhorst R, van't Laar A. Hemodynamic effects of isometric exercise and mental arithmetic in hypertension treated with selective and nonselective beta-blockade. Clin Pharmacol Ther. 1983;34(2):164-9. [pmid: 6872409].
Howe PRC, Jureidini KF, Smith RM. Sodium and blood pressure in children - a short-term dietary intervention study. Proceedings of the Nutrition Society of Australia. 1985;10:121-4. PMID: N/A.
Hu YZ, Zhou D. Studies on blood pressure and hypertension in children of 13 minority nationalities in China. J Tongji Med Univ. 1987;7(2):103-7. [pmid: 3656485].
Hurley BF, Hagberg JM, Goldberg AP, Seals DR, Ehsani AA, Brennan RE, et al. Resistive training can reduce coronary risk factors without altering VO2max or percent body fat. Med Sci Sports Exerc. 1988;20(Supplement 2):150-4. [pmid: 3285118].
Hurley BFf, Seals DR, Ehsani AA, Cartier LJ, Dalsky GP, Hagberg JM, et al. Effects of high-intensity strength training on cardiovascular function. Med Sci Sports Exerc. 1984;16(5):483-8. [pmid: 6513767].
Ilyas M, Peracha MA, Rahman I. Comparison of a semi-automated sphygmomanometer with the clinical sphygmomanometer. Jpn Heart J. 1975;16(2):118-21. [pmid: 1117590].
Irons BK, Kumar A. Valsartan-Induced Angioedema. Ann Pharmacother. 2003;37(7):1024-7. [pmid: 12841812].
Israili ZH, Hall WD. Cough and Angioneurotic Edema Associated with Angiotensin-Converting Enzyme Inhibitor Therapy. Ann Intern Med. 1992;117(3):234-42. [pmid: 1616218].
Ito Y, Kinoshita S, Yoshioka F, Ohotani Y, Kuriya N, Kato H. Mass screening of blood pressure in school children: results of the Karatsu Study. Jpn Circ J. 1986;50(12):1318-20. [pmid: 3820543].
Jafar TH, Chaturvedi N, Pappas G. Prevalence of overweight and obesity and their association with hypertension and diabetes mellitus in an Indo-Asian population. CAN MED ASSOC J. 2006;175(9):1071-7. [pmid: 17060656].
Jafar TH, Islam M, Hatcher J, Hashmi S, Bux R, Khan A, et al. Community based lifestyle intervention for blood pressure reduction in children and young adults in developing country: cluster randomised controlled trial. BMJ. 2010;340. [pmid: 20530082].
Jain M, Armstrong L, Hall J. Predisposition to and late onset of upper airway obstruction following angiotensin-converting enzyme inhibitor therapy. Chest. 1992;102(3):871-4. [pmid: 1325341].
Jennings G, Nelson L, Nestel P, Esler M, Korner P, Burton D, et al. The effects of changes in physical activity on major cardiovascular risk factors, hemodynamics, sympathetic function, and glucose utilization in man: a controlled study of four levels of activity. Circulation. 1986;73(1):30-40. [pmid: 3510088].
Jennings GL, Sudhir K, Laufer E, Korner P, Reid C. Assessment of effects of two anti-hypertensive regimens on overall cardiovascular risk. J Hum Hypertens. 1995;9(3):181-6. [pmid: 7783099].
Johnson CC, Nicklas TA, Arbeit ML, Franklin FA, Cresanta JL, Harsha DW, et al. Cardiovascular risk in parents of children with elevated blood pressure. “Heart Smart”--family health promotion. J Clin Hypertens. 1987;3(4):559-66. [pmid: 3453389].
Johnson CE, Jacobson PA, Song MH. Isradipine therapy in hypertensive pediatric patients. Ann Pharmacother. 1997;31(6):704-7. [pmid: 9184708].
Johnson D, Perrault H, Vobecky SJ, Trudeau F, Delvin E, Fournier A, et al. Resetting of the cardiopulmonary baroreflex 10 years after surgical repair of coarctation of the aorta. Heart. 2001;85(3):318-25. [pmid: 11179275].
Johnston GD, Wilson RC, McDermott BJ, Conroy C. A low dose atenolol/bendrofluazide combination in patients with mild to moderate hypertension. J Hum Hypertens. 1997;11:759-60. [pmid: 9416987].
Jones MR, Sealey JE, Laragh JH. Effects of Angiotensin Receptor Blockers on Ambulatory Plasma Renin Activity in Healthy, Normal Subjects During Unrestricted Sodium Intake. Am J Hypertens. 2007;20(8):907-16. [pmid: 17679042].
Jurgens G, Graudal NA. Effects of low sodium diet versus high sodium diet on blood pressure, renin, aldosterone, catecholamines, cholesterols, and triglyceride. Cochrane Database of Systematic Reviews. 2009;(1). PMID: N/A.
Kane ML, Iwata BA, Kane DF. Temporal effects of prompting on acceptance and follow-up in a community-based hypertension screening program. J Community Psychol. 1984;12(2):164-72. [pmid: 10266580].
Kannel WB, Castelli WP, McNamara PM, McKee PA, Feinleib M. Role of Blood Pressure in the Development of Congestive Heart Failure. N Engl J Med. 1972;287(16):781-7. [pmid: 4262573].
Kassler-Taub K, Littlejohn T, Elliott W, Ruddy T, Adler E. Comparative efficacy of two angiotensin II receptor antagonists, irbesartan and losartan in mild-to-moderate hypertension. Irbesartan/Losartan Study Investigators. Am J Hypertens. 1998;11(4 Pt 1):445-53. [pmid: 9607383].
Kassler-Taub K, Littlejohn T, Elliott W, Ruddy T, Adler E. Comparative efficacy of two angiotensin II receptor antagonists, irbesartan and losartan in mild-to-moderate hypertension. Irbesartan/Losartan Study Investigators. [Erratum appears in Am J Hypertens 1998;11(6 Pt 1):736]. Am J Hypertens. 1998;11(4 Pt 1):445-53. [pmid: 9607383].
Kaufman FL, Hughson RL, Schaman JP. Effect of exercise on recovery blood pressure in normotensive and hypertensive subjects. Med Sci Sports Exerc. 1987;19(1):17-20. [pmid: 3821451].
Kaufman J, Barkey N. Hypertension in Africa: an overview of prevalence rates and causal risk factors. Ethn Dis. 1993;3(101). [pmid: 8087029].
Kellaway GS. A comparison of the efficacy of cilazapril versus cilazapril plus hydrochlorothiazide in patients with mild to moderate essential hypertension. Inhibace General Practice Study Group. Eur J Clin Pharmacol. 1993;44(4):377-9. [pmid: 8513849].
Khattak S, Rogan JW, Saunders EF, Theis JG, Arbus GS, Koren G. Efficacy of amlodipine in pediatric bone marrow transplant patients. Clin Pediatr (Phila). 1998;37(1):31-5. [pmid: 9475697].
Kiesman MA, Evans B, Semchuk WM. Etiology and treatment of angiotensin converting enzyme inhibitor-induced cough. Can J Hosp Pharm. 1995;48(1):25-31. PMID: N/A.
Kilcoyne MM. Hypertension and heart disease in the urban community. Bull N Y Acad Med. 1973;49(6):501-9. [pmid: 4513125].
Kim MT, Hill MN. Validity of self-report of illicit drug use in young hypertensive urban African American males. Addict Behav. 2003;28(4):795-802. [pmid: 12726792].
Kimball TR, Reynolds JM, Mays WA, Khoury P, Claytor RP, Daniels SR. Persistent hyperdynamic cardiovascular state at rest and during exercise in children after successful repair of coarctation of the aorta. J Am Coll Cardiol. 1994;24(1):194-200. [pmid: 8006265].
Kiyonaga A, Arakawa K, Tanaka H, Shindo M. Blood pressure and hormonal responses to aerobic exercise. Hypertension. 1985;7(1):125-31. [pmid: 2984115].
Kneisley J, Schork N, Julius S. Predictors of blood pressure and hypertension in Tecumseh, Michigan. Clin Exp Hypertens A. 1990;12(5):693-708. [pmid: 2208743].
Kochar MS, Itskovitz HD, Panagis C. Hypertension control among patients referred by a community blood pressure screening program. J Chronic Dis. 1979;32(7):493-7. [pmid: 457834].
Koshy SM, Garcia-Garcia G, Pamplona JS, Renoirte-Lopez K, Perez-Cortes G, Gutierrez ML, et al. Screening for kidney disease in children on World Kidney Day in Jalisco, Mexico. Pediatr Nephrol. 2009;24(6):1219-25. [pmid: 19271247].
Kreutz R, Bolbrinker J, Huber M. Pharmacokinetics of Olmesartan Medoxomil plus Hydrochlorothiazide Combination in Healthy Subjects. Clin Drug Investig. 2006;26(1):29-34. [pmid: 17163232].
Krum H, Nolly H, Workman D, He W, Roniker B, Krause S, et al. Efficacy of eplerenone added to renin-angiotensin blockade in hypertensive patients. Hypertension. 2002;40(2):117-23. [pmid: 12154100].
Kubota K, Kubota N, Pearce GL, Inman WHW. ACE-inhibitor-induced cough, an adverse drug reaction unrecognised for several years: studies in Prescription-Event Monitoring. Eur J Clin Pharmacol. 1996;49(6):431-7. [pmid: 8706766].
Lacourciere Y, Arnott W. Placebo-controlled comparison of the effects of nebivolol and low-dose hydrochlorothiazide as monotherapies and in combination on blood pressure and lipid profile in hypertensive patients. J Hum Hypertens. 1994;8(4):283-8. [pmid: 8021909].
Lacourcière Y, Brunner H, Irwin R, Karlberg BE, Ramsay LE, Snavely DB, et al. Effects of modulators of the renin-angiotensin-aldosterone system on cough. J Hypertens. 1994;12(12):1387-94. [pmid: 7706699].
Lacourciere Y, Lefebvre J, Poirier L, Archambault F, Arnott W. Treatment of ambulatory hypertensives with nebivolol or hydrochlorothiazide alone and in combination. A randomized, double-blind, placebo-controlled, factorial-design trial. Am J Hypertens. 1994;7(2):137-45. [pmid: 8179848].
Lacourciere Y, Poirier L, Boucher S, Spenard J. Comparative effects of diltiazem sustained-release and captopril on blood pressure control and plasma lipoproteins in primary hypertension: a randomized, double-blind, crossover study. J Hum Hypertens. 1990;4(5):553-6. [pmid: 2283645].
Lacourciere Y, Poirier L, Lefebvre J, Burford RG. Clinical efficacy of force titrated doses of diltiazem extended-release. A placebo controlled study. Am J Hypertens. 1995;8(3):282-6. [pmid: 7794578].
Laher MS, Kelly JG, Doyle GD, Carmody M, Donohoe JF, Greb H, et al. Pharmacokinetics of amlodipine in renal impairment. J Cardiovasc Pharmacol. 1988;12(Supplement 7):S60-S3. [pmid: 2467131].
Lama G, Salsano ME, Pedulla' M, Grassia C, Ruocco G. Angiotensin converting enzyme inhibitors and reflux nephropathy: 2-year follow-up. Pediatr Nephrol. 1997;11(6):714-8. [pmid: 9438650].
Lambert CR, Hill JA, Nichols WW, Feldman RL, Pepine CJ. Coronary and systemic hemodynamic effects of nicardipine. Am J Cardiol. 1985;55(6):652-6. [pmid: 3976506].
Larochelle P, Flack JM, Hannah S, Smith S, Hwa J, Reeves RA. D103: Irbesartan versus enalapril in severe hypertension. Am J Hypertens. 1997;10(S2):131A-A. PMID: N/A.
Lasko BH, Laplante A, Hebert D, Bonnefis-Boyer S. Canadian valsartan study in patients with mild-to-moderate hypertension. Blood Press Monit. 2001;6(2):91-9. [pmid: 11433130].
Laufer E, Reid C, Qi XL, Jennings GL. Absence of detectable regression of human hypertensive left ventricular hypertrophy following drug treatment for 1 year. Clin Exp Pharmacol Physiol. 1998;25(3-4):208-15. [pmid: 9590570].
Lawrie GM, DeBakey ME, Morris GC Jr., Crawford ES, Wagner WF, Glaeser DH. Late repair of coarctation of the descending thoracic aorta in 190 patients. Results up to 30 years after operation. Arch Surg. 1981;116(12):1557-60. [pmid: 6459070].
Lazarou C, Panagiotakos DB, Matalas AL. Foods E-KINDEX: a dietary index associated with reduced blood pressure levels among young children: the CYKIDS study. J Am Diet Assoc. 2009;109(6):1070-5. [pmid: 19465190].
Leavitt Ad, Zweifler AJ. Nifedipine, Hypotension Myocardial Injury. Ann Intern Med. 1988;108(2):305-6. [pmid: 3341662].
Leenen FH, Balfe JA, Pelech AN, Barker GA, Balfe JW, Olley PM. Postoperative hypertension after repair of coarctation of aorta in children: protective effect of propranolol?. Am Heart J. 1987;113(5):1164-73. [pmid: 3554943].
Levene MI, Gibson NA, Fenton AC, Papathoma E, Barnett D. The Use Of A Calcium-Channel Blocker, Nicardipine, For Severely Asphyxiated Newborn Infants. Dev Med Child Neurol. 1990;32(7):567-74. [pmid: 2391009].
Ley SH, Harris SB, Mamakeesick M, Noon T, Fiddler E, Gittelsohn J, et al. Metabolic syndrome and its components as predictors of incident type 2 diabetes mellitus in an Aboriginal community. CAN MED ASSOC J. 2009;180(6):617-24. [pmid: 19289805].
Li Z, Snieder H, Harshfield GA, Treiber FA, Wang X. A 15-year longitudinal study on ambulatory blood pressure tracking from childhood to early adulthood. Hypertens Res Clin Exp. 2009;32(5):404-10. [pmid: 19325561].
Liao CC, Su TC, Chien KL, Wang JK, Chiang CC, Lin CC, et al. Elevated blood pressure, obesity, and hyperlipidemia. J Pediatr. 2009;155(1):79-83. [pmid: 19446850].
Liberthson RR, Pennington DG, Jacobs ML, Daggett WM. Coarctation of the aorta: review of 234 patients and clarification of management problems. Am J Cardiol. 1979;43(4):835-40. [pmid: 425922].
Lo KS. Angioedema Associated with Candesartan. Pharmacotherapy. 2002;22(9):1176-9. [pmid: 12222554].
Lodish MB, Sinaii N, Patronas N, Batista DL, Keil M, Samuel J, et al. Blood pressure in pediatric patients with Cushing syndrome. J Clin Endocrinol Metab. 2009;94(6):2002-8. [pmid: 19293264].
Lohsoonthorn V. BMI and health risks of health checkup clients at the Preventive Medicine Clinic, King Chulalongkorn Memorial Hospital. J Med Assoc Thai. 2001;84(1). [pmid: 11529344].
Lopez-Herce J, Albajara L, Cagigas P, Garcia S, Ruza F. Treatment of hypertensive crisis in children with nifedipine. Intensive Care Med. 1988;14(5):519-21. [pmid: 3221006].
Lorber R, Gidding SS, Daviglus ML, Colangelo LA, Liu K, Gardin JM. Influence of systolic blood pressure and body mass index on left ventricular structure in healthy African-American and white young adults: the CARDIA study. J Am Coll Cardiol. 2003;41(6):955-60. [pmid: 12651040].
Lubrano R, Soscia F, Elli M, Ventriglia F, Raggi C, Travasso E, et al. Renal and Cardiovascular Effects of Angiotensin-Converting Enzyme Inhibitor Plus Angiotensin II Receptor Antagonist Therapy in Children With Proteinuria. Pediatrics. 2006;118(3):e833-e8. [pmid: 16923922].
Lucky D, Turner B, Hall M, Lefaver S, de Werk A. Blood pressure screenings through community nursing health fairs: motivating individuals to seek health care follow-up. J Community Health Nurs. 2011;28(3):119-29. [pmid: 21809928].
Luther RR, Glassman HN, Jordan DC, Sperzel WD. Efficacy of terazosin as an antihypertensive agent. Am J Med. 1986;80(5B):73-6. [pmid: 2872811].
Lv J, Zhang H, Zhou Y, Li G, Zou W, Wang H. Natural history of immunoglobulin A nephropathy and predictive factors of prognosis: A long-term follow up of 204 cases in China. Nephrology. 2008;13(3):242-6. [pmid: 18221258].
Macdonald LA, Sackett DL, Haynes RB, Taylor DW. Labelling in hypertension: a review of the behavioural and psychological consequences. J Chronic Dis. 1984;37(12):933-42. [pmid: 6396317].
Maiorano G, Contursi V, Saracino E. Blood pressure and isometric exercise. Am J Hypertens. 1989;2:65S-9S. PMID: N/A. [pmid: 2645909].
Malini PL, Strocchi E, Zanardi M, Milani M, Ambrosioni E. Thromboxane antagonism and cough induced by angiotensin-converting-enzyme inhibitor. The Lancet. 1997;350(9070):15-8. [pmid: 9217714].
Mallion JM, Asmar R, Boutelant S, Guez D. Twenty-four hour antihypertensive efficacy of indapamide, 1.5-mg sustained release: results of two randomized double-blind controlled studies. J Cardiovasc Pharmacol. 1998;32(4):673-8. [pmid: 9781939].
Mallion JM. An evaluation of the initial and long-term antihypertensive efficacy of zofenopril compared with enalapril in mild to moderate hypertension. Blood Press Suppl. 2007;2:13-8. [pmid: 18046974].
Mancia G, Korlipara K, van Rossum P, Villa G, Silvert B. An ambulatory blood pressure monitoring study of the comparative antihypertensive efficacy of two angiotensin II receptor antagonists, irbesartan and valsartan. Blood Press Monit. 2002;7(2):135-42. [pmid: 12048432].
Mann AH. The psychological effect of a screening programme and clinical trial for hypertension upon the participants. Psychol Med. 1977;7(03):431-8. [pmid: 905459].
Maroko PR, McDevitt JT, Fox MJ, Silber SA, Young MD, Beg M, et al. Antihypertensive effectiveness of very low doses of hydrochlorothiazide: results of the PHICOG Trial. Clin Ther. 1989;11(1):94-119. [pmid: 2655909].
Martin DR, Ventrapragada S, Behrend T, Vijayan A, Miller SB. Elevated blood pressure in men accompanying patients to the obstetrician's office. Am J Hypertens. 2000;13(9):1042-4. [pmid: 10981558].
M'Buyamba-Kabangu JR, Fagard R, Lijnen P, Staessen J, Lissens W, Ditu M, et al. Calcium entry blockade or beta-blockade in long-term management of hypertension in blacks. Clin Pharmacol Ther. 1987;41(1):45-54. [pmid: 3802705].
M'Buyamba-Kabangu JR, Lepira B, Fagard R, Lijnen P, Ditu M, Tshiani KA, et al. Relative potency of a beta-blocking and a calcium entry blocking agent as antihypertensive drugs in black patients. Eur J Clin Pharmacol. 1986;29(5):523-7. [pmid: 2869952].
McIntyre L, Shah CP. Prevalence of hypertension, obesity and smoking in three Indian communities in northwestern. Ontario CAN MED ASSOC J. 1986;134(4):345-9. [pmid: 3942942].
McLeod PJ, Ogilvie RI, Ruedy J. Effects of large and small doses of hydrochlorothiazide in hypertensive patients. Clin Pharmacol Ther. 1970;11:733-9. [pmid: 5455635].
McMurray RG, Harrell JS, Bangdiwala SI, Bradley CB, Deng S, Levine A. A school-based intervention can reduce body fat and blood pressure in young adolescents. J Adolesc Health. 2002;31(2):125-32. [pmid: 12127382].
Megnigbeto AC, Niakara A, Nebie LV, Ouedraogo NA, Zagre NM. Validation of a method of blood pressure measurement for a study of hypertension in a black African population. [French]. Sante. 2002;12(3):313-7. [pmid: 12473526].
Mesihovic-Dinarevic S, Kulic M, Kreso A. Cardiovascular screening in young athletes in Sarajevo Canton. Bosn J Basic Med Sci. 2010;10(3):227-33. [pmid: 20846130].
Michael J, Groshong T, Tobias JD. Nicardipine for hypertensive emergencies in children with renal disease. Pediatr Nephrol. 1998;12(1):40-2. [pmid: 9502566].
Miller K, Atkin B, Rodel PV Jr., Walker JF. Enalapril: a well-tolerated and efficacious agent for the pediatric hypertensive patient. J Cardiovasc Pharmacol. Suppl 7. 1987;10:S154-6. [pmid: 2485054].
Mimran A, Ruilope L, Kerwin L, Nys M, Owens D, Osbakken M. Comparison of the angiotensin II receptor antagonist, irbesartan, with the full dose range of enalapril for the treatment of hypertension. J Hypertens - Supplement. 1997;15(Supplement 4):s117. PMID: N/A.
Mirkin BL, Newman TJ. Efficacy and safety of captopril in the treatment of severe childhood hypertension: report of the International Collaborative Study Group. Pediatrics. 1985;75(6):1091-100. [pmid: 3889818].
Mizushima S, Cappuccio FP, Nichols R, Elliott P. Dietary magnesium intake and blood pressure: a qualitative overview of the observational studies. J Hum Hypertens. 1998;12(7):447-53. [pmid: 9702930].
Moncica I, Oh PI, ul Qamar I, Scolnik D, Arbus GS, Herbert D, et al. A crossover comparison of extended release felodipine with prolonged action nifedipine in hypertension. Arch Dis Child. 1995;73(2):154-6. [pmid: 7574861].
Mounier-Vehier C, Bernaud C, Carre A, Lequeuche B, Hotton JM, Charpentier JC. Compliance and antihypertensive efficacy of amlodipine compared with nifedipine slow-release. Am J Hypertens. 1998;11(4 Pt 1):478-86. [pmid: 9607387].
Mu J, Liu Z, Liu F, Xu X, Liang Y, Zhu D. Family-based randomized trial to detect effects on blood pressure of a salt substitute containing potassium and calcium in hypertensive adolescents. Am J Hypertens. 2009;22(9):943-7. [pmid: 19661927].
Mu JJ, Liu ZQ, Yang J, Liang YM, Zhy DJ, Wang YX, et al. Long term observation in effects of potassium and calcium supplementation on arterial blood pressure and sodium metabolism in adolescents with higher blood pressure. Zhonghua yu fang yi xue za zhi. Chinese journal of preventive medicine. 2003;37(2):90-2. [pmid: 12839657].
Mulrow PJ. Detection and control of hypertension in the population: the United States experience. Am J Hypertens. 1998;11(6 Pt 1):744-6. [pmid: 9657637].
Muraguri PW, McLigeyo SO, Kayima JK. Proteinuria, other selected urinary abnormalities and hypertension among teenage secondary school students in Nairobi. Kenya East Afr Med J. 1997;74(8):467-73. [pmid: 9487409].
Murphy J, Lasagna L, Casey W. The effect of dosage regimen on the diuretic efficacy of chlorothiazide in human subjects. J Pharmacol Exp Ther. 1961;134(3):286-90. [pmid: 14477425].
Must A, Jacques PF, Dallal GE, Bajema CJ, Dietz WH. Long-Term Morbidity and Mortality of Overweight Adolescents. N Engl J Med. 1992;327(19):1350-5. [pmid: 1406836].
Musto C, Cifarelli A, Pucci E, Paladini S, De Felice F, Fiorilli R, et al. Endovascular treatment of aortic coarctation: long-term effects on hypertension. Int J Cardiol. 2008;130(3):420-5. [pmid: 18164768].
Myers JB. Reduced sodium chloride intake normalises blood pressure distribution. J Hum Hypertens. 1989;3(2):97-104. [pmid: 2760911].
Nagai K, Imai Y, Tsuji I, Ohkubo T, Sakuma M, Watanabe N, et al. Prevalence of hypertension and rate of blood pressure control as assessed by home blood pressure measurements in a rural Japanese community, Ohasama. Clin Exp Hypertens. 1996;18(5):713-28. [pmid: 8781755].
Nanton MA, Olley PM. Residual hypertension after coarctectomy in children. Am J Cardiol. 1976;37(5):769-72. [pmid: 1266744].
Neldam S, Edwards C, Telmisartan/Hydrochlorothiazide I. Results of increasing doses of hydrochlorothiazide in combination with an angiotensin receptor blocker in patients with uncontrolled hypertension. J Clin Hypertens. 2008;10(8):612-8. [pmid: 18772643].
Nelson L, Esler M, Jennings G, Korner P. Effect of changing levels of physical activity on blood-pressure and haemodynamics in essential hypertension. The Lancet. 1986;328(8505):473-6. [pmid: 2875235].
Nesbitt SD, Amerena JV, Grant E, Jamerson KA, Lu H, Weder A, et al. Home blood pressure as a predictor of future blood pressure stability in borderline hypertension. The Tecumseh Study. Am J Hypertens. 1997;10(11):1270-80. [pmid: 9397247].
Neutel JM, Rotenberg K. Comparison of a chronotherapeutically administered beta blocker vs. a traditionally administered beta blocker in patients with hypertension. J Clin Hypertens. 2005;7(7):395-400. quiz 1-2. [pmid: 16015049].
Nickenig G, Simanenkov V, Lembo G, Rodriguez P, Salko T, Ritter S, et al. Efficacy of aliskiren/hydrochlorothiazide single-pill combinations in aliskiren non-responders. Blood Press Suppl. 2008;2:31-40. [pmid: 19203020].
Niinikoski H, Jula A, Viikari J, Ronnemaa T, Heino P, Lagstrom H, et al. Blood pressure is lower in children and adolescents with a low-saturated-fat diet since infancy: the special turku coronary risk factor intervention project. Hypertension. 2009;53(6):918-24. [pmid: 19364991].
Nishikawa T, Omote K, Namiki A, Takahashi T. The Effects of Nicardipine on Cerebrospinal Fluid Pressure in Humans. Anesth Analg. 1986;65(5):507-10. [pmid: 3083718].
Nobile-Orazio E, Sterzi R. Cerebral ischaemia after nifedipine treatment. Br Med J (Clin Res Ed). 1981;283(6297):948. [pmid: 6793184].
Norris K, Bourgoigne J, Gassman J, Hebert L, Middleton J, Phillips RA, et al. Cardiovascular outcomes in the African American Study of Kidney Disease and Hypertension (AASK) Trial. Am J Kidney Dis. 2006;48(5):739-51. [pmid: 17059993].
Ogihara T, Arakawa K, Iimura O, Abe K, Saruta T, Ishii M, et al. Open clinical studies on a new angiotensin II receptor antagonist, TCV 116. J Hypertens Suppl. 1994;12(9):s35-s8. [pmid: 7884583].
Ogihara T, Mikami H, Katahira K, Otsuka A. Comparative study of the effects of three angiotensin converting enzyme inhibitors on the cough reflex. Am J Hypertens. 1991;4(1 part 2):46s-51s. [pmid: 2009148].
Ogihara T, Nagano M, Mikami H, Higaki J, Kohara K, Azuma J, et al. Effects of the angiotensin II receptor antagonist, TCV-116, on blood pressure and the renin-angiotensin system in healthy subjects. Clin Ther. 1994;16(1):74-86. [pmid: 8205603].
Olsen CG. Delay of Diagnosis and Empiric Treatment of Angiotensin-Converting Enzyme InhibitorˆInduced Cough in Office Practice. Arch Fam Med. 1995;4(6):525-8. [pmid: 7773428].
Oparil S, Bernink P, Bursztyn M, Carney S, Kobrin I. Antihypertensive effects of mibefradil in the treatment of mild-to-moderate systemic hypertension. Am J Cardiol. 1997;80(4B):12C-9C. [pmid: 9286849].
Oparil S, Kobrin I, Abernethy DR, Levine BS, Reif MC, Shepherd AM. Dose-response characteristics of mibefradil, a novel calcium antagonist, in the treatment of essential hypertension. [Erratum appears in Am J Hypertens 1997;10(9 Pt 1):1081]. Am J Hypertens. 1997;10(7 Pt 1):735-42. [pmid: 9234827].
Oparil S, Kobrin I, Abernethy DR, Levine BS, Reif MC, Shepherd AM. Dose-response characteristics of mibefradil, a novel calcium antagonist, in the treatment of essential hypertension. Am J Hypertens. 1997;10(7 Pt 1):735-42. [pmid: 9234827].
Opie LH, Muller FO, Myburgh DP, Rosendorff C, Sareli P, Seedat YK, et al. Efficacy and tolerability of nisoldipine coat-core formulation in the treatment of essential hypertension: The South African Multicenter ANCHOR Study. Ambulatory Nisoldipine Coat-Core Hypertension Outpatient Response (ANCHOR) Investigators. [Erratum appears in Am J Hypertens 1997;10(6):696]. Am J Hypertens. 1997;10(3):250-60. [pmid: 9056681].
Opie LH, Muller FO, Myburgh DP, Rosendorff C, Sareli P, Seedat YK, et al. Efficacy and tolerability of nisoldipine coat-core formulation in the treatment of essential hypertension: The South African Multicenter ANCHOR Study. Ambulatory Nisoldipine Coat-Core Hypertension Outpatient Response (ANCHOR) Investigators. Am J Hypertens. 1997;10(3):250-60. [pmid: 9056681].
Os I, Bratland B, Dahlöf B, Gisholt K, Syvertsen JO, Tretli S. Female sex as an important determinant of lisinopril-induced cough. Lancet. 1992;339(8789):372. [pmid: 1346451].
Os I, Hotnes T, Dollerup J, Mogensen CE. Comparison of the combination of enalapril and a very low dose of hydrochlorothiazide with atenolol in patients with mild-to-moderate hypertension. Scandinavian Study Group. Am J Hypertens. 1997;10(8):899-904. [pmid: 9270085].
Ovbiagele B, Hutchison P, Handschumacher L, Coleman A, Gutierrez M, Yellin-Mednick S, et al. Educating and mobilizing youth to detect undiagnosed elevated blood pressure: searching for the silent killer. Ethn Dis. 2008;18(1):84-8. [pmid: 18447105].
Overlack A. ACE inhibitor-induced cough and bronchospasm. Incidence, mechanisms and management. Drug Saf. 1996;15(1):72-8. [pmid: 8862965].
Oviasu VO. Arterial blood pressures and hypertension in a rural Nigerian community. Afr J Med Med Sci. 1978;7(3):137-43. [pmid: 108932].
Palacios C, Wigertz K, Martin BR, Jackman L, Pratt JH, Peacock M, et al. Sodium Retention in Black and White Female Adolescents in Response to Salt Intake. J Clin Endocrinol Metab. 2004;89(4):1858-63. [pmid: 15070956].
Palatini P, Bongiovi S, Cordiano R, Munari L, Scanavacca G, Musco A, et al. Ventricular ectopic activity in physically trained hypertensive subjects. Eur Heart J. 1992;13(3):316-20. [pmid: 1597217].
Palatini P, Bratti P, Palomba D, Saladini F, Zanatta N, Maraglino G. Regular physical activity attenuates the blood pressure response to public speaking and delays the development of hypertension. J Hypertens. 2010;28(6):1186-93. [pmid: 20486274].
Palatini P, Visentin P, Dorigatti F, Guarnieri C, Santonastaso M, Cozzio S, et al. Regular physical activity prevents development of left ventricular hypertrophy in hypertension. Eur Heart J. 2009;30(2):225-32. [pmid: 19074443].
Pareek A, Basavanagowdappa H, Zawar S, Kumar A, Chandurkar N. A randomized, comparative study evaluating the efficacy and tolerability of losartan-low dose chlorthalidone (6.25 mg) combination with losartan-hydrochlorothiazide (12.5 mg) combination in Indian patients with mild-to-moderate essential hypertension. Expert opinion on pharmacotherapy. 2009;10(10):1529-36. [pmid: 19514864].
Parker ED, Schmitz KH, Jacobs DR Jr., Dengel DR, Schreiner PJ. Physical activity in young adults and incident hypertension over 15 years of follow-up: the CARDIA study. Am J Public Health. 2007;97(4):703-9. [pmid: 17329668].
Parra Carrillo JZ, Fernandez M, Barrera M, Bahena J, Estrella M, Olivares Ruiz R, et al. Effect of telmisartan 80 mg once daily on 24-h blood pressure profile in patients with mild-to-moderate hypertension failing to respond to prior antihypertensive therapy. Int J Clin Pract. 2004;Supplement(145):9-15. [pmid: 15617453].
Parving HH, Persson F, Lewis JB, Lewis EJ, Hollenberg NK, Investigators AS. Aliskiren combined with losartan in type 2 diabetes and nephropathy. N Engl J Med. 2008;358(23):2433-46. [pmid: 18525041].
Pennisi AJ, Takahashi M, Bernstein BH, Singsen BH, Uittenbogaart C, Ettenger RB, et al. Minoxidil therapy in children with severe hypertension. J Pediatr. May. 1977;90(5):813-9. [pmid: 323442].
Petrie JR, Glen SK, MacMahon M, Crome R, Meredith PA, Elliott HL, et al. Haemodynamics, cardiac conduction and pharmacokinetics of mibefradil (Ro 40-5967), a novel calcium antagonist. J Hypertens. 1995;13(12 Pt 2):1842-6. [pmid: 8903664].
Pierce JR, Kleinstein RN. Screening for hypertension by optometrists. Am J Public Health. 1977;67(10):977-9. [pmid: 911011].
Pietrement C, Malot L, Santerne B, Roussel B, Motte J, Morville P. Neonatal acute renal failure secondary to maternal exposure to telmisartan, angiotensin II receptor antagonist. J Perinatol. 2003;23(3):254-5. [pmid: 12732865].
Pillans PI, Coulter DM, Black P. Angiooedema and urticaria with angiotensin converting enzyme inhibitors. Eur J Clin Pharmacol. 1996;51(2):123-6. [pmid: 8911875].
Piper JM, Ray WA, Rosa FW. Pregnancy outcome following exposure to angiotensin-converting enzyme inhibitors. Obstet Gynecol. 1992;80(3 Pt 1):429-32. [pmid: 1495700].
Pivac N, Naranca M, Vujic-Podlipec D, Bagatin J, Rumboldt Z. Prospective controlled trial of two nifedipine extended release formulations in the treatment of essential hypertension. Arzneimittelforschung. 2002;52(5):379-84. [pmid: 12087923].
Podoll A, Grenier M, Croix B, Feig DI. Inaccuracy in Pediatric Outpatient Blood Pressure Measurement. Pediatrics. 2007;119(3):e538-e43. [pmid: 17332173].
Poirier L, Bourgeois J, Lacourciere Y. Once-daily trandolapril compared with the twice-daily formulation in the treatment of mild to moderate essential hypertension: assessment by conventional and ambulatory blood pressures. J Clin Pharmacol. 1993;33(9):832-6. [pmid: 8227480].
Pope Iv JC, Brock Iii JW, Adams MC, Miyazaki Y, Stephens FD, Ichikawa I. Congenital anomalies of the kidney and urinary tract-- role of the loss of function mutation in the pluripotent angiotensin type 2 receptor gene. J Urol. 2001;165(1):196-202. [pmid: 11125405].
Presbitero P, Demarie D, Villani M, Perinetto EA, Riva G, Orzan F, et al. Long term results (15-30 years) of surgical repair of aortic coarctation. Br Heart J. 1987;57(5):462-7. [pmid: 3593616].
Prisant LM, Krum H, Roniker B, Krause SL, Fakouhi K, He W. Can renin status predict the antihypertensive efficacy of eplerenone add-on therapy?. J Clin Pharmacol. 2003;43(11):1203-10. [pmid: 14551174].
Proesmans W, Knockaert H, Trouet D. Enalapril in paediatric patients with Alport syndrome: 2 years' experience. Eur J Pediatr. 2000;159(6):430-3. [pmid: 10867848].
Proesmans W, Van Dyck M. Enalapril in children with Alport syndrome. Pediatr Nephrol. 2004;19(3):271-5. [pmid: 14745635].
Proesmans W, Van Wambeke I, Van Dyck M. Long-term therapy with enalapril in patients with nephrotic-range proteinuria. Pediatr Nephrol. 1996;10(5):587-9. [pmid: 8897561].
Pryde PG, Sedman AB, Nugent CE, Barr M Jr. Angiotensin-converting enzyme inhibitor fetopathy. J Am Soc Nephrol. 1993;3(9):1575-82. [pmid: 8507813].
Pryer J, Cappuccio FP, Elliott P. Dietary calcium and blood pressure: a review of the observational studies. J Hum Hypertens. 1995;9(8):597-604. [pmid: 8523372].
Psaty BM, Heckbert SR, Koepsell TD, Siscovick DS, Raghunathan TE, Weiss NS, et al. The Risk of Myocardial Infarction Associated With Antihypertensive Drug Therapies. JAMA. 1995;274(8):620-5. [pmid: 7637142].
Puchler K, Nussberger J, Laeis P, Witte PU, Brunner HR. Blood pressure and endocrine effects of single doses of CS-866, a novel angiotensin II antagonist, in salt-restricted hypertensive patients. J Hypertens. 1997;15(12):1809-12. [pmid: 9488244].
Puig JG, Mateos FA, Ramos TH, Lavilla MP, Capitan MC, Gil A. Albumin excretion rate and metabolic modifications in patients with essential hypertension. Effects of two angiotensin converting enzyme inhibitors. Am J Hypertens. 1994;7(1):46-51. [pmid: 8136110].
Punzi HA. Safety update: Focus on cough. Am J Cardiol. 1993;72(20):H45-H8. [pmid: 8285182].
Radauceanu A, Virion JM, Boivin JM, Zannad F. Time-effect profile of antihypertensive agents assessed with trough/peak ratio, smoothness index and dose omission: an ambulatory blood pressure monitoring study with trandolapril vs. quinapril. Fundam Clin Pharmacol. 2002;16(6):545-54. [pmid: 12685514].
Rafraf M, Gargari BP, Safaiyan A. Prevalence of prehypertension and hypertension among adolescent high school girls in Tabriz, Iran. Food & Nutrition Bulletin. 2010;31(3):461-5. [pmid: 20973466].
Raglin JS, Morgan WP. Influence of exercise and quiet rest on state anxiety and blood pressure. Med Sci Sports Exerc. 1987;19(5):456-63. [pmid: 3316903].
Ram CV, Ames RP, Applegate WB, Burris JF, Davidov ME, Mroczek WJ. Double-blind comparison of amlodipine and hydrochlorothiazide in patients with mild to moderate hypertension. Clin Cardiol. 1994;17(5):251-6. [pmid: 8004839].
Ramsay LE, Yeo WW. ACE inhibitors, angiotensin II antagonists and cough. The Losartan Cough Study Group. J Hum Hypertens. 1995;9(supplement 5):s51-s4. [pmid: 8583482].
Randall OS, Retta TM, Kwagyan J, Gordeuk VR, Xu S, Maqbool AR, et al. Obese African Americans: the prevalence of dyslipidemia, hypertension, and diabetes mellitus. Ethn Dis. 2004;14(3):384-8. [pmid: 15328940].
Redon-Mas J, Abellan-Aleman J, Aranda-Lara P, de la Figuera-von Wichmann M, Luque-Otero M, Rodicio-Diaz JL, et al. Antihypertensive activity of verapamil: impact of dietary sodium. The VERSAL Study Group. J Hypertens. 1993;11(6):665-71. [pmid: 8397246].
Reinehr T, de Sousa G, Toschke AM, Andler W. Long-term follow-up of cardiovascular disease risk factors in children after an obesity intervention. Am J Clin Nutr. 2006;84(3):490-6. [pmid: 16960161].
Reneland R, Andersson PE, Haenni A, Lithell H. Metabolic effects of long-term angiotensin-converting enzyme inhibition with fosinopril in patients with essential hypertension: relationship to angiotensin-converting enzyme inhibition. Eur J Clin Pharmacol. 1994;46(5):431-6. [pmid: 7957538].
Resnick LM, Catanzaro D, Sealey JE, Laragh JH. Acute vascular effects of the angiotensin II receptor antagonist olmesartan in normal subjects: relation to the Renin-Aldosterone system. Am J Hypertens. 2004;17(3):203-8. [pmid: 15001191].
Ribeiro AB, Mion D Jr., Marin MJ, Majul C, Botero R, Lopez R, et al. Antihypertensive efficacy of amlodipine and losartan after two ‘missed’ doses in patients with mild to moderate essential hypertension. [Erratum appears in J Int Med Res. 2009;37(1):280 Note: Lopez, N R [corrected to Lopez, R]]. J Int Med Res. 2007;35(6):762-72. [pmid: 18034989].
Ribeiro AB, Mion D, Marin MJ, Majul C, Botero R, Lopez R, et al. Antihypertensive efficacy of amlodipine and losartan after two ‘missed’ doses in patients with mild to moderate essential hypertension. J Int Med Res. 2007;35(6):762-72. [pmid: 18034989].
Richard Hobbs FD, Gensini G, John Mancini GB, Manolis AJ, Bauer B, Genest J, et al. International open-label studies to assess the efficacy and safety of single-pill amlodipine/atorvastatin in attaining blood pressure and lipid targets recommended by country-specific guidelines: the JEWEL programme. Eur J Cardiovasc Prev Rehabil. 2009;16(4):472-80. [pmid: 19407658].
Rippley RK, Connor J, Boyle J, Bradstreet TE, Hand E, Lo MW, et al. Pharmacokinetic assessment of an oral enalapril suspension for use in children. Biopharm Drug Dispos. 2000;21(9):339-44. [pmid: 11523062].
Roca-Cusachs A, Torres F, Horas M, Rios J, Calvo G, Delgadillo J, et al. Nitrendipine and enalapril combination therapy in mild to moderate hypertension: assessment of dose-response relationship by a clinical trial of factorial design. J Cardiovasc Pharmacol. 2001;38(6):840-9. [pmid: 11707687].
Rocchini AP, Katch V, Anderson J, Hinderliter J, Becque D, Martin M, et al. Blood pressure in obese adolescents: effect of weight loss. Pediatrics. 1988;82(1):16-23. [pmid: 3288957].
Rocchini AP. Cardiovascular causes of systemic hypertension. Pediatr Clin North Am. 1993;40(1):141-7. [pmid: 8417402].
Rodd CJ, Sockalosky JJ. Endocrine causes of hypertension in children. Pediatr Clin North Am. 1993;40(1):149-64. [pmid: 8417403].
Rogan JW, Lyszkiewicz DA, Blowey D, Khattak S, Arbus GS, Koren G. A randomized prospective crossover trial of amlodipine in pediatric hypertension. Pediatric Nephrology. 2000;14(12):1083-7. [pmid: 11045391].
Rogstad B. A comparison of lisinopril and nifedipine in the treatment of mild to moderate hypertension. A multicentre study. Eur J Clin Pharmacol. 1994;46(6):487-9. [pmid: 7995312].
Rosenthal J, Bahrmann H, Benkert K, Baumgart P, Bonner G, Klein G, et al. Analysis of adverse effects among patients with essential hypertension receiving an ACE inhibitor or a beta-blocker. Cardiology. 1996;87(5):409-14. [pmid: 8894262].
Roth B, Herkenrath P, Krebber J, Abu-Chaaban M. Nifedipine in hypertensive crises of infants and children. Clin Exp Hypertens A. 1986;A8(4 &5):871-7. [pmid: 3530561].
Rouine-Rapp K, Mello DM, Hanley FL, Mohan Reddy V, Soifer S. Effect of enalaprilat on postoperative hypertension after surgical repair of coarctation of the aorta. Pediatr Crit Care Med. 2003;4(3):327-32. [pmid: 12831415].
Rowlands DB, Glover DR, Ireland MA, McLeay RA, Stallard TJ, Watson RD, et al. Assessment of left-ventricular mass and its response to antihypertensive treatment. Lancet. 1982;1(8270):467-70. [pmid: 6121138].
Ruddy TD, Wright JM, Savard D, Handa SP, Chockalingam A, Boulet AP. Comparison of the efficacy and safety of once-daily versus twice-daily formulations of diltiazem in the treatment of systemic hypertension. The Canadian Multicenter Diltiazem-CD Hypertension Trial Group. Cardiovasc Drugs Ther. 1995;9(3):413-20. [pmid: 8527351].
Ruddy TD, Wright JM, Savard D, Handa SP, Chockalingam A, Fischer L, et al. 24 hour blood pressure control with once-daily versus twice-daily formulations of diltiazem. Cardiovasc Drugs Ther. 1995;9(6):799-807. [pmid: 8850385].
Ruff D, Gazdick LP, Berman R, Goldberg AI, Sweet CS. Comparative effects of combination drug therapy regimens commencing with either losartan potassium, an angiotensin II receptor antagonist, or enalapril maleate for the treatment of severe hypertension. J Hypertens. 1996;14(2):263-70. [pmid: 8728306].
Ruggenenti P, Perna A, Gherardi G, Benini R, Remuzzi G. Chronic proteinuric nephropathies: outcomes and response to treatment in a prospective cohort of 352 patients with different patterns of renal injury. Am J Kidney Dis. 2000;35(6):1155-65. [pmid: 10845831].
Ruilope LM. Comparison of a new vasodilating beta-blocker, carvedilol, with atenolol in the treatment of mild to moderate essential hypertension. Am J Hypertens. 1994;7(2):129-36. [pmid: 7910028].
Ruilope LM. Comparison of a new vasodilating beta-blocker, carvedilol, with atenolol in the treatment of mild to moderate essential hypertension. [Erratum appears in Am J Hypertens 1994;7(4 Pt 1):379]. Am J Hypertens. 1994;7(2):129-36. [pmid: 7910028].
Sakey AH. Anaemia after enalapril in a child with nephrotic syndrome. The Lancet. 1998;352(9124):285. [pmid: 9690411].
Salazar MR, Carbajal HA, Aizpurua M, Riondet B, Rodrigo HF, Rechifort V, et al. Decrease of blood pressure by community-based strategies. Medicina (Mex). 2005;65(6):507-12. [pmid: 16433477].
Salcedo-Alejos M, Banda-Espinoza F, Rodríguez-Morán M, Guerrero-Romero F. Irbesartan reduces creatinine clearance in type 1 diabetic children with renal hyperfunction: a randomized, double-blind, placebo-controlled trial. Nephrol Dial Transplant. 2005;20(10):2120-5. [pmid: 16091379].
Salminen M, Vahlberg T, Kivela SL. Effects of family-oriented risk-based prevention on serum cholesterol and blood pressure values of children and adolescents. Scand J Prim Health Care. 2005;23(1):34-41. [pmid: 16025872].
Sanchez-Benito JL, Sanchez-Soriano E, Suarez JG. Unbalanced intake of fats and minerals associated with hypertension risk in young cyclists. Nutr Hosp. 2007;22(5):552-9. [pmid: 17970538].
Sarnak MJ, Greene T, Wang X, Beck G, Kusek JW, Collins AJ, et al. The effect of a lower target blood pressure on the progression of kidney disease: long-term follow-up of the modification of diet in renal disease study. Ann Intern Med. 2005;142(5):342-51. [pmid: 15738453].
Sasaki R. Nifedipine-induced transient cerebral ischemia in a child with Cockayne syndrome. Anaesthesia. 1997;52(12):1230-40. [pmid: 9485983].
Savoca MR, Domel Baxter S, Ludwig DA, Evans CD, Mackey ML, Wilson ME, et al. A 4-day sodium-controlled diet reduces variability of overnight sodium excretion in free-living normotensive adolescents. J Am Diet Assoc. 2007;107(3):490-4. [pmid: 17324668].
Sayer GP, Britt H, Meza RA, Charles J, Traynor V, Miles DA. The management of hypertension in general practice. Results from the Australian Morbidity and Treatment Survey, 1990-1991. Aust Fam Physician. 1994;23(4):697-700. 2. [pmid: 8198491].
Schaefer F, Litwin M, Zachwieja J, Zurowska A, Turi S, Grosso A, et al. Efficacy and safety of valsartan compared to enalapril in hypertensive children: a 12-week, randomized, double-blind, parallel-group study. J Hypertens. 2011;29(12):2484-90. [pmid: 22025233].
Schaefer F, van de Walle J, Zurowska A, Gimpel C, van Hoeck K, Drozdz D, et al. Efficacy, safety and pharmacokinetics of candesartan cilexetil in hypertensive children from 1 to less than 6 years of age. J Hypertens. 2010;28(5):1083-90. [pmid: 20160654].
Schieken RM, Clarke WR, Lauer RM. Left ventricular hypertrophy in children with blood pressures in the upper quintile of the distribution. The Muscatine Study Hypertension. 1981;3(6):669-75. [pmid: 6457796].
Schiel R, Muller UA, Beltschikow W, Stein G. Trends in the management of arterial hypertension in patients with type 1 and insulin-treated type 2 diabetes mellitus over a period of 10 years (1989/1990-1994/1995). Results of the JEVIN trial. J Diabetes Complications. 2006;20(5):273-9. [pmid: 16949513].
Schilder J, Van den Anker JN. Use of enalapril in neonatal hypertension. Acta Pædiatrica. 1995;84(12):1426-8. [pmid: 8645963].
Schmieder RE, Klingbeil AU, Fleischmann EH, Veelken R, Delles C. Additional Antiproteinuric Effect of Ultrahigh Dose Candesartan: A Double-Blind, Randomized, Prospective Study. J Am Soc Nephrol. 2005;16(10):3038-45. [pmid: 16120821].
Schwartz SL, Hanson C, Lucas C, Rosenblatt S, Rosenstock J, Whittier F, et al. Double-blind, placebo-controlled study of ramipril in diabetics with mild to moderate hypertension. Clin Ther. 1993;15(1):79-87. [pmid: 8458057].
Schwieler JH, Ericsson H, Lofdahl P, Thulin T, Kahan T. Circulatory effects and pharmacology of clevidipine, a novel ultra short acting and vascular selective calcium antagonist, in hypertensive humans. J Cardiovasc Pharmacol. 1999;34(2):268-74. [pmid: 10445679].
Seals DR, Hurley BF, Hagberg JM, Schultz J, Under BJ, Natter L, et al. Effects of training on systolic time intervals at rest and during isometric exercise in men and women 61 to 64 years old. Am J Cardiol. 1985;55(6):797-800. [pmid: 3976527].
Searle M, Dathan R, Dean S, Christensen CC, Westheim A. Doxazosin in combination with atenolol in essential hypertension: a double-blind placebo-controlled multicentre trial. Eur J Clin Pharmacol. 1990;39(3):299-300. [pmid: 2147909].
Sedman AJ, Posvar E. Clinical pharmacology of quinapril in healthy volunteers and in patients with hypertension and congestive heart failure. Angiology. 1989;40(4 Pt 2):360-9. [pmid: 2539762].
Seeman T, Gilik J, Vondrak K, Simkova E, Flogelova H, Hladikova M, et al. Regression of left-ventricular hypertrophy in children and adolescents with hypertension during ramipril monotherapy. Am J Hypertens. 2007;20(9):990-6. [pmid: 17765141].
Semplicini A, Strapazzon G, Papparella I, Sartori M, Realdi A, Macchini L, et al. RGS2 expression and aldosterone: renin ratio modulate response to drug therapy in hypertensive patients. J Hypertens. 2010;28(5):1104-8. [pmid: 20375904].
Sever P, Holzgreve H. Long-term efficacy and tolerability of candesartan cilexetil in patients with mild to moderate hypertension. J Hum Hypertens. 1997;11(2). [pmid: 9331014].
Shand DG. A loading-maintenance regimen for more rapid initiaion of the effect of guanethiaine. Clin Pharmacol Ther. 1975;18:139-44. PMID: N/A.
Sharif M, Evans B, Pylypchuk G. Cough induced by quinapril with resolution after changing to fosinopril. Ann Pharmacother. 1994;28(6):720-2. [pmid: 7919557].
Sharma BK, Sagar S, Wahi PL, Talwar KK, Singh S, Kumar L. Blood pressure in schoolchildren in northwest India. Am J Epidemiol. 1991;134(12):1417-26. [pmid: 1776616].
SHARMA PK, YIUM JJ. Angioedema Associated With Angiotensin II Receptor Antagonist Losartan. South Med J. 1997;90(5):552-3. [pmid: 9160080].
Shinebourne EA, Tam AS, Elseed AM, Paneth M, Lennox SC, Cleland WP. Coarctation of the aorta in infancy and childhood. Br Heart J. 1976;38(4):375-80. [pmid: 1267982].
Siche JP, Baguet JP, Fagret D, Tremel F, de Gaudemaris R, Mallion JM. Effects of amlodipine on baroreflex and sympathetic nervous system activity in mild-to-moderate hypertension. Am J Hypertens. 2001;14(5 Pt 1):424-8. [pmid: 11368462].
Sidorenko VN. Effects of the Medical Resonance Therapy Music on haemodynamic parameter in children with autonomic nervous system disturbances. Integr Physiol Behav Sci. 2000;35(3):208-11. [pmid: 11286373].
Siegler RL, Brewer ED. Effect of sublingual or oral nifedipine in the treatment of hypertension. J Pediatr. 1988;112(5):811-3. [pmid: 3361396].
Silva JMP, Santos Diniz JS, Marino VSP, Lima EM, Cardoso LSB, Vasconcelos MA, et al. Clinical course of 735 children and adolescents with primary vesicoureteral reflux. Pediatr Nephrol. 2006;21(7):981-8. [pmid: 16773411].
Silverberg DS, Smith ES, Juchli B, VanDorsser E. Use of shopping centres in screening for hypertension. Can Med Assoc J. 1974;111(8):769-74. [pmid: 4422766].
Silverstein DM, Palmer J, Baluarte HJ, Brass C, Conley SB, Polinsky MS. Use of calcium-channel blockers in pediatric renal transplant recipients. Pediatr Transplant. 1999;3(4):288-92. [pmid: 10562973].
Simon SR, Black HR, Moser M, Berland WE. Cough and ACE Inhibitors. Arch Intern Med. 1992;152(8):1698-700. [pmid: 1497404].
Simonetti G, Bianchetti M, Konrad M, von Vigier R. Severe anemia caused by the angiotensin receptor blocker irbesartan after renal transplantation. Pediatr Nephrol. 2007;22(5):756-7. [pmid: 17216246].
Simonetti GD, Santoro L, Ferrarini A, Crosazzo-Franscini L, Fossali E, Bianchetti MG, et al. Systemic hypertension and proteinuria in childhood chronic renal parenchymal disease: role of antihypertensive drug management. Paediatr Drugs. 2007;9(6):413-8. [pmid: 18052411].
Sinaiko AR, O'Dea RF, Mirkin BL. Clinical response of hypertensive children to long-term minoxidil therapy. J Cardiovasc Pharmacol. Suppl 2. 1980;2:S181-8. [pmid: 6156354].
Slater EE, Merrill DD, Guess HA, Roylance PJ, Cooper WD, Inman WHW, et al. Clinical Profile of Angioedema Associated With Angiotensin Converting-Enzyme Inhibition. JAMA. 1988;260(7):967-70. [pmid: 2840522].
Smith DH, Matzek KM, Kempthorne-Rawson J. Dose response and safety of telmisartan in patients with mild to moderate hypertension. J Clin Pharmacol. 2000;40(12 Pt 1):1380-90. [pmid: 11185637].
Smits P, Hoffmann H, Thien T, Houben H, van 'T Laar A. Hemodynamic and humoral effects of coffee after B_1_-selective and nonselective B-blockade. Clin Pharmacol Ther. 1983:153-8. [pmid: 6347498].
Soininen K, Gerlin-Piira L, Suihkonen J, Kyllonen T, Parviainen R, Kyllonen E, et al. A study of the effects of lisinopril when used in addition to atenolol. J Hum Hypertens. 1992;6(4):321-4. [pmid: 1331443].
Somers VK, Conway J, Sleight P. The effect of physical training on home blood pressure measurements in normal subjects. J Hypertens. 1986;4(Supplement 6):S657-S8. [pmid: 19129855].
Sorof JM, Turner J, Martin DS, Garcia K, Garami Z, Alexandrov AV, et al. Cardiovascular risk factors and sequelae in hypertensive children identified by referral versus school-based screening. Hypertension. 2004;43(2):214-8. [pmid: 14744920].
Sowmya R, Maruthy KN, Gupta R. Cardiovascular autonomic responses to whole body isotonic exercise in normotensive healthy young adult males with parental history of hypertension. Indian J Physiol Pharmacol. 2010;54(1):37-44. [pmid: 21046918].
Spark RF, O'Hare CM, Regan RM. Low-Renin Hypertension: Restoration of Normotension and Renin Responsiveness. Arch Intern Med. 1974;133(2):205-11. [pmid: 4591266].
Spence JD, Huff M, Barnett PA. Effects of indapamide versus hydrochlorothiazide on plasma lipids and lipoproteins in hypertensive patients: a direct comparison. Can J Clin Pharmacol. 2000;7(1):32-7. [pmid: 10822211].
Stahl M, Bulpitt CJ, Palmer AJ, Beevers DG, Coles EC, Webster J. Calcium channel blockers, ACE inhibitors, and the risk of cancer in hypertensive patients: a report from the Department of Health Hypertension Care Computing Project (DHCCP). J Hum Hypertens. 2000;14(5):299-304. [pmid: 10822315].
Steffen LM, Kroenke CH, Yu X, Pereira MA, Slattery ML, Van Horn L, et al. Associations of plant food, dairy product, and meat intakes with 15-y incidence of elevated blood pressure in young black and white adults: the Coronary Artery Risk Development in Young Adults (CARDIA) Study. Am J Clin Nutr. 2005;82(6):1169-77. [pmid: 16332648].
Stephens MB, Wentz SW. Supplemental fitness activities and fitness in urban elementary school classrooms. Fam Med. 1998;30(3):220-3. [pmid: 9532446].
Stewart JN, McGillivray D, Sussman J, Foster B. The value of routine blood pressure measurement in children presenting to the emergency department with nonurgent problems. J Pediatr. 2008;153(4):478-83. [pmid: 18534208].
Stokes G, MacCarthy P, Frost G, Mennie B, Karplus T, Garrington J. Management of hypertension newly detected by health screening. Med J Aust. 1981;1(10):527-31. [pmid: 7254016].
Strafford MA, Griffiths SP, Gersony WM. Coarctation of the aorta: a study in delayed detection. Pediatrics. 1982;69(2):159-63. [pmid: 7058089].
Strocchi E, Valtancoli G, Ricci C, Malini PL, Bassein L, Ambrosioni E. Post-marketing studies of subjective side effects; a case for strict methodological criteria and careful analysis of data. Pharmacol Res. 1992;25(Supplement 1):79-80. [pmid: 1508819].
Suh I, Nam CM, Jee SH, Kim SI, Lee KH, Kim HC, et al. Twelve-year tracking of blood pressure in Korean school children: the Kangwha Study. Yonsei Med J. 1999;40(4):383-7. [pmid: 10487143].
Sukonthasarn A, Ratanaprakarn R, Koanantakul B, Ngam-Ukos P. Efficacy and acceptability of perindopril in essential hypertension. J Med Assoc Thai. 1994;77(6):281-7. [pmid: 7869013].
Sutherland J, Castle C, Friedman R. Hypertension: current management strategies. J Am Board Fam Pract. 1994;7(3):202-17. [pmid: 8059624].
Szamosi A, Czinner A, Szamosi T, Sallai A, Hatunic M, Berla Z, et al. Effect of diet and physical exercise treatment on insulin resistance syndrome of schoolchildren. J Am Coll Nutr. 2008;27(1):177-83. [pmid: 18460496].
Szelestei T, Kovacs T, Barta J, Nagy J. Circadian blood pressure changes and cardiac abnormalities in IgA nephropathy. Am J Nephrol. 1999;19(5):546-51. [pmid: 10575181].
Szucs T, Schneeweiss A. Cilazapril: an overview of its efficacy and safety in hypertension. Cardiology. 1992;80(1):34-41. [pmid: 1532534].
Tabbutt S, Nicolson SC, Adamson PC, Zhang X, Hoffman ML, Wells W, et al. The safety, efficacy, and pharmacokinetics of esmolol for blood pressure control immediately after repair of coarctation of the aorta in infants and children: a multicenter, double-blind, randomized trial. J Thorac Cardiovasc Surg. 2008;136(2):321-8. [pmid: 18692637].
Tack ED, Perlman JM. Renal failure in sick hypertensive premature infants receiving captopril therapy. J Pediatr. 1988;112(5):805-10. [pmid: 3283314].
Taittonen L, Nuutinen M, Turtinen J, Uhari M. Prenatal and postnatal factors in predicting later blood pressure among children: cardiovascular risk in young Finns. Pediatr Res. 1996;40(4):627-32. [pmid: 8888294].
Takahashi S, Okada K, Yanai M. The Kidney Early Evaluation Program (KEEP) of Japan: results from the initial screening period. Kidney International Supplement. 2010;116(23). [pmid: 20186175].
Tanaka M, Nishikawa T. Oral clonidine premedication attenuates the hypertensive response to ketamine. Br J Anaesth. 1994;73(6):758-62. [pmid: 7880659].
Taylor AA, Shepherd AM, Polvino W, Mangoo-Karim R, Ballard K, Sunthornyothin S, et al. Prolonged fenoldopam infusions in patients with mild to moderate hypertension: pharmacodynamic and pharmacokinetic effects. Am J Hypertens. 1999;12(9 Pt 1):906-14. [pmid: 10509549].
Tekol Y. Maternal and infantile dietary salt exposure may cause hypertension later in life. Birth Defects Research Part B, Developmental and Reproductive Toxicology. 2008;83(2):77-9. [pmid: 18330898].
Testa MA, Turner RR, Simonson DC, Krafcik MB, Calvo C, Luque-Otero M. Quality of life and calcium channel blockade with nifedipine GITS versus amlodipine in hypertensive patients in Spain. Gastrointestinal Therapeutic System. J Hypertens. 1998;16(12 Pt 1):1839-47. [pmid: 9869019].
Thoele DG, Muster AJ, Paul MH. Recognition of coarctation of the aorta. A continuing challenge for the primary care physician. [Erratum appears in Am J Dis Child 1988;142(6):592]. Am J Dis Child. 1987;141(11):1201-4. [pmid: 3673972].
Thompson T, Frable MAS. Drug-Induced, life-threatening angioedema revisited. The Laryngoscope. 1993;103(1):10-2. [pmid: 8380620].
Thompson TR, Andrish JT, Bergfeld JA. A prospective study of preparticipation sports examinations of 2670 young athletes: method and results. Cleve Clin Q. 1982;49(4):225-33. [pmid: 7168912].
Thysell H, Andersson KE, Andersson SI, Ekman R. Angiotensin-converting enzyme inhibition, cough and the serum concentration of substance P. Eur J Clin Pharmacol. 1988;34(6):649-50. [pmid: 2458939].
Tian HG, Guo ZY, Hu G, Yu SJ, Sun W, Pietinen P, et al. Changes in sodium intake and blood pressure in a community-based intervention project in China. J Hum Hypertens. 1995;9(12):959-68. [pmid: 8746640].
Tikkanen I, Omvik P, Jensen HA. Comparison of the angiotensin II antagonist losartan with the angiotensin converting enzyme inhibitor enalapril in patients with essential hypertension. J Hypertens. 1995;13(11):1343-51. [pmid: 8984133].
Timmermans PB, Wong PC, Chiu AT, Herblin WF, Benfield P, Carini DJ, et al. Angiotensin II receptors and angiotensin II receptor antagonists. Pharmacol Rev. 1993;45(2):205-51. [pmid: 8372104].
Tobias JD, Hersey S, Mencio GA, Green NE. Nicardipine for controlled hypotension during spinal surgery. J Pediatr Orthop. 1996;16(3):370-3. [pmid: 8728640].
Tobias JD, Lowe S, Deshpande JK. Nicardipine: perioperative applications in children. Paediatr Anaesth. 1995;5(3):171-6. [pmid: 7489437].
Tobias JD. Nicardipine to control mean arterial pressure after cardiothoracic surgery in infants and children. Am J Ther. 2001;8(1):3-6. [pmid: 11304651].
Tomaki M, Ichinose M, Miura M, Hirayama Y, Kageyama N, Yamauchi H, et al. Angiotensin converting enzyme (ACE) inhibitor-induced cough and substance P. Thorax. 1996;51(2):199-201. [pmid: 8711657].
Torok E, Borbas S, Lengyel M, Zorandi A. Regression of cardiac hypertrophy in hypertensive patients by long-term treatment with isradipine. J Cardiovasc Pharmacol. Suppl 3. 1992;19:S79-83. [pmid: 1376844].
Toto R, Shultz P, Raij L, Mitchell H, Shaw W, Ramjit D, et al. Efficacy and tolerability of losartan in hypertensive patients with renal impairment. Collaborative Group. Hypertension. 1998;31(2):684-91. [pmid: 9461241].
Townsend R, Haggert B, Liss C, Edelman JM. Efficacy and tolerability of losartan versus enalapril alone or in combination with hydrochlorothiazide in patients with essential hypertension. Clin Ther. 1995;17(5):911-23. [pmid: 8595643].
Trevisan M, Cooper R, Ostrow D, Miller W, Sparks S, Leonas Y, et al. Dietary sodium, erythrocyte sodium concentration, sodium-stimulated lithium efflux and blood pressure. Clin Sci. Suppl 7. 1981;61:29s-32s. [pmid: 7318331].
Trevisan R, Tiengo A. Effect of low-dose ramipril on microalbuminuria in normotensive or mild hypertensive non-insulin-dependent diabetic patients. North-East Italy Microalbuminuria Study Group. Am J Hypertens. 1995;8(9):876-83. [pmid: 8541002].
Trimarco B, Cuocolo A, Groothold G, Ricciardelli B, De Luca N, Volpe M, et al. Indenolol: a new antihypertensive agent: efficacy, toxicity, and hemodynamic effects in a crossover double-blind study with metoprolol. J Clin Pharmacol. 1985;25(5):328-36. [pmid: 4031109].
Tucker DT, Smothers M, Lewis C, Feldman H. Effects of decreased dietary salt intake on blood pressure in preschool children. J Natl Med Assoc. 1989;81(3):299-302. [pmid: 2709432].
Tullus K. Safety concerns of angiotensin II receptor blockers in preschool children. Arch Dis Child. 2011;96(9):881+. [pmid: 21690106].
Uchiyama M, Sakai K. Rectal administration of perforated nifedipine capsules in acute severe hypertension in children. Br J Clin Pract. 1992;46(2):100-1. [pmid: 1457294].
Urata H, Tanabe Y, Kiyonaga A, Ikeda M, Tanaka H, Shindo M, et al. Antihypertensive and volume-depleting effects of mild exercise on essential hypertension. Hypertension. 1987;9(3):245-52. [pmid: 3546120].
Vaidyanathan S, Valencia J, Kemp C, Zhao C, Yeh CM, Bizot MN, et al. Lack of pharmacokinetic interactions of aliskiren, a novel direct renin inhibitor for the treatment of hypertension, with the antihypertensives amlodipine, valsartan, hydrochlorothiazide (HCTZ) and ramipril in healthy volunteers. Int J Clin Pract. 2006;60(11):1343-56. [pmid: 17073832].
Valvo E, Bedogna V, Casagrande P. Ambulatory blood pressure measurement in assessing the antihypertensive effect of benazepril plus hydrochlorothiazide in a fixed combination. Clin Ther. 1993;15(4):650-6. [pmid: 8221814].
Van Hoof R, Hespel P, Fagard R, Lijnen P, Staessen J, Amery A. Effect of endurance training on blood pressure at rest, during exercise and during 24 hours in sedentary men. Am J Cardiol. 1989;63(13):945-9. [pmid: 2929469].
Van Nueten L, Schelling A, Vertommen C, Dupont AG, Robertson JI. Nebivolol vs enalapril in the treatment of essential hypertension: a double-blind randomised trial. J Hum Hypertens. 1997;11(12):813-9. [pmid: 9468009].
Van Nueten L, Taylor FR, Robertson JI. Nebivolol vs atenolol and placebo in essential hypertension: a double-blind randomised trial. J Hum Hypertens. 1998;12(2):135-40. [pmid: 9504355].
Van Wijk BLG, Klungel OH, Heerdink ER, de Boer A. Initial non-compliance with antihypertensive monotherapy is followed by complete discontinuation of antihypertensive therapy. Pharmacoepidemiology & Drug Safety. 2006;15(8):587-93. [pmid: 16586465].
Vandenburg MJ, Mackay EM, Dews I, Pullan T, Brugier S. Dose finding studies with imidapril--a new ACE inhibitor. Br J Clin Pharmacol. 1994;37(3):265-72. [pmid: 8198936].
Vandongen R, Jenner DA, Thompson C, Taggart AC, Spickett EE, Burke V, et al. A controlled evaluation of a fitness and nutrition intervention program on cardiovascular health in 10- to 12-year old children. Prev Med. 1995;24(1):9-22. [pmid: 7740021].
Viera AJ, Neutze DM. Diagnosis of secondary hypertension: an age-based approach. Am Fam Physician. 2010;82(12):1471-8. [pmid: 21166367].
Viviani GL. Lercanidipine in type II diabetic patients with mild to moderate arterial hypertension. J Cardiovasc Pharmacol. 2002;40(1):133-9. [pmid: 12072586].
von Vigier RO, Franscini LMD, Bianda NDF, Pfister R, Casaulta-Aebischer C, Bianchetti MG. Antihypertensive efficacy of amlodipine in children with chronic kidney diseases. J Hum Hypertens. 2001;15(6):387-91. [pmid: 11439313].
von Vigier RO, Zberg PM, Teuffel O, Bianchetti MG. Preliminary experience with the angiotensin II receptor antagonist irbesartan in chronic kidney disease. Eur J Pediatr. 2000;159(8):590-3. [pmid: 10968237].
Wade DR Jr., Biggs M, Ahmad I. Hypertensive screening, a community effort. J Tenn Med Assoc. 1974;67(11):909-12. [pmid: 4437166].
Waeber B, Weidmann P, Wohler D, Le Bloch Y. Albuminuria in diabetes mellitus: relation to ambulatory versus office blood pressure and effects of cilazapril. Am J Hypertens. 1996;9(12 Pt 1):1220-7. [pmid: 8972894].
Walker G, Mandagere A, Dufton C, Venitz J. The pharmacokinetics and pharmacodynamics of warfarin in combination with ambrisentan in healthy volunteers. Br J Clin Pharmacol. 2009;67(5):527-34. [pmid: 19552747].
Walter HJ, Hofman A, Connelly PA, Barrett LT, Kost KL. Primary prevention of chronic disease in childhood: changes in risk factors after one year of intervention. Am J Epidemiol. 1985;122(5):772-81. [pmid: 4050769].
Ward HJ, Morisky DE, Lees NB, Fong R. A clinic and community-based approach to hypertension control for an underserved minority population: design and methods. Am J Hypertens. 2000;13(2):177-83. [pmid: 10701818].
Ward KE, Pryor RW, Matson JR, Razook JD, Thompson WM, Elkins RC. Delayed detection of coarctation in infancy: implications for timing of newborn follow-up. Pediatrics. 1990;86(6):972-6. [pmid: 2251033].
Weder AB, Torretti BA, Katch VL, Rocchini AP. The antihypertensive effect of calorie restriction in obese adolescents: dissociation of effects on erythrocyte countertransport and cotransport. J Hypertens. 1984;2(5):507-14. [pmid: 6530554].
Weidmann P. Metabolic profile of indapamide sustained-release in patients with hypertension: data from three randomised double-blind studies. Drug Saf. 2001;24(15):1155-65. [pmid: 11772148].
Weir MR, Weber MA, Punzi HA, Serfer HM, Rosenblatt S, Cady WJ. A dose escalation trial comparing the combination of diltiazem SR and hydrochlorothiazide with the monotherapies in patients with essential hypertension. J Hum Hypertens. 1992;6(2):133-8. [pmid: 1597846].
Weir MR. Speed and duration of dose titration with the angiotensin converting enzyme inhibitor quinapril: relationship with efficacy in patients with moderate hypertension. J Hum Hypertens. 1994;8(9):725-30. [pmid: 7807504].
Weir RJ, Lee PS, Clegg DS, Hemingray S, Belgrave GP, Walter E. A multicentre study to compare the therapeutic efficacy of sustained-release diltiazem and enalapril in the treatment of patients with mild to moderate hypertension. Br J Clin Pract. 1994;48(6):287-92. [pmid: 7848788].
Wells T, Blumer J, Meyers KEC, Neto JPR, Meneses R, Litwin M, et al. Effectiveness and Safety of Valsartan in Children Aged 6 to 16 Years With Hypertension. J Clinic Hypertens. 2011;13(5):357-65. [pmid: 21545397].
Wells T, Rippley R, Hogg R, Sakarcan A, Blowey D, Walson P, et al. The pharmacokinetics of enalapril in children and infants with hypertension. J Clin Pharmacol. 2001;41(10):1064-74. [pmid: 11583474].
Wells TG, Sinaiko AR. Antihypertensive effect and pharmacokinetics of nitrendipine in children. J Pediatr. 1991;118(4 Pt 1):638-43. [pmid: 2007942].
Westaby S, Parnell B, Pridie RB. Coarctation of the aorta in adults. Clinical presentation and results of surgery. J Cardiovasc Surg (Torino). 1987;28(2):124-7. [pmid: 3558457].
Westbrook P, Bednarczyk EM, Carlson M, Sheehan H, Bissada NF. Regression of Nifedipine-induced gingival hyperplasia following switch to a same class calcium channel blocker, isradipine. J Periodontol. 1997;68:645-50. [pmid: 9249636].
Westheim A, Simonsen K, Schanaun O. Effect of exercise training with essential hypertension. Acta Medica Scandinavica - Supplementum. 1986;714(Supplement):99-103. [pmid: 3472452].
Whelton A, Eff J, Magner DJ. Sustained antihypertensive activity of diltiazem SR: double-blind, placebo-controlled study with 24-hour ambulatory blood pressure monitoring. J Clin Pharmacol. 1992;32(9):808-15. [pmid: 1430300].
Whelton PK, He J. Potassium in preventing and treating high blood pressure. Semin Nephrol. 1999;19(5):494-9. [pmid: 10511389].
Wilcox RG, Bennett T, Brown AM, Macdonald IA. Is exercise good for high blood pressure?. Br Med J (Clin Res Ed). 1982;285(6344):767-9. [pmid: 6810991].
Wilford Germino F, Lastra J, Pool P, Punzi H, Spinowitz B, Smith W, et al. Evaluation of the cough profile of fosinopril in hypertensive patients with ACE inhibitor-associated cough--A pilot study. Curr Ther Res Clin Exp. 1993;54(5):469-75. [pmid: 11854791].
Willemsen JM, Rabelink TJ, Boer P, Gaillard CA. Disparate systemic and renal blocking properties of angiotensin II antagonists during exogenous angiotensin II administration: implications for treatment. J Hum Hypertens. 2004;18(12):857-63. [pmid: 15361886].
Williams B, Gosse P, Lowe L, Harper R, Group PIS. The prospective, randomized investigation of the safety and efficacy of telmisartan versus ramipril using ambulatory blood pressure monitoring (PRISMA I). J Hypertens. 2006;24(1):193-200. [pmid: 16331118].
Wilmore JH. Dose-response: variation with age, sex, and health status. Med Sci Sports Exerc. 2001;33(6 Suppl):S622-34. discussion S40-1. [pmid: 11427787].
Wilson AC, Forsyth JS, Greene SA, Irvine L, Hau C, Howie PW. Relation of infant diet to childhood health: seven year follow up of cohort of children in Dundee infant feeding study. BMJ. 1998;316(7124):21-5. [pmid: 9451261].
Wilson TW, Lacourciere Y, Barnes CC. The antihypertensive efficacy of losartan and amlodipine assessed with office and ambulatory blood pressure monitoring. Canadian Cozaar Hyzaar Amlodipine Trial Study Group. Can Med Assoc J. 1998;159(5):469-76. [pmid: 9757170].
Wing LM, Arnolda LF, Harvey PJ, Upton J, Molloy D, Gabb GM, et al. Low-dose diuretic and/or dietary sodium restriction when blood pressure is resistant to ACE inhibitor. Blood Press. 1998;7(5-6):299-307. [pmid: 10321443].
Wingen AM, Fabian-Bach C, Schaefer F, Mehls O. Randomised multicentre study of a low-protein diet on the progression of chronic renal failure in children. The Lancet. 1997;349(9059):1117-23. [pmid: 9113009].
Winnicki M, Bonso E, Dorigatti F, Longo D, Zaetta V, Mattarei M, et al. Effect of body weight loss on blood pressure after 6 years of follow-up in stage 1 hypertension. Am J Hypertens. 2006;19(11):1103-9. [pmid: 17070419].
Woehler TR, Eff J, Graney W, Heald D, Ziemniak J, Magner D. Multicenter evaluation of the efficacy and safety of sustained-release diltiazem hydrochloride for the treatment of hypertension. Clin Ther. 1992;14(2):148-57. [pmid: 1611639].
Wofford MR, King DS, Wyatt SB, Jones DW. Secondary Hypertension: Detection and Management for the Primary Care Provider. J Clin Hypertens (Greenwich). 2000;2(2):124-31. [pmid: 11416635].
Wolk R, Smith WB, Neutel JM, Rubino J, Xuan D, Mancuso J, et al. Blood pressure lowering effects of a new long-acting inhibitor of phosphodiesterase 5 in patients with mild to moderate hypertension. Hypertension. 2009;53(6):1091-7. [pmid: 19398651].
Woo KS, Norris RM, Nicholls G. Racial difference in incidence of cough with angiotensin-converting enzyme inhibitors (a tale of two cities). Am J Cardiol. 1995;75(14):967-8. [pmid: 7733017].
Wu YK, Lu CQ, Gao RC, Yu JS, Liu GC. Nation-wide hypertension screening in China during 1979-1980. Chin Med J (Engl). 1982;95(2):101-8. [pmid: 6807611].
Wuhl E, Mehls O, Schaefer F. Antihypertensive and antiproteinuric efficacy of ramiprilin children with chronic renal failure. Kidney Int. 2004;66(2):768-76. [pmid: 15253732].
Wuhl E, Schaefer F. Therapeutic strategies to slow chronic kidney disease progression. Pediatr Nephrol. 2008;23(5):705-16. [pmid: 18335252].
Yasky J. The benifitial effect of lozartan on angiotnsin-converting enzyme inhibitors (ACE) cough. Am J Hypertens. 1996;9(4, Supplement 1):166A-A. PMID: N/A.
Yeo W, Foster G, Ramsay L. Prevalence of Persistent Cough During Long-term Enalapril Treatment: Controlled Study Versus Nifedipine. QJM. 1991;80(3):763-70. [pmid: 1754676].
Yeo WW, Ramsay LE. Persistent dry cough with enalapril: incidence depends on method used. J Hum Hypertens. 1990;4(5):517-20. [pmid: 2283641].
Yesil S, Yesil M, Bayata S, Postaci N. Ace Inhibitors and Cough. Angiology. 1994;45(9):805-8. [pmid: 8092546].
Yoon SS, Ostchega Y, Louis T. Recent trends in the prevalence of high blood pressure and its treatment and control, 1999-2008. NCHS Data Brief. 2010;(48):1-8. [pmid: 21050532].
Zacest R, Gilmore E, Koch-Wesser J. Treatment of essential hypertension with combined vasodilatation and beta-adrenergic blockage. N Engl J Med. 1972;286:618-22. [pmid: 4401216].
Zanchetti A, Omboni S, Di Biagio C. Candesartan cilexetil and enalapril are of equivalent efficacy in patients with mild to moderate hypertension. J Hum Hypertens. Suppl 2. 1997;11:S57-9. [pmid: 9331009].
Zanchetti A. Concepts of multiple risk factors management: the Gubbio study. J Hypertens - Supplement. 1990;8(1):S3-5. [pmid: 2332815].
Zannad F, Bernaud CM, Fay R. Double-blind, randomized, multicentre comparison of the effects of amlodipine and perindopril on 24 h therapeutic coverage and beyond in patients with mild to moderate hypertension. General Physicians Investigators' Group. J Hypertens. 1999;17(1):137-46. [pmid: 10100105].
Zappe DH, Sowers JR, Hsueh WA, Haffner SM, Deedwania PC, Fonseca VA, et al. Metabolic and antihypertensive effects of combined angiotensin receptor blocker and diuretic therapy in prediabetic hypertensive patients with the cardiometabolic syndrome. J Clin Hypertens. 2008;10(12):894-903. [pmid: 19120715].
Zhao X, Wu F, Jia S, Qu P, Li H, Zhao X, et al. Azelnidipine and amlodipine: a comparison of their effects and safety in a randomized double-blinded clinical trial in Chinese essential hypertensive patients. Clin Exp Hypertens. 2010;32(6):372-6. [pmid: 21029001].
Zhu JR, Bai J, Cai NS, Tang B, Fan WH, Guo JZ, et al. Efficacy and safety of olmesartan medoxomil versus losartan potassium in Chinese patients with mild to moderate essential hypertension. Int J Clin Pract. 2004;Supplement(145):46-9. [pmid: 15617459].
Zhu JR, Bai J, Cai NS, Tang B, Fan WH, Guo JZ, et al. Efficacy and safety of telmisartan vs. losartan in control of mild-to-moderate hypertension: a multicentre, randomised, double-blind study. Int J Clin Pract. 2004;Supplement(145):46-9. [pmid: 15617459].
Zidek W, Spiecker C, Knaup G, Steindl L, Breuer HW. Comparison of the efficacy and safety of nifedipine coat-core versus amlodipine in the treatment of patients with mild-to-moderate essential hypertension. Hypertension Study Group. Clin Ther. 1995;17(4):686-700. [pmid: 8565032].
Zusman RM, Christensen DM, Higgins J, Boucher CA. Effects of fosinopril on cardiac function in patients with hypertension. Radionuclide assessment of left ventricular systolic and diastolic performance. Am J Hypertens. 1992;5(4 Pt 1):219-23. [pmid: 1534664].
Zyczynski TM, Leidy NK, Kong BW, Helaszek CT, Michelson EL, Association of Black Cardiologists Candesartan Study G. Effects of candesartan cilexetil on health-related quality of life in black patients with systemic hypertension in the ABC Trial. Heart Dis. 2000;2(6):400-6. [pmid: 11728290].

### Wrong Intervention

Bal LV, Shugaeva EN, Deev AA, Maslova AR, Aleksandrov AA. Results of a three-year trial of arterial hypertension prevention in a population of children aged 11-15 years by overweight control. Cor Vasa. 1990;32(6):448-56. [pmid: 2085976].
Bayliss H, Churchill D, Beevers M, Beevers DG. Anti-hypertensive drugs in pregnancy and fetal growth: evidence for “pharmacological programming” in the first trimester?. Hypertension in Pregnancy. 2002;21(2):161-74. [pmid: 12175444].
Berg CL, Swanson DJ, Juhl N. Total blood cholesterol and contributory risk factors in an adolescent population. J Sch Health. 1992;62(2):64-6. [pmid: 1564914].
Bradley CB, Harrell JS, McMurray RG, Bangdiwala SI, Frauman AC, Webb JP. Prevalence of high cholesterol, high blood pressure, and smoking among elementary schoolchildren in North Carolina. N C Med J. 1997;58(5):362-7. [pmid: 9313361].
Bunchman TE, Lynch RE, Wood EG. Intravenously administered labetalol for treatment of hypertension in children. J Pediatr. 1992;120(1):140-4. [pmid: 1731011].
Covelli MM. Efficacy of a school-based cardiac health promotion intervention program for African-American adolescents. Appl Nurs Res. 2008;21(4):173-80. [pmid: 18995158].
Cuneo BF, Zales VR, Blahunka PC, Benson DW Jr. Pharmacodynamics and pharmacokinetics of esmolol, a short-acting beta-blocking agent, in children. Pediatr Cardiol. 1994;15(6):296-301. [pmid: 7838803].
Falkner B, Thanki BH. Effect of hospitalization versus placebo in hypertensive adolescents. J Adolesc Health Care. 1982;3(3):173-6. [pmid: 7153164].
Flynn JT, Mottes TA, Brophy PD, Kershaw DB, Smoyer WE, Bunchman TE. Intravenous nicardipine for treatment of severe hypertension in children. J Pediatr. 2001;139(1):38-43. [pmid: 11445792].
Gouyon JB, Geneste B, Semama DS, Francoise M, Germain JF. Intravenous nicardipine in hypertensive preterm infants. Archives of Disease in Childhood Fetal & Neonatal Edition. 1997;76(2):F126-7. [pmid: 9135293].
Kafatos I, Manios Y, Moschandreas J, Kafatos A, Preventive M, Nutrition Clinic University of Crete Research T. Health and nutrition education program in primary schools of Crete: changes in blood pressure over 10 years. Eur J Clin Nutr. 2007;61(7):837-45. [pmid: 17213871].
McCrory WW, Kohaut EC, Lewy JE, Lieberman E, Travis LB. Safety of intravenous diazoxide in children with severe hypertension. Clin Pediatr (Phila). 1979;18(11):661-3. 6. 7. 71. [pmid: 498689].
Milou C, Debuche-Benouachkou V, Semama DS, Germain JF, Gouyon JB. Intravenous nicardipine as a first-line antihypertensive drug in neonates. Intensive Care Med. 2000;26(7):956-8. [pmid: 10990112].
Sorof JM, Turner J, Franco K, Portman RJ. Characteristics of hypertensive children identified by primary care referral compared with school-based screening. J Pediatr. 2004;144(4):485-9. [pmid: 15069397].
Sorof JM, Urbina EM, Cunningham RJ, Hogg RJ, Moxey-Mims M, Eissa MA, et al. Screening for eligibility in the study of antihypertensive medication in children: experience from the Ziac Pediatric Hypertension Study. Am J Hypertens. 2001;14(8 Pt 1):783-7. [pmid: 11497194].
Tenney F, Sakarcan A. Nicardipine is a safe and effective agent in pediatric hypertensive emergencies. Am J Kidney Dis. 2000;35(5):E20-E. [pmid: 10793049].
Treluyer JM, Hubert P, Jouvet P, Couderc S, Cloup M. Intravenous nicardipine in hypertensive children. Eur J Pediatr. 1993;152(9):712-4. [pmid: 8223797].
Vartiainen E, Puska P, Pietinen P, Nissinen A, Leino U, Uusitalo U. Effects of dietary fat modifications on serum lipids and blood pressure in children. Acta Paediatr Scand. 1986;75(3):396-401. [pmid: 3728000].
Wells TG, Graham CJ, Moss MM, Kearns GL. Nifedipine Poisoning in a Child. Pediatrics. 1990;86(1):91-4. [pmid: 2359687].
Grunbaum JA, Rodriguez BL, Labarthe DR. Parental response to identification of elevated blood pressure or cholesterol following school-based screening. J Adolesc Health. 1993;14(2):99-103. [pmid: 8476880].
McLaughlin D, Hayes JR, Kelleher K. Office-based interventions for recognizing abnormal pediatric blood pressures. Clin Pediatr (Phila). 2010;49(4):355-62. [pmid: 19589919].
Rokicki W, Skierska A, Bilewicz-Wyrozumska T. Arterial hypertension in children treated at the Katowice Department of Pediatric Cardiology between 1993-2000. Przegl Lek. 2002;59(9):759-61. [pmid: 12632905].

### Wrong Outcome

Adams MH, Carter TM, Lammon CA, Judd AH, Leeper J, Wheat JR. Obesity and blood pressure trends in rural adolescents over a decade. Pediatr Nurs. 2008;34(5):381-6. [pmid: 19051841].
Adrogué HE, Sinaiko AR. Prevalence of hypertension in junior high school-aged children: Effect of new recommendations in the 1996 updated task force report. Am J Hypertens. 2001;14(5):412-4. [pmid: 11368459].
Alper AB Jr., Chen W, Yau L, Srinivasan SR, Berenson GS, Hamm LL. Childhood uric acid predicts adult blood pressure: the Bogalusa Heart Study. Hypertension. 2005;45(1):34-8. [pmid: 15569853].
Andersen LB, Haraldsdottir J. Tracking of cardiovascular disease risk factors including maximal oxygen uptake and physical activity from late teenage to adulthood. An 8-year follow-up study. J Intern Med. 1993;234(3):309-15. [pmid: 8354982].
Arbeit ML, Johnson CC, Mott DS, Harsha DW, Nicklas TA, Webber LS, et al. The Heart Smart cardiovascular school health promotion: behavior correlates of risk factor change. Prev Med. 1992;21(1):18-32. [pmid: 1738766].
Aristimuno GG, Foster TA, Voors AW, Srinivasan SR, Berenson GS. Influence of persistent obesity in children on cardiovascular risk factors: the Bogalusa Heart Study. Circulation. 1984;69(5):895-904. [pmid: 6705165].
Ashrafi MR, Abdollahi M, Ahranjani BM, Shabanian R. Blood pressure distribution among healthy schoolchildren aged 6-13 years in Tehran. East Mediterr Health J. 2005;11(5-6):968-76. [pmid: 16761667].
Bald M, Westhues R, Bonzel KE. Blood pressure monitoring at the wrist: is it reliable in children and adolescents?. Z Kardiol. 1996;3:106-8. [pmid: 8896309].
Balkrishnan R, Phatak H, Gleim G, Karve S. Assessment of the use of angiotensin receptor blockers in major European markets among paediatric population for treating essential hypertension. J Hum Hypertens. 2009;23(6):420-5. [pmid: 19052566].
Barath A, Turi S, Nemeth I, Bereczki C, Gellen B, Haszon I, et al. Different pathomechanisms of essential and obesity-associated hypertension in adolescents. Pediatric nephrology (Berlin, Germany). 2006;21(10):1419-25. [pmid: 16896999].
Beaglehole R, Salmond CE, Eyles EF. A longitudal study of blood pressue in polynesian children. Am J Epidemiol. 1977;105(1):87-9. [pmid: 831467].
Berenson G, Srinivasan S, Chen W, Li S, Patel D, Bogalusa Heart Study G. Racial (black-white) contrasts of risk for hypertensive disease in youth have implications for preventive care: the Bogalusa Heart Study. Ethn Dis. 2006;16(3 Suppl 4):S4-2-9. [pmid: 16937775].
Berenson GS, Wattigney WA, Webber LS. Epidemiology of hypertension from childhood to young adulthood in black, white, and Hispanic population samples. Public Health Rep. Suppl 2. 1996;111:3-6. [pmid: 8898760].
Blowey DL, Moncica I, Scolnik D, Arbus GS, Hébert D, Balfe JW, et al. The pharmacokinetics of extended release felodipine in children. Eur J Clin Pharmacol. 1996;50(1):147-8. [pmid: 8739826].
Brady TM, Fivush B, Flynn JT, Parekh R. Ability of Blood Pressure to Predict Left Ventricular Hypertrophy in Children with Primary Hypertension. J Pediatr. 2008;152(1):73-8.e1. [pmid: 18154904].
Brosnan CA, Swint JM, Upchurch SL, Meininger JC, Johnson G, Lee YF, et al. The cost of screening adolescents for overweight and hypertension using a community partnership model. Public Health Nurs. 2008;25(3):235-43. [pmid: 18477374].
Chen J, Millar WJ. Health effects of physical activity. Health Rep. 1999;11(1):21-30. (Eng). 21. 31. (Fre). [pmid: 11965821].
Chen W, Srinivasan SR, Li S, Xu J, Berenson GS. Metabolic syndrome variables at low levels in childhood are beneficially associated with adulthood cardiovascular risk: the Bogalusa Heart Study. Diabetes Care. 2005;28(1):126-31. [pmid: 15616245].
Chen W, Srinivasan SR, Ruan L, Mei H, Berenson GS. Adult hypertension is associated with blood pressure variability in childhood in blacks and whites: the bogalusa heart study. Am J Hypertens. 2011;24(1):77-82. [pmid: 20725054].
Chen X, Wang Y, Appel LJ, Mi J. Impacts of measurement protocols on blood pressure tracking from childhood into adulthood: a metaregression analysis. Hypertension. 2008;51(3):642-9. [pmid: 18212267].
Cheung YB, Machin D, Karlberg J, Khoo KS. A longitudinal study of pediatric body mass index values predicted health in middle age. J Clin Epidemiol. 2004;57(12):1316-22. [pmid: 15617958].
Clarke WR, Schrott HG, Leaverton PE, Connor WE, Lauer RM. Tracking of blood lipids and blood pressures in school age children: the Muscatine study. Circulation. 1978;58(4):626-34. [pmid: 688572].
Collins AJ, Li S, Chen SC, Vassalotti JA. Participant follow-up in the Kidney Early Evaluation Program (KEEP) after initial detection. Am J Kidney Dis. 2008;51(4 Suppl 2). [pmid: 18359410].
Cooper MJ, Sinaiko AR, Anders MW, Mirkin BL. High pressure liquid chromatographic determination of hydrochlorothiazide in human serum and urine. Anal Chem. 1976;48(8):1110-1. [pmid: 1275270].
Cooper R, Trevisan M, Van Horn L, Larbi E, Liu K, Nanas S, et al. Effect of dietary sodium reduction on red blood cell sodium concentration and sodium-lithium countertransport. Hypertension. 1984;6(5):731-5. [pmid: 6500678].
Cross AW. Health screening in schools. Part II. J Pediatr. 1985;107(5):653-61. [pmid: 3932628].
Danese A, Moffitt TE, Harrington H, Milne BJ, Polanczyk G, Pariante CM, et al. Adverse childhood experiences and adult risk factors for age-related disease: depression, inflammation, and clustering of metabolic risk markers. Arch Pediatr Adolesc Med. 2009;163(12):1135-43. [pmid: 19996051].
de Swiet M, Fayers P, Shinebourne EA. Blood pressure in first 10 years of life: the Brompton study. BMJ. 1992;304(6818):23-6. [pmid: 1734987].
Diller PM, Huster GA, Leach AD, Laskarzewski PM, Sprecher DL. Definition and application of the discretionary screening indicators according to the National Cholesterol Education Program for Children and Adolescents. J Pediatr. 1995;126(3):345-52. [pmid: 7869190].
Eckenfels EJ, Frate DA, Logan EW, Nelson KE, Schoenberger JA, Shumway DL, et al. Endemic hypertension in a poor, Black rural community: can it be controlled?. J Chronic Dis. 1977;30(8):499-518. [pmid: 893654].
Elmfeldt D, Olofsson B, Meredith P. The Relationships Between Dose and Antihypertensive Effect of Four AT[sub 1]-receptor Blockers Differences in Potency and Efficacy. Blood Press. 2002;11(5):293-301. [pmid: 12458652].
Falkner B, Onesti G, Moshang T Jr., Lowenthal DT. Growth hormone release in hypertensive adolescents treated with clonidine. J Clin Pharmacol. 1981;21(1):31-6. [pmid: 7217341].
Falkner B, Sherif K, Michel S, Kushner H. Dietary nutrients and blood pressure in urban minority adolescents at risk for hypertension. Arch Pediatr Adolesc Med. 2000;154(9):918-22. [pmid: 10980796].
Farris RP, Frank GC, Webber LS, Berenson GS. A nutrition curriculum for families with high blood pressure. J Sch Health. 1985;55(3):110-2. [pmid: 3845257].
Ferreira I, van de Laar RJ, Prins MH, Twisk JW, Stehouwer CD. Carotid stiffness in young adults: a life-course analysis of its early determinants: the Amsterdam Growth and Health Longitudinal Study. Hypertension. 2012;59(1):54-61. [pmid: 22068867].
Flint PM, Middleton DB. Hypertension in children. N Engl J Med. 1997;336(23):1675. author reply 6. [pmid: 9173274].
Foglia CFP, von Vigier RO, Fossali E, Salice P, Ghiglia S, Ardissino G, et al. A simplified antihypertensive drug regimen does not ameliorate control of childhood hypertension. J Hum Hypertens. 2005;19(8):653-4. [pmid: 15905892].
Foster BJ, Ali H, Mamber S, Polomeno RC, Mackie AS. Prevalence and severity of hypertensive retinopathy in children. Clin Pediatr (Phila). 2009;48(9):926-30. [pmid: 19571332].
Freedman DS, Patel DA, Srinivasan SR, Chen W, Tang R, Bond MG, et al. The contribution of childhood obesity to adult carotid intima-media thickness: the Bogalusa Heart Study. Int J Obes. 2008;32(5):749-56. [pmid: 18227845].
Gardin JM, Brunner D, Schreiner PJ, Xie X, Reid CL, Ruth K, et al. Demographics and correlates of five-year change in echocardiographic left ventricular mass in young black and white adult men and women: the Coronary Artery Risk Development in Young Adults (CARDIA) study. J Am Coll Cardiol. 2002;40(3):529-35. [pmid: 12142122].
Gidding SS, Barton BA, Dorgan JA, Kimm SYS, Kwiterovich PO, Lasser NL, et al. Higher self-reported physical activity is associated with lower systolic blood pressure: the Dietary Intervention Study in Childhood (DISC). Pediatrics. 2006;118(6):2388-93. [pmid: 17142523].
Gomez-Marin O, Prineas RJ, Rastam L. Cuff bladder width and blood pressure measurement in children and adolescents. J Hypertens. 1992;10(10):1235-41. [pmid: 1335006].
Haji SA, Ulusoy RE, Patel DA, Srinivasan SR, Chen W, Delafontaine P, et al. Predictors of left ventricular dilatation in young adults (from the Bogalusa Heart Study). Am J Cardiol. 2006;98(9):1234-7. [pmid: 17056336].
Hansen HS, Hyldebrandt N, Froberg K, Nielsen JR. Blood pressure and physical fitness in a population of children--the Odense Schoolchild Study. J Hum Hypertens. 1990;4(6):615-20. [pmid: 2096201].
Higgins MW, Keller JB, Metzner HL, Moore FE, Ostrander LD Jr. Studies of blood pressure in Tecumseh, Michigan. II. Antecedents in childhood of high blood pressure in young adults. Hypertension. 1980;2(4 Pt 2):117-23. [pmid: 7399643].
Hond ED, Celis H, Fagard R, Keary L, Leeman M, O'Brien E, et al. Self-measured versus ambulatory blood pressure in the diagnosis of hypertension. J Hypertens. 2003;21(4):717-22. [pmid: 12658017].
Janz KF, Dawson JD, Mahoney LT. Increases in physical fitness during childhood improve cardiovascular health during adolescence: the Muscatine Study. Int J Sports Med. Suppl 1. 2002;23:S15-21. [pmid: 12012257].
Johnson CB, Meyers AW, Schleser R, Thackwray D. The role of student volunteers in door-to-door hypertension screening. J Community Health. 1984;9(3):206-15. [pmid: 6480888].
Juonala M, Magnussen CG, Venn A, Dwyer T, Burns TL, Davis PH, et al. Influence of age on associations between childhood risk factors and carotid intima-media thickness in adulthood: the Cardiovascular Risk in Young Finns Study, the Childhood Determinants of Adult Health Study, the Bogalusa Heart Study, and the Muscatine Study for the International Childhood Cardiovascular Cohort (i3C) Consortium. Circulation. 2010;122(24):2514-20. [pmid: 21126976].
Juonala M, Viikari JSA, Hutri-Kahonen N, Pietikainen M, Jokinen E, Taittonen L, et al. The 21-year follow-up of the Cardiovascular Risk in Young Finns Study: risk factor levels, secular trends and east-west difference. J Intern Med. 2004;255(4):457-68. [pmid: 15049880].
Kaitosaari T, Ronnemaa T, Viikari J, Raitakari O, Arffman M, Marniemi J, et al. Low-saturated fat dietary counseling starting in infancy improves insulin sensitivity in 9-year-old healthy children: the Special Turku Coronary Risk Factor Intervention Project for Children (STRIP) study. Diabetes Care. 2006;29(4):781-5. [pmid: 16567815].
Kanade A, Deshpande S, Patil K, Rao S. Prevalence of high blood pressure among young rural adults in relation to height in childhood and adult body mass index. J Am Coll Nutr. 2011;30(3):216-23. [pmid: 21896880].
Katz S, Hediger M, Schall J, Bowers E, Barker W, Aurand S, et al. Blood pressure, growth and maturation from childhood through adolescence. Mixed longitudinal analyses of the Philadelphia Blood Pressure Project. Hypertension. 1980;2(4):55-69. [pmid: 7399646].
Kilcoyne MM. Adolescent hypertension. II. Characteristics and response to treatment. Circulation. 1974;50(5):1014-9. [pmid: 4371994].
Kivimaki M, Kinnunen ML, Pitkanen T, Vahtera J, Elovainio M, Pulkkinen L. Contribution of early and adult factors to socioeconomic variation in blood pressure: thirty-four-year follow-up study of school children. [Erratum appears in Psychosom Med. 2004;66(3):3b]. Psychosom Med. 2004;66(2):184-9. [pmid: 15039502].
Koskinen J, Kahanen M, Viikari JSA, Taittonen L, Laitinen T, Rannemaa T, et al. Conventional Cardiovascular Risk Factors and Metabolic Syndrome in Predicting Carotid Intima-Media Thickness Progression in Young Adults. Circulation. 2009;120(3):229-36. [pmid: 19581494].
Kotchen JM, Kotchen TA, Guthrie GP Jr, Cottrill CM, McKean HE. Correlates of Adolescent Blood Pressure at Five-Year Follow-Up. Hypertension. 1980;2(4):I-130. [pmid: 7399644].
Kotchen JM, McKean HE, Kotchen TA. Blood Pressure Trends With Aging. Hypertension. 1982;4(5):III-134. [pmid: 7049927].
Kouidi E, Fahadidou-Tsiligiroglou A, Tassoulas E, Deligiannis A, Coats A. White coat hypertension detected during screening of male adolescent athletes. Am J Hypertens. 1999;12(2):223-6. [pmid: 10090352].
Kruckel K. Hypertension screening in schools--a pilot program. J N Y State Sch Nurse Teach Assoc. 1974;6(1):20-1. [pmid: 4548909].
Kuller LHMD, Crook MRNBSN, Jane MAMS, Detre KMD, Reese GRNMS, Rutan GMPH. Dormont High School (Pittsburgh, Pennsylvania) Blood Pressure Study. Hypertension. 1980;2(4):109-116. [pmid: 7399642].
Lambrechtsen J, Rasmussen F, Hansen HS, Jacobsen IA. Tracking and factors predicting rising in ‘tracking quartile’ in blood pressure from childhood to adulthood: Odense Schoolchild Study. J Hum Hypertens. 1999;13(6):385-91. [pmid: 10408588].
Lauer RM, Clarke WR. Childhood risk factors for high adult blood pressure: the Muscatine Study. Pediatrics. 1989;84(4):633-41. [pmid: 2780125].
Law CM, Shiell AW, Newsome CA, Syddall HE, Shinebourne EA, Fayers PM, et al. Fetal, infant, and childhood growth and adult blood pressure: a longitudinal study from birth to 22 years of age. Circulation. 2002;105(9):1088-92. [pmid: 11877360].
Li L, Wang Y, Cao W, Xu F, Cao J. Longitudinal studies of blood pressure in children. Asia Pac J Public Health. 1995;8(2):130-3. [pmid: 9037811].
Li S, Chen W, Srinivasan SR, Berenson GS. Childhood Blood Pressure as a Predictor of Arterial Stiffness in Young Adults: The Bogalusa Heart Study. Hypertension. 2004;43(3):541-6. [pmid: 14744922].
Li X, Li S, Ulusoy E, Chen W, Srinivasan SR, Berenson GS. Childhood adiposity as a predictor of cardiac mass in adulthood: the Bogalusa Heart Study. Circulation. 2004;110(22):3488-92. [pmid: 15557363].
Liehr P, Meininger JC, Mueller W, Chandler SP, Chan W. Blood pressure reactivity in urban youth during angry and normal talking. J Cardiovasc Nurs. 1997;11(4):85-94. [pmid: 9200022].
Lin JD, Shieh WB, Huang MJ, Huang HS. Diabetes mellitus and hypertension based on the family history and 2-h postprandial blood sugar in the Ann-Lo district (northern Taiwan). Diabetes Res Clin Pract. 1993;20(1):75-85. [pmid: 8344134].
Loirat C, Azancot A, Pillion G, Macher MA, Mouchet B, Gainet B, et al. Sequential echocardiographic study prior and during antihypertensive therapy in children with severe hypertension. Clinical & Experimental Hypertension - Part A, Theory & Practice. 1986;8(4-5):805-10. [pmid: 2944675].
Maggiore A, Piazzi A, De Vinci M, Orecchio F. Sensitivity, specificity and predictive value of body mass index for the screening of juvenile arterial hypertension. [Italian]. Minerva Med. 1991;82(1-2):23-8. [pmid: 2000169].
Magnussen CG, Raitakari OT, Thomson R, Juonala M, Patel DA, Viikari JS, et al. Utility of currently recommended pediatric dyslipidemia classifications in predicting dyslipidemia in adulthood: evidence from the Childhood Determinants of Adult Health (CDAH) study, Cardiovascular Risk in Young Finns Study and Bogalusa Heart Study. Circulation. 2008;117(1):32-42. [pmid: 18071074].
Magnussen CG, Venn A, Thomson R, Juonala M, Srinivasan SR, Viikari JS, et al. The association of pediatric low- and high-density lipoprotein cholesterol dyslipidemia classifications and change in dyslipidemia status with carotid intima-media thickness in adulthood evidence from the cardiovascular risk in Young Finns study, the Bogalusa Heart study, and the CDAH (Childhood Determinants of Adult Health) study. J Am Coll Cardiol. 2009;53(10):860-9. [pmid: 19264243].
Mahoney LT, Schieken RM, Clarke WR, Lauer RM. Left ventricular mass and exercise responses predict future blood pressure. The Muscatine Study. Hypertension. 1988;12(2):206-13. [pmid: 3410529].
Mahyar A, Ebrahemi M, Shahsavari A, Rahmani Y. Blood pressure of primary-school children of Eghbalieh city, Islamic Republic of Iran. East Mediterr Health J. 2009;15(6):1449-54. [pmid: 20218137].
McDonald A, Trevisan M, Cooper R, Stamler R, Gosch F, Ostrow D, et al. Epidemiological studies of sodium transport and hypertension. Hypertension. 1987;10(5 Pt 2):I42-7. [pmid: 2824365].
Meagher D, Mann KV. The effect of an educational program on knowledge & attitudes about blood pressure by junior high school students: a pilot project. Can J Cardiovasc Nurs. 1990;1(5):15-22. [pmid: 2285455].
Menon S, Berezny KY, Kilaru R, Benjamin DK, Kay JD, Hazan L, et al. Racial differences are seen in blood pressure response to fosinopril in hypertensive children. Am Heart J. 2006;152(2):394-9. [pmid: 16875928].
Michels VV, Bergstralh EJ, Hoverman VR, O'Fallon WM, Weidman WH. Tracking and prediction of blood pressure in children. Mayo Clin Proc. 1987;62(10):875-81. [pmid: 3657303].
Morsing P, Adler G, Brandt-Eliasson U, Karp L, Ohlson K, Renberg L, et al. Mechanistic Differences of Various AT1-Receptor Blockers in Isolated Vessels of Different Origin. Hypertension. 1999;33(6):1406-13. [pmid: 10373224].
Nahata MC, Morosco RS, Hipple TF. Stability of amldipine besylate in two liquid dosage forms. J Am Pharm Assoc (Wash). 1999;39:375-7. [pmid: 10363465].
Nakanishi K, Iijima K, Ishikura K, Hataya H, Awazu M, Sako M, et al. Efficacy and safety of lisinopril for mild childhood IgA nephropathy: a pilot study. Pediatr Nephrol. 2009;24(4):845-9. [pmid: 18825420].
Nelson MJ, Ragland DR, Syme SL. Longitudinal prediction of adult blood pressure from juvenile blood pressure levels. Am J Epidemiol. 1992;136(6):633-45. [pmid: 1442730].
Ogden CL, Kuczmarski RJ, Flegal KM, Mei Z, Guo S, Wei R, et al. Centers for Disease Control and Prevention 2000 Growth Charts for the United States: Improvements to the 1977 National Center for Health Statistics Version. Pediatrics. 2002;109(1):45-60. [pmid: 11773541].
Ovbiagele B, Hutchison P, Handschumacher L, Gutierrez M, Yellin-Mednick S, Beanes S, et al. Urban high school students can successfully screen for high blood pressure in their community. Ethn Dis. 2010;20(3). [pmid: 20828092].
Ovbiagele B, Hutchison P, Handschumacher L, Gutierrez M, Yellin-Mednick S, Beanes S, et al. Impact of an urban community hypertension screening program on participating high school students. Ethn Dis. 2011;21(1):68-73. [pmid: 21462733].
Palacios C, Wigertz K, Martin BR, Braun M, Pratt JH, Peacock M, et al. Racial differences in potassium homeostasis in response to differences in dietary sodium in girls. Am J Clin Nutr. 2010;91(3):597-603. [pmid: 20007307].
Parati G, Stergiou GS. Self measured and ambulatory blood pressure in assessing the ‘white-coat’ phenomenon. J Hypertens. 2003;21(4):677-82. [pmid: 12658008].
Perichart-Perera O, Balas-Nakash M, Schiffman-Selechnik E, Barbato-Dosal A, Vadillo-Ortega F. Obesity increases metabolic syndrome risk factors in school-aged children from an urban school in Mexico city. J Am Diet Assoc. 2007;107(1):81-91. [pmid: 17197275].
Peterson S, Sheffer S, Roth SL, Bennett PA, Lloyd L. Noninvasive screening for risk factors of type 2 diabetes in young, rural, caucasian children. J Sch Nurs. 2010;26(4):301-9. [pmid: 20335231].
Podraza J, Roberts TA. Identification, evaluation, and management of pediatric obesity in military academic and nonacademic settings. Mil Med. 2008;173(12):1199-202. [pmid: 19149339].
Prebis JW, Gruskin AB, Polinsky MS, Baluarte HJ. Uric acid in childhood essential hypertension. J Pediatr. 1981;98(5):702-7. [pmid: 7229748].
Prentice D, Kilty HL, Stearne K, Dobbin SW. Prevalence of cardiovascular risk factors in grade nine students. Can J Cardiovasc Nurs. 2008;18(3):12-6. [pmid: 18727282].
Rokkedal Nielsen J, Hansen HS, Froberg K, Pedersen PK, Oxhoj H. Left ventricular hypertrophy induced by elevated blood pressure and physical activity. Echocardiographic assessment in children and young adults. Scand J Clin Lab Invest Suppl. 1989;192:32-6. [pmid: 2523557].
Rosner B, Hennekens CH, Kass EH, Miall WE. Age-specific correlation analysis of longitudinal blood pressure data. Am J Epidemiol. 1977;106(4):306-13. [pmid: 910798].
Saito I, Nishino M, Kawabe H, Wainai H, Hasegawa C, Saruta T, et al. Leisure time physical activity and insulin resistance in young obese students with hypertension. Am J Hypertens. 1992;5(12 Pt 1):915-8. [pmid: 1285941].
Schwandt P, Bischoff-Ferrari HA, Staehelin HB, Haas GM. Cardiovascular risk screening in school children predicts risk in parents. Atherosclerosis. 2009;205(2):626-31. [pmid: 19223031].
Schwartz GJ, Munoz A, Schneider MF, Mak RH, Kaskel F, Warady BA, et al. New Equations to Estimate GFR in Children with CKD. J Am Soc Nephrol. 2009;20(3):629-37. [pmid: 19158356].
Shahinfar S, Rippley R, Hogg RJ. Multicenter study of enalapril pharmacokinetics in hypertensive children and infants. Pediatr Res. 2000;47(4). PMID: N/A.
Shea S, Rabinowitz D, Stein AD, Basch CE. Components of variability in the systolic blood pressures of preschool children. Am J Epidemiol. 1998;147(3):240-9. [pmid: 9482498].
Shear CL, Burke GL, Freedman DS, Berenson GS. Value of childhood blood pressure measurements and family history in predicting future blood pressure status: results from 8 years of follow-up in the Bogalusa Heart Study. Pediatrics. 1986;77(6):862-9. [pmid: 3714379].
Shield JPH, Lynn R, Wan KC, Haines L, Barrett TG. Management and 1 year outcome for UK children with type 2 diabetes. Arch Dis Child. 2009;94(3):206-9. [pmid: 18838418].
Sinaiko AR. Clinical pharmacology of converting enzyme inhibitors, calcium channel blockers and diuretics. J Hum Hypertens. 1994;8(5):389-94. [pmid: 8064788].
Slover RH, Klingensmith GJ, Gotlin RW, Radcliffe J. A Comparison of Clonidine and Standard Provocative Agents of Growth Hormone. Am J Dis Child. 1984;138(3):314-7. [pmid: 6322574].
Soergel M, Kirschstein M, Busch C, Danne T, Gellermann J, Holl R, et al. Oscillometric twenty-four-hour ambulatory blood pressure values in healthy children and adolescents: A multicenter trial including 1141 subjects. J Pediatr. 1997;130(2):178-84. [pmid: 9042117].
Starner TM, Peters RM. Anger expression and blood pressure in adolescents. J Sch Nurs. 2004;20(6):335-42. [pmid: 15560731].
Steinberger J, Moran A, Hong CP, Jacobs Jr, DR Sinaiko AR. Adiposity in childhood predicts obesity and insulin resistance in young adulthood. J Pediatr. 2001;138(4):469-73. [pmid: 11295707].
Stenhoff H, Lagerström PO, Andersen C. Determination of candesartan cilexetil, candesartan and a metabolite in human plasma and urine by liquid chromatography and fluorometric detection. J Chromatogr B Biomed Sci Appl. 1999;731(2):411-7. [pmid: 10510797].
Sturkenboom MCJM, Dieleman JP, Picelli G, Mazzaglia G, Mozaffari E, Filippi A, et al. Prevalence and treatment of hypertensive patients with multiple concomitant cardiovascular risk factors in The Netherlands and Italy. J Hum Hypertens. 2008;22(10):704-13. [pmid: 18668128].
Tan F, Okamoto M, Suyama A, Miyamoto T. Tracking of cardiovascular risk factors and a cohort study on hyperlipidemia in rural schoolchildren in Japan. J Epidemiol. 2000;10(4):255-61. [pmid: 10959608].
Toprak A, Wang H, Chen W, Paul T, Srinivasan S, Berenson G. Relation of childhood risk factors to left ventricular hypertrophy (eccentric or concentric) in relatively young adulthood (from the Bogalusa Heart Study). Am J Cardiol. 2008;101(11):1621-5. [pmid: 18489940].
Trudeau F, Shephard RJ, Arsenault F, Laurencelle L. Tracking of physical fitness from childhood to adulthood. Can J Appl Physiol. 2003;28(2):257-71. [pmid: 12825334].
Tulio S, Egle S, Greily B. Blood pressure response to exercise of obese and lean hypertensive and normotensive male adolescents. J Hum Hypertens. 1995;9(12):953-8. [pmid: 8746639].
Urbina EM, Gidding SS, Bao W, Pickoff AS, Berdusis K, Berenson GS. Effect of Body Size, Ponderosity, and Blood Pressure on Left Ventricular Growth in Children and Young Adults in the Bogalusa Heart Study. Circulation. 1995;91(9):2400-6. [pmid: 7729027].
Voors A, Dalferes E, Frank G, Aristimuno G, Berenson G. Relation between ingested potassium and sodium balance in young Blacks and whites. Am J Clin Nutr. 1983;37(4):583-94. [pmid: 6837493].
Voors AW, Berenson GS, Dalferes ER, Webber LS, Shuler SE. Racial differences in blood pressure control. Science. 1979;204(4397):1091-4. [pmid: 451554].
Webb NJA, Lam C, Loeys T, Shahinfar S, Strehlau J, Wells TG, et al. Randomized, double-blind, controlled study of losartan in children with proteinuria. Clin J Am Soc Nephrol. 2010;5(3):417-24. [pmid: 20089489].
White C, Macpherson C, Hurley R, Matsell D. Antiproteinuric effects of enalapril and losartan: a pilot study. Pediatr Nephrol. 2003;18(10):1038-43. [pmid: 12920631].
Yong LC, Kuller LH, Rutan G, Bunker C. Longitudinal study of blood pressure: changes and determinants from adolescence to middle age. The Dormont High School follow-up study, 1957-1963 to 1989-1990. Am J Epidemiol. 1993;138(11):973-83. [pmid: 8256782].
Yong LC, Kuller LH. Tracking of Blood Pressure from Adolescence to Middle Age: The Dormont High School Study. Prev Med. 1994;23(4):418-26. [pmid: 7971868].
Zanozdra NS, Chernoguz LS, Kupchinskaia EG, Krishchuk AA, Savitskii S, Popova LI. Effect of the treatment on hemodynamic indicators and plasma testosterone level in patients with juvenile hypertension. Klin Med (Mosk). 1990;68(7):89-92. [pmid: 2232659].
Zugelj U, Zupancic M, Komidar L, Kenda R, Varda NM, Gregoric A. Self-reported adherence behavior in adolescent hypertensive patients: the role of illness representations and personality. J Pediatr Psychol. 2010;35(9):1049-60. [pmid: 20430840].

### Wrong Study Design for Key Question

Administration FaD. Summaries of Medical and Clinical Pharmacology Reviews of Pediatric Studies; Availability. Department Of Health And Human Services. 2008. PMID: N/A.
Alpert BS. Exercise as a therapy to control hypertension in children. Int J Sports Med. Suppl 2. 2000;21:S94-6. discussion S7. [pmid: 11142600].
Andersen J, Groshong T, Tobias JD. Preliminary experience with amlodipine in the pediatric population. Am J Ther. 2006;13(3):198-204. [pmid: 16772760].
Aschinberg LC, Zeis PM, Miller RA, John EG, Chan LL. Essential hypertension in childhood. JAMA. 1977;238(4):322-4. [pmid: 577536].
Bass JK, Faix RG. Gestational therapy with an angiotensin II receptor antagonist and transient renal failure in a premature infant. Am J Perinatol. 2006;23(5):313-7. [pmid: 16799914].
Bennett DL. Hypertension in adolescents. Ala J Med Sci. 1974;11(3):198-206. [pmid: 4451259].
Boerth RC, Long WR. Dose-response relation of diazoxide in children with hypertension. Circulation. 1977;56(6):1062-6. [pmid: 923046].
Boxer M. Accupril- and Cozaar-induced angioedema in the same patient. J Allergy Clin Immunol. 1996;98(2):471. [pmid: 8757229].
Calvetta A, Martino S, von Vigier RO, Schmidtko J, Fossali E, Bianchetti MG. “What goes up must immediately come down!” Which indication for short-acting nifedipine in children with arterial hypertension?. Pediatr Nephrol. 2003;18(1):1-2. [pmid: 12520323].
Chaturvedi S, Licht C, Parekh R, Craig JC. Pharmacological interventions for essential hypertension in children. Cochrane Database of Systematic Reviews. 2009;(1). PMID: N/A.
Collins R, Somes G, Alpert B. Differences in Arterial Compliance Among Normotensive Adolescent Groups: Collins Arterial Compliance in Adolescents. Pediatr Cardiol. 2008;29(5):929-34. [pmid: 18437445].
Craig SB, Bandini LG, Lichtenstein AH, Schaefer EJ, Dietz WH. The impact of physical activity on lipids, lipoproteins, and blood pressure in preadolescent girls. Pediatrics. 1996;98(3 Pt 1):389-95. [pmid: 8784362].
DiPietro A, Kees-Folts D, DesHarnais S, Camacho F, Wassner SJ. Primary hypertension at a single center: treatment, time to control, and extended follow-up. Pediatr Nephrol. 2009;24(12):2421-8. [pmid: 19714367].
Falkner B, Lowenthal DT, Onesti G. Dynamic exercise response in hypertensive adolescent on clonidine therapy: clonidine therapy in adolescent hypertension. Pediatr Pharmacol (New York). 1980;1(2):121-8. [pmid: 7346736].
Garbus SB, Garbus S, Paul J. Mass screening for hypertension. New Orleans, Louisiana: a public screening project. Urban Health. 1975;4(3):47-8. [pmid: 10238374].
Kupferman JC, Paterno K, Mahgerefteh J, Pagala M, Golden M, Lytrivi ID, et al. Improvement of left ventricular mass with antihypertensive therapy in children with hypertension. Pediatr Nephrol. 2010;25(8):1513-8. [pmid: 20393750].
Laeis P, Puchler K, Kirch W. The pharmacokinetic and metabolic profile of olmesartan medoxomil limits the risk of clinically relevant drug interaction. J Hypertens - Supplement. 2001;19(1):s21-s32. [pmid: 11451211].
Lande MB, Meagher CC, Fisher SG, Belani P, Wang H, Rashid M. Left Ventricular Mass Index in Children with White Coat Hypertension. J Pediatr. 2008;153(1):50-4. [pmid: 18571535].
Leonard AR, Igra A, Hawthorne A. Status of high blood pressure control in California: a preliminary report of a statewide survey. Heart Lung. 1981;10(2):255-60. [pmid: 6907260].
Litwin M, Niemirska A, Sladowska-Kozlowska J, Wierzbicka A, Janas R, Wawer ZT, et al. Regression of target organ damage in children and adolescents with primary hypertension. Pediatr Nephrol. 2010;25(12):2489-99. [pmid: 20730452].
MacDonald J, Johnson C, Jacobson P. Stability of isradipine in an extemporaneously compounded oral liquid. Am J Health Syst Pharm. 1994;51(19):2409-11. [pmid: 7847406].
Mizuno M, Sada T, Ikeda M, Fukuda N, Miyamoto M, Yanagisawa H, et al. Pharmacology of CS-866, a novel nonpeptide angiotensin II receptor antagonist. Eur J Pharmacol. 1995;285(2):181-8. [pmid: 8566137].
Muntner P, He J, C JA. Trends in blood pressure among children and adolescents. JAMA. 2004;291:2107. [pmid: 15126439].
Neuhauser HK, Rosario AS, Thamm M, Ellert U. Prevalence of children with blood pressure measurements exceeding adult cutoffs for optimal blood pressure in Germany. Eur J Cardiovasc Prev Rehabil. 2009;16(2):195-200. [pmid: 19378395].
Nevins TE. Why do they do that?. Pediatr Nephrol. 2005;20(7):845-8. [pmid: 15912377].
Oberfield SE, Rapaport R, Levine LS, New MI. Long-term treatment of childhood hypertension with captopril. Pediatr Ann. 1982;11(7):614-6. 20. 1. [pmid: 6810289].
Parker ML, Robinson RF, Nahata MC. Amlodipine therapy in pediatric patients with hypertension. J Am Pharm Assoc (Wash). 2002;42(1):114-7. [pmid: 11833502].
Pollock E, Wines W. A survey of blood pressure in 10-year-old children of a health district together with a consideration of screening policy for hypertension. Community Med. 1981;3(3):199-204. [pmid: 7273690].
Rocchini AP. Angiotensin receptor blockers for the treatment of hypertension in children. Clin Pediatr (Phila). 2011;50(9):791-6. [pmid: 21127084].
Rohatagi S, Lee J, Shenouda M, Haworth S, Bathala MS, Allison M, et al. Pharmacokinetics of Amlodipine and Olmesartan After Administration of Amlodipine Besylate and Olmesartan Medoxomil in Separate Dosage Forms and as a Fixed-Dose Combination. J Clin Pharmacol. 2008;48(11):1309-22. [pmid: 18974285].
Schwocho L, Masonson H. Pharmacokinetics of CS-866, a new angiotensin II receptor blocker, in healthy subjects. J Clin Pharmacol. 2001;41(5):515-27. [pmid: 11361048].
Silverstein DM, Champoux E, Aviles DH, Vehaskari VM. Treatment of primary and secondary hypertension in children. Pediatr Nephrol. 2006;21(6):820-7. [pmid: 16703375].
Stergiou GS, Alamara CV, Kalkana CB, Vaindirlis IN, Stefanidis CJ, Dacou-Voutetakis C, et al. Out-of-office blood pressure in children and adolescents: Disparate findings by using home or ambulatory monitoring. Am J Hypertens. 2004;17(10):869-75. [pmid: 15485747].
Stergiou GS, Yiannes NG, Rarra VC. Validation of the Omron 705 IT oscillometric device for home blood pressure measurement in children and adolescents: The Arsakion School Study. Blood Press Monit. 2006;11(4):229-34. [pmid: 16810034].
Stergiou GS, Yiannes NG, Rarra VC, Panagiotakos DB. Home blood pressure normalcy in children and adolescents: the Arsakeion School study. J Hypertens. 2007;25(7):1375-9. [pmid: 17563558].
Strauser LM, Groshong T, Tobias JD. Initial experience with isradipine for the treatment of hypertension in children. South Med J. 2000;93(3):287-93. [pmid: 10728516].
Strauser LM, Pruitt RD, Tobias JD. Initial experience with fenoldopam in children. Am J Ther. 1999;6(5):283-8. [pmid: 11329109].
Troiano RP, Flegal KM, Kuczmarski RJ, Campbell SM, Johnson CL. Overweight Prevalence and Trends for Children and Adolescents: The National Health and Nutrition Examination Surveys, 1963 to 1991. Arch Pediatr Adolesc Med. 1995;149(10):1085-91. [pmid: 7550810].

### No Original Data

Detection of hypertension in childhood. Br Med J. 1973;3(5876):365-6. [pmid: 4730181].
Atherosclerosis prevention in children. West J Med. 1975;122(4):355-6. [pmid: 1154777].
Hypertension in childhood. Lancet. 1979;2(8147):833-4. [pmid: 90925].
Arterial hypertension in children: few clinical trials. Prescrire Int. 2010;19(108):181. [pmid: 20939458].
Losartan and hypertensive children. Another option for a small number of children. Prescrire Int. 2010;19(108):160. [pmid: 20939445].
Adelman RD, Coppo R, Dillon MJ. The emergency management of severe hypertension. Pediatr Nephrol. 2000;14(5):422-7. [pmid: 10805473].
Adelman RD. Hypertension in infants. Pediatr Ann. 4. 1989;18(9):562-5. 7-8 passim. [pmid: 2780118].
Adelman RD. The hypertensive neonate. Clin Perinatol. 1988;15(3):567-85. [pmid: 3066552].
Alpert BS. Exercise in hypertensive children and adolescents: any harm done?. Pediatr Cardiol. 1999;20(1):66-9. discussion 70. [pmid: 9861083].
Anonymous. Hypertension control. Report of a WHO Expert Committee. [Review] [120 refs]. World Health Organ Tech Rep Ser. 1996;862:1-83. [pmid: 8669153].
Ardissino G, Edefonti A, Bianchetti MG, Corti C, Fossali E, Gioventu M, et al. Criteri diagnostici e terapeutici dell'ipertensione arteriosa in età pediatrica. Giornale Italiano di Nefrologia. 2006;23(2):149-62. PMID: N/A. [pmid: 16710820].
Arroll B, Beaglehole R. Does physical activity lower blood pressure: a critical review of the clinical trials. J Clin Epidemiol. 1992;45(5):439-47. [pmid: 1588350].
Assadi FK, Wang HE, Lawless S, McKay CP, Hopp L, Fattori D. Angiotensin converting enzyme inhibitor-induced angioedema: a report of two cases. Pediatr Nephrol. 1999;13(9):917-9. [pmid: 10603148].
Bailey EN, Kiehl PS, Akram DS, Loughlin HH, Metcalf TJ, Jain R, et al. Screening in pediatric practice. [Review] [273 refs]. Pediatr Clin North Am. 1974;21(1):123-65. [pmid: 4590155].
Balfe JW, Levin L, Tsuru N, Chan JC. Hypertension in childhood. Adv Pediatr. 1989;36:201-46. [pmid: 2675569].
Balfe JW, Rance CP. Recognition and management of hypertensive crises in childhood. Pediatr Clin North Am. 1978;25(1):159-74. [pmid: 628562].
Bauer JH, Reams G. Short- and long-term effects of calcium entry blockers on the kidney. Am J Cardiol. 1987;59(2):A66-A71. [pmid: 3544786].
Benabe JE, Rios EV. Kidney disease in the Hispanic population: facing the growing challenge. J Natl Med Assoc. 2004;96(6):789-98. [pmid: 15233489].
Ben-Dov IZ, Bursztyn M. Ambulatory blood pressure monitoring in childhood and adult obesity. Curr Hypertens Rep. 2009;11(2):133-42. [pmid: 19278603].
Ben-Dov IZ, Bursztyn M. Ambulatory blood pressure monitoring in childhood and adult obesity. Curr Hypertens Rep. 2009;11(2):133-42. [pmid: 19278603].
Berenson GS, Voors AW, Webber LS, Frerichs RR. Blood pressure in children and its interpretation. Pediatrics. 1978;61(2):333-6. [pmid: 634708].
Berenson GS, Wattigney WA, Bao W, Nicklas TA, Jiang X, Rush JA. Epidemiology of early primary hypertension and implications for prevention: the Bogalusa Heart Study. J Hum Hypertens. 1994;8(5):303-11. [pmid: 8064774].
Berenson GS. The control of hypertension in African-American children: the Bogalusa Heart Study. J Natl Med Assoc. 1995;87(8 Suppl):614-7. [pmid: 7674355].
Bergstein JM. A practical approach to proteinuria. Pediatr Nephrol. 1999;13(8):697-700. [pmid: 10502130].
Bianchetti MG, Ardissino G, Fossali E, Ramelli GP, Salice P. Tips for the use of antihypertensive drugs: DELTAREPROSI. J Pediatr. 2004;145(3):288-90. [pmid: 15343175].
Bianchetti MG, Caflisch M, Oetliker OH. Cough and converting enzyme inhibitors. Eur J Pediatr. 1992;151(3):225-6. PMID: N/A. [pmid: 1601018].
Biron P, Mongeau JG, Bertrand D. Familial Aggregation of Blood Pressure in Childhood Is Hereditary. Pediatrics. 1974;54(5):659-60. [pmid: 4453481].
Blaszak RT, Savage JA, Ellis EN. The use of short-acting nifedipine in pediatric patients with hypertension. J Pediatr. 2001;139(1):34-7. [pmid: 11445791].
Blaufox MD. Systemic arterial hypertension in pediatric practice. Pediatr Clin North Am. 1971;18(2):577-93. [pmid: 4939565].
Bloom BS. Daily regimen and compliance with treatment. BMJ. 2001;323(7314):647. [pmid: 11566816].
Blowey DL. Approach to the pharmacologic treatment of pediatric hypertension. Portman RJ, Sorof JM, Ingelfinger JR, editors. Pediatric hypertension. Totowa, New Jersey. Humana Press. 2004:429-42. PMID: N/A.
Blowey DL. Safety of the newer antihypertensive agents in children. Expert Opinion on Drug Safety. 2002;1(1):39-43. [pmid: 12904158].
Blumenthal S, Epps RP, Heavenrich R, Lauer RM, Lieberman E, Mirkin B, et al. Report of the task force on blood pressure control in children. Pediatrics. 1977;59(5 2 suppl):I-II. 797. 820. [pmid: 859728].
Blumenthal S. Precursors in childhood of primary hypertension in the adult. Ann N Y Acad Sci. 1978;304:28-32. [pmid: 360922].
Brogden RN, Sorkin EM. Isradipine: an update of its pharmacodynamic and pharmacokinetic properties and therapeutic efficacy in the treatment of mild to moderate hypertension. Drugs. 1995;49(4):618-49. [pmid: 7789292].
Buck C. The detection of essential hypertension in childhood. Am Heart J. 1975;89(4):540-1. [pmid: 1114986].
Buckley MMT, Grant SM, Goa KL, McTavish D, Sorkin EM. Diltiazem: a reappraisal of its pharmacological properties and therapeutic use. Drugs. 1990;39(5):757-806. [pmid: 2191851].
Calhoun DA. Use of Aldosterone Antagonists in Resistant Hypertension. Prog Cardiovasc Dis. 48(6):387-96. [pmid: 16714158].
Carmon M, Hauber RP, Howell C, Rice M. Cardiovascular screening programs: implications for school nurses. Pediatr Nurs. 1990;16(5):509-11. [pmid: 2216580].
Chantler C. Paediatric hypertension. Midwife Health Visit Community Nurse. 1983;19(2):42-8. [pmid: 6550176].
Chesney RW, Jones DP. Is there a role for beta-adrenergic blockers in treating hypertension in children?. J Pediatr. 2007;150(2):121-2. [pmid: 17236884].
Chishti AS. Ambulatory blood pressure monitoring. A pediatric review. Saudi Med J. 2003;24(12):1292-5. [pmid: 14710271].
Chobanian AV. Overview and Other Metabolic Issues and Concerns. J Cardiovasc Pharmacol. 1984;6(Supplement 3):s483-s6. [pmid: 6208416].
Clavijo G, de Clavijo I, Weart C. Amlodipine: a new calcium antagonist. Am J Health Syst Pharm. 1994;51(1):59-68. [pmid: 8135260].
Collins RT 2nd, Alpert BS. Pre-hypertension and hypertension in pediatrics: don't let the statistics hide the pathology. J Pediatr. 2009;155(2):165-9. [pmid: 19619748].
Cretens ML. A hypertension screening program of children in Delta and Menominee countries (Michigan). J Am Med Wom Assoc. 1977;32(6):216-7. [pmid: 194946].
Cretens ML. Early detection of hypertension proved valuable in UP. Mich Med. 1976;75(10). [pmid: 979672].
Cromwell PF, Munn N, Zolkowski-Wynne J. Evaluation and management of hypertension in children and adolescents (part two): evaluation and management. J Pediatr Health Care. 2005;19(5):309-13. [pmid: 16202839].
Cumming AM. Paediatrics: hypertension in juvenile patients. Nurs Times. 1980;76(6):245-7. [pmid: 6899150].
Dawber TR, Kannel WB. Susceptibility to coronary heart disease. Mod Concepts Cardiovasc Dis. 1961;30:671-4. [pmid: 13720286].
De Santo NG, Capasso G, Giordano DR, Massimo L. Secondary forms of hypertension. Semin Nephrol. 1989;9(3):272-86. [pmid: 2675246].
de Swiet M, Dillon MJ, Littler W, O'Brien E, Padfield PL, Petrie JC. Measurement of blood pressure in children Recommendations of a working party of the British Hypertension Society. BMJ. 1989;299(6697):19. [pmid: 2503193].
de Swiet M, Dillon MJ. Hypertension in children. [Erratum appears in BMJ 1989;299(6702):754]. BMJ. 6697. 299(6697):469-70. [pmid: 2507022].
de Swiet M, Dillon MJ. Hypertension in children. BMJ. 1989;299(6697):469-70. [pmid: 2507022].
Dillon MJ. Recent advances in evaluation and management of childhood hypertension. Eur J Pediatr. 1979;132(3):133-9. [pmid: 510316].
Dougall HT, McLay J. A comparative review of the adverse effects of calcium antagonists. Drug Saf. 1996;15:91-106. [pmid: 8884161].
Dworkin L, Shemin D. Antihypertensive therapy and progression of chronic renal disease. Curr Hypertens Rep. 1999;1(5):417-22. [pmid: 10981100].
Earley A, de Swiet M, Shinebourne AE. Problems of hypertension in childhood. Practitioner. 1979;223(1334):203-8. [pmid: 41231].
Egger DW, Deming DD, Hamada N, Perkin RM, Sahney S. Evaluation of the safety of short-acting nifedipine in children with hypertension. Pediatr Nephrol. 2002;17(1):35-40. [pmid: 11793132].
Elmfeldt D, Berglund G, Wedel H, Wilhelmsen L. Incidence and importance of metabolic side-effects during antihypertensive therapy. Acta Med Scand. 1983;213(S672):79-83. [pmid: 6138939].
Engle MA, Ehlers KH, Klein AA, Levin AR. Hypertension in the infant, child, and adolescent. Cardiovasc Clin. 1978;9(1):291-310. [pmid: 352520].
Epstein FH. How useful is a family history of hypertension as a predictor of future hypertension?. Ann Clin Res. 1984;43:32-4. [pmid: 6535441].
Fagard RH. Prescription and results of physical activity. J Cardiovasc Pharmacol. Suppl 1. 1995;25:S20-7. [pmid: 7752665].
Feber J, Ahmed M. Hypertension in children: new trends and challenges. Clin Sci. 2010;119(4):151-61. [pmid: 20477751].
Feld LG, Springate JE. Hypertension in children. Curr Probl Pediatr. 1988;18(6):317-73. [pmid: 3048906].
Finnerty FA. Hypertension Is Different in Blacks. JAMA. 1971;216(10):1634-5. PMID: N/A. [pmid: 5108502].
Fitton A, Benfield P. Isradipine. A review of its pharmacodynamic and pharmacokinetic properties, and therapeutic use in cardiovascular disease. Drugs. 1990;40(1):31-74. [pmid: 2143980].
Flynn JT, Falkner BE. Should the current approach to the evaluation and treatment of high blood pressure in children be changed?. J Pediatr. 2009;155(2):157-8. [pmid: 19619744].
Flynn JT, Falkner BE. The importance of blood pressure screening in children. J Pediatr. 2009;155(2):299-300. [pmid: 19619758].
Flynn JT, Flynn JT. Hypertension in the young: epidemiology, sequelae and therapy. Nephrol Dial Transplant. 2009;24(2):370-5. [pmid: 18996836].
Flynn JT, Flynn JT. Pediatric hypertension: recent trends and accomplishments, future challenges. Am J Hypertens. 2008;21(6):605-12. [pmid: 18437129].
Flynn JT. Nifedipine in the treatment of hypertension in children. J Pediatr. 2002;140(6):787-8. [pmid: 12072894].
Friedman A. Blood pressure screening in children: do we have this right?. J Pediatr. 2008;153(4):452-3. [pmid: 18847615].
Frishman W. New therapeutic modalities in hypertension: focus on a new calcium antagonist-nicardipine. J Clin Pharmacol. 1989;29(6):481-7. [pmid: 2666449].
Garfunkel JM. Hypertension in apparently normal children. J Pediatr. 1971;78(4):733-4. [pmid: 5547837].
Gaudio KM, Ross BA, Siegel NJ. Hypertension in children and adolescents. Prim Care. 1983;10(1):125-34. [pmid: 6553935].
Gill D. Childhood hypertension. Br Med J. 1977;2(6087):637. [pmid: 902011].
Gillman MW. Childhood prevention of hypertensive cardiovascular disease. J Pediatr. 2009;155(2):159-61. [pmid: 19619745].
Gillum RF. Management of hypertension. J Pediatr. 1980;97(6):1039. [pmid: 7441415].
Goonasekera CD, Dillon MJ. Measurement and interpretation of blood pressure. Arch Dis Child. 2000;82(3):261-5. [pmid: 10685936].
Grobbee DE, Hofman A. Results of intervention studies of blood pressure in childhood and adolescence. Scand J Clin Lab Invest Suppl. 1989;192:19-31. [pmid: 2652277].
Grobbee DE. Predicting hypertension in childhood: value of blood pressure measurement and family history. J Am Coll Nutr. 1992;11. [pmid: 1619201].
Grossman E, Messerli FH, Grodzicki T, Kowey P. Should a Moratorium Be Placed on Sublingual Nifedipine Capsules Given for Hypertensive Emergencies and Pseudoemergencies?. JAMA. 1996;276(16):1328-31. [pmid: 8861992].
Grossman N. Usefulness of screening for hypertension. Pediatrics. 1984;73(6). [pmid: 6728598].
Haria M, Wagstaff AJ. Amlodipine: A reappraisal of its pharmacological properites and therapeutic use in cardiovascular disease. Drugs. 1995;50(3):560-86. [pmid: 8521773].
Hayashi K, Ozawa Y, Fujiwara K, Wakino S, Kumagai H, Saruta T. Role of Actions of Calcium Antagonists on Efferent Arterioles – with Special References to Glomerular Hypertension. Am J Nephrol. 2003;23(4):229-44. [pmid: 12840599].
He FJ, MacGregor GA. Importance of salt in determining blood pressure in children: meta-analysis of controlled trials. Hypertension. 2006;48(5):861-9. [pmid: 17000923].
He FJ, Macgregor GA. Salt and blood pressure in children: reply to commentary by Alderman. J Hum Hypertens. 2008;22(1):71-2. [pmid: 17823596].
Heale WF. The management of hypertension in children. Aust Fam Physician. 1980;9(12):849-50. [pmid: 7213221].
Herder SD, Weber E, Winkemann A, Herder C, Morck H. Efficacy and safety of angiotensin II receptor type 1 antagonists in children and adolescents. Pediatr Nephrol. 2010;25(5):801-11. [pmid: 19936798].
Hindmarsh PC, Brook CG. Evidence for an association between birth weight and blood pressure. Acta Paediatrica Supplement. 1999;88(428):66-9. [pmid: 10102055].
Holliday MA, Anderson AS, Barness LA, Goldbloom RB, Haworth JC, Mauer AM, et al. Salt intake and eating patterns of infants and children in relation to blood pressure. Pediatrics. 1974;53(1):115-21. PMID: N/A.
Hollis K. Hypertension in children and adolescents. Adv Nurse Pract. 2009;17(6):52-4. [pmid: 20000186].
Houtman PN, Dillon MJ. Routine measurement of blood pressure in schoolchildren. Arch Dis Child. 1991;66(5):567-8. [pmid: 2039242].
Houtman PN, Dillon MJ. Screening for hypertension in fit children. J Hum Hypertens. 1991;5(5):345-8. [pmid: 1770463].
Houtman PN, Dillon MJ. Screening for hypertension in fit children. J Hum Hypertens. 1991;5(5):345-8. [pmid: 1770463].
Husserl FE, Messerli FH. Adverse effects of antihypertensive drugs. Drugs. 1981;22(3):118-210. [pmid: 7021123].
Ichikawa I. Angiotensin Receptors: What is New?. Am J Kidney Dis. 2000;35(5):8-10. PMID: N/A.
Ilsley CD, Millar JA. Hypertension in children. BMJ. 1985;290(6480):1451-2. [pmid: 3922530].
Inc DS. Benicar (olmesartan medomoxil) tablets: US prescribing information. benicarcom. 2011. PMID: N/A.
Ingelfinger JR. Pediatric hypertension. Curr Opin Pediatr. 1994;6(2):198-206. [pmid: 8032401].
Ingelfinger JR. Sodium and blood pressure in infancy. JAMA. 1983;250(3):389-90. [pmid: 6854907].
Kannel WB, dawber TR. Hypertension is an ingredient of a cardiovascular risk profile. Br J Hosp Med. 1974;11:508-23. PMID: N/A.
Kannel WB. Current Status of the Epidemiology of Brain Infarction Associated with Occlusive Arterial Disease. Stroke. 1971;2(4):295-318. [pmid: 5113790].
Kaplan NM. Resistant hypertension. J Hypertens. 2005;23(8):1441-4. [pmid: 16003165].
Kaplan NM. Systemic Hypertension: Mechanisms and Diagnosis (Chapter 37). 2005. PMID: N/A.
Kilcoyne MM. Adolescent hypertension. Am J Med. 1975;58(6):735-9. [pmid: 1094826].
Kilcoyne MM. Techniques of screening. Bull N Y Acad Med. 1976;52(6):657-64. [pmid: 1067880].
Klein AA, McCrory WW, Engle MA. Hypertension in children. Cardiovasc Clin. 1980;11(2):11-33. [pmid: 7011539].
Kloke HJ, Branten AJ, Huysmans FT, Wetzels JF. Antihypertensive treatment of patients with proteinuric renal diseases: Risks or benefits of calcium channel blockers?. Kidney Int. 1998;53(6):1559-73. [pmid: 9607186].
Kollias A, Antonodimitrakis P, Grammatikos E, Chatziantonakis N, Grammatikos EE, Stergiou GS. Trends in high blood pressure prevalence in Greek adolescents. J Hum Hypertens. 2009;23(6):385-90. [pmid: 19158825].
Kotchen JM, Holley J, Kotchen TA. Treatment of high blood pressure in the young. Semin Nephrol. 1989;9(3):296-303. [pmid: 2675247].
Kouda K, Nakamura H, Nishio N, Fujita Y, Takeuchi H, Iki M. Trends in body mass index, blood pressure, and serum lipids in Japanese children: Iwata population-based annual screening (1993-2008). J Epidemiol. 2010;20(3):212-8. [pmid: 20208399].
Labarthe DR, Eissa M, Varas C. Childhood precursors of high blood pressure and elevated cholesterol. Annu Rev Public Health. 1991;12:519-41. [pmid: 2049146].
Lee J, Lauer RM. Pediatric aspects of atherosclerosis and hypertension. Pediatr Clin North Am. 1978;25(4):909-29. [pmid: 733370].
Leeder JS, Kearns GL. Pharmacogenetics in pediatrics: Implications for Practice. Pediatr Clin North Am. 1997;44(1):55-77. [pmid: 9057784].
Leonard AR, Igra A, Felten PG. California's approach to hypertension control: an overview. West J Med. 1983;139(3):388-94. [pmid: 6688903].
Leversha AM, Wilson NJ, Clarkson PM, Calder AL, Ramage MC, Neutze JM. Efficacy and dosage of enalapril in congenital and acquired heart disease. Arch Dis Child. 1994;70(1):35-9. [pmid: 8110005].
Levin SE. Blood pressure levels in children and essential hypertension. S Afr Med J. 1981;60(17):645-6. [pmid: 7302711].
Levy F. Clonidine: adverse responses. J Paediatr Child Health. 1998;34(6):501-2. [pmid: 9928638].
Lieberman E. Essential hypertension in children and youth: a pediatric perspective. J Pediatr. 1974;85(1):1-11. [pmid: 4604441].
Loggie JM. Hypertension in children and adolescents. Hosp Pract. 1975;10:81-92. PMID: N/A.
Loggie JM. Hypertension in children and adolescents. I. Causes and diagnostic studies. J Pediatr. 1969;74(3):331-5. [pmid: 4885043].
Londe S, Goldring D, Gollub SW, Hernandez A. Blood pressure and hypertension in children: studies, problems and perspectives. new MJ, Levine LS, editors. Juvinile hypertension. New York. Raven press. 1977:13-24. PMID: N/A.
Londe S, Goldring D. High blood pressure in children: problems and guidelines for evaluation and treatment. Am J Cardiol. 1976;37(4):650-7. [pmid: 1258802].
Lurbe E, Alvarez V, Redon J. Predictors of progression in hypertensive renal disease in children. J Clin Hypertens. 2004;6(4):186-91. [pmid: 15073472].
Lurbe E, Cifkova R, Cruickshank JK, Dillon MJ, Ferreira I, Invitti C, et al. Management of high blood pressure in children and adolescents: recommendations of the European Society of Hypertension. J Hypertens. 2009;27(9):1719-42. [pmid: 19625970].
Lurbe E, Parati G, Lurbe E, Parati G. Out-of-office blood pressure measurement in children and adolescents. J Hypertens. 2008;26(8):1536-239. [pmid: 18622226].
Lüscher TF, Cosentino F. The Classification of Calcium Antagonists and their Selection in the Treatment of Hypertension: A Reappraisal. Drugs. 1998;55(4):509-17. [pmid: 9561341].
MacNab IF. Hypertension in school-children: the case for screening. Health Visit. 1987;60(11):381-3. [pmid: 3679850].
Martins D, Tareen N, Norris KC. The Epidemiology of End-Stage Renal Disease among African Americans. Am J Med Sci. 2002;323(2):65-71. [pmid: 11863081].
McCrindle BW. Cardiovascular risk factors in adolescents: relevance, detection, and intervention. Adolesc Med State Art Rev. 2001;12(1):147-62. [pmid: 11224028].
McCrory WW. Essential hypertension in childhood. Pediatr Ann. 1982;11(7):585-6. 90. [pmid: 7110747].
McEnery PT, Davis CA. Nonpharmacologic interventions in hypertension. Pediatr Clin North Am. 1978;25(1):127-36. [pmid: 628560].
Menghetti E, Fossali E, Perego L, Virdis R. A study on hypertension in schoolchildren. Riv Eur Sci Med Farmacol. 1993;15(1):57-60. [pmid: 8159839].
Meraw SJ, Sheridan PJ. Medically induced gingival hyperplasia. Mayo Clin Proc. 1998;73(12):1196-9. [pmid: 9868421].
Michalets EL. Update: Clincally Significant Cytochrome P-450 Drug Interactions. Pharmacotherapy. 1998;18(1):84-112. [pmid: 9469685].
Miller NE. Plasma Lipoproteins, Antihypertensive Drugs and Coronary Heart Disease. J Cardiovasc Pharmacol. 1985;7(Supplement 2):S105-S9. [pmid: 2409358].
Mire DE, Silfani TN, Pugsley MK. A Review of the Structural and Functional Features of Olmesartan Medoxomil, An Angiotensin Receptor Blocker. J Cardiovasc Pharmacol. 2005;46(5):585-93. [pmid: 16220064].
Mitchell SC, Blount SG, Blumenthal S, Hoffman JIE, Jesse MJ, Lauer RM, et al. The pediatrician and hypertension. Pediatrics. 1975;56(1):3-5. [pmid: 1153251].
Mollohan CJ. Hypertension programs in schools. J Sch Health. 1986;56(6):237-9. [pmid: 3638444].
Mongeau JG. Hypertension in children. Patterns of inheritance and implications for screening and management. Drugs. 1989;38(2):175-9. [pmid: 2766961].
Moore WE, Stephens A, Wilson T, Wilson W, Eichner JE. Body mass index and blood pressure screening in a rural public school system: the Healthy Kids Project. Prev Chronic Dis. 2006;3(4). [pmid: 16978489].
Muir VJ, Keating GM. Olmesartan medoxomil: in children and adolescents with hypertension. Drugs. 2010;70(18):2439-47. [pmid: 21142262].
Murdoch D, Heel RC. Amlodipine: a review of its pharmacodynamic and pharmacokinitec properties and therapeutic use in cardiovascular disease. Drugs. 1991;41(3):478-505. [pmid: 1711448].
National Pulmonary Hypertension Centres of the UK, Ireland. Consensus statement on the management of pulmonary hypertension in clinical practice in the UK and Ireland. Thorax. 2008;63(2). [pmid: 18308974].
Nehal US, Ingelfinger JR. Pediatric hypertension: recent literature. Curr Opin Pediatr. 2002;14(2):189-96. [pmid: 11981289].
Neutel JM. Combination therapy as initial treatment for hypertension. Manag Care. 2004;13(7 Suppl):5-11. discussion 2-6. [pmid: 15352768].
Norman M. Preterm birth--an emerging risk factor for adult hypertension?. Semin Perinatol. 2010;34(3):183-7. [pmid: 20494733].
North AF Jr. Hypertension in children. J Pediatr. 1971;79(3):510-2. [pmid: 5567978].
Norwood VF. Hypertension. Pediatr Rev. 2002;23(6):197-208. [pmid: 12042594].
Nussinovitch N, Elishkevitz K, Rosenthal T, Nussinovitch M. Screening for hypertension in high school. Clin Pediatr (Phila). 2005;44(8):711-4. [pmid: 16211196].
Page LB, Sidd JJ. Medical management of primary hypertension (first of three parts). N Engl J Med. 1972;287(19):960-7. [pmid: 4562224].
Page LB. Nutritional determinants of hypertension. Curr Concepts Nutr. 1981;10:113-26. [pmid: 7249679].
Palmer BF. Angiotensin-converting enzyme inhibitors and angiotensin receptor blockers: what to do if the serum creatinine and/or serum potassium concentration rises. Nephrol Dial Transplant. 2003;18(10):1973-5. [pmid: 13679467].
Pascual-Castroviejo I, SI PP. Nicardipine-induced gingival hyperplasia. Neurologia. 1997;12(1):37-9. [pmid: 9131913].
Patel HP, Mitsnefes M. Advances in the pathogenesis and management of hypertensive crisis. Curr Opin Pediatr. 2005;17(2):210-4. [pmid: 15800414].
Perazella MA. Drug-induced hyperkalemia: old culprits and new offenders. Am J Med. 2000;109(4):307-14. [pmid: 10996582].
Perez-Stable E, Caralis PV. Thiazide-induced disturbances in carbohydrate, lipid, and potassium metabolism. Am Heart J. 1983;106(1, Part 2):245-51. [pmid: 6869206].
Peters RM, Flack JM. Diagnosis and treatment of hypertension in children and adolescents. J Am Acad Nurse Pract. 2003;15(2):56-63. [pmid: 12640940].
Phillips LS, Branch WT, Cook CB, Doyle JP, El-Kebbi IM, Gallina DL, et al. Clinical Inertia. Ann Intern Med. 2001;135(9):825-34. [pmid: 11694107].
Pinto A, Roldan R, Sollecito TP. Hypertension in children: an overview. J Dent Educ. 2006;70(4):434-40. [pmid: 16595536].
Porter CbJ, Garson A, Gillette PC. Verapamil: An Effective Calcium Blocking Agent for Pediatric Patients. Pediatrics. 1983;71(5):748-55. [pmid: 6340050].
Purcell HJ, Gibbs JS, Coats AJ, Fox KM. Ambulatory blood pressure monitoring and circadian variation of cardiovascular disease; clinical and research applications. Int J Cardiol. 1992;36(2):135-49. [pmid: 1512052].
Pylypchuk G. ACE inhibitor- versus angiotensin II blocker-induced cough and angioedema. Ann Pharmacother. 1998;32(10):1060-6. [pmid: 9793599].
Reece SM. Toward the prevention of coronary heart disease: screening of children and adolescents for high blood cholesterol. Nurse Pract. 1995;20(2):24-6. [pmid: 7715864].
Reichgott MJ. Issues in the pharmacologic management of primary hypertension in adolescence. J Adolesc Health Care. 1987;8(1):92-104. [pmid: 3546230].
Reinehr T, Wabitsch M, Andler W, Beyer P, Bottner A, Chen-Stute A, et al. Medical care of obese children and adolescents. APV: a standardised multicentre documentation derived to study initial presentation and cardiovascular risk factors in patients transferred to specialised treatment institutions. Eur J Pediatr. 2004;163(6):308-12. [pmid: 15346912].
Reisman L, Selden RV. Management of systemic hypertension in children. Pediatr Ann. 1982;11(7):604-5. 7. 10. 12. 3. [pmid: 7050855].
Remuzzi G, Ruggenenti P, Perico N. Chronic Renal Diseases: Renoprotective Benefits of Renin–Angiotensin System Inhibition. Ann Intern Med. 2002;136(8):604-15. [pmid: 11955029].
Resnicow K, Futterman R, Vaughan RD. Body mass index as a predictor of systolic blood pressure in a multiracial sample of US schoolchildren. Ethn Dis. 1993;3(4):351-61. [pmid: 7888986].
Rodicio JL. Calcium Antagonists and Renal Protection from Cyclosporine Nephrotoxicity: Long-term Trial in Renal Transplantation Patients. J Cardiovasc Pharmacol. 2000;(3):S7-S11. [pmid: 11347860].
Rowland TW. Physical fitness in children: implications for the prevention of coronary artery disease. Curr Probl Pediatr. 1981;11(9):1-54. [pmid: 7026178].
Sahney S. A review of calcium channel antagonists in the treatment of pediatric hypertension. Paediatr Drugs. 2006;8(6):357-73. [pmid: 17154643].
Saji H, Yamanaka M, Hagiwara A, Ijiri R. Losartan and fetal toxic effects. The Lancet. 2001;357(9253):363. [pmid: 11211003].
Schieken RM. New perspectives in childhood blood pressure. Curr Opin Cardiol. 1995;10(1):87-91. [pmid: 7787269].
Scott LJ, McCormack PL. Olmesartan Medoxomil: A Review of its Use in the Management of Hypertension. Drugs. 2008;68:1239-72. [pmid: 18547134].
Seals DR, Hagberg JM. The effect of exercise training on human hypertension: a review. Med Sci Sports Exerc. 1984;16(3):207-15. [pmid: 6748915].
Sedman AB, Kershaw DB, Bunchman TE. Recognition and management of angiotensin converting enzyme inhibitor fetopathy. Pediatr Nephrol. 1995;9(3):382-5. [pmid: 7632538].
Shand DG. Propranolol. N Engl J Med. 1975;293:280-5. PMID: N/A. [pmid: 1094291].
Shulman N, Birge J. Mass screening for hypertension. Atlanta, Georgia: screening and health education in school systems. Urban Health. 1975;4(3):44-5. [pmid: 10238373].
Sica DA. Minoxidil: An Underused Vasodilator for Resistant or Severe Hypertension. J Clinic Hypertens. 2004;6(5):283-7. [pmid: 1513341].
Simonetti GD, Fossali E, Ramelli GP. Prise en charge pharmacologique de l'hypertension arterielle chronique chez l'enfant: KISS, please. Rev Med Suisse. 2005;1:1307-10. [pmid: 15962631].
Sinaiko AR, Daniels SR. The use of short-acting nifedipine in children with hypertension: another example of the need for comprehensive drug testing in children. J Pediatr. 2001;139(1):7-9. [pmid: 11445783].
Sinaiko AR, Mirkin BL. Therapeutic agents for pediatric hypertension. Pediatr Ann. 1977;6(6):401-9. [pmid: 865911].
Sinaiko AR. Hypertension in children. N Engl J Med. 1996;335(26):1968-73. [pmid: 8960478].
Smith RJH, Alexander J, Barlow PN, Botto M, Cassavant TL, Cook HT, et al. New Approaches to the Treatment of Dense Deposit Disease. J Am Soc Nephrol. 2007;18(9):2447-56. [pmid: 17675665].
Soffer BA, Shahinfar S, Shaw W, Zhang Z, Herrera P, Frame V, et al. A042: Effects of the ACE inhibitor, enalapril, in children age 6-16 years with hypertension. Am J Hypertens. 2000;13(S2):126A-A. PMID: N/A.
Spizzirri F, Rahman R. Adverse reactions to short-acting nifedipine in hypertensive crises. Pediatr Nephrol. 1999;13:366. [pmid: 10454793].
Spratlen LP. Nurse-role dimensions of a school-based hypertension screening, education, and follow-up program. J Sch Health. 1982;52(3):174-8. [pmid: 6916960].
Spratlen LP. School-based hypertension screening as a clinical unit experience for nursing students. J Nurs Educ. 1983;22(9):386-9. [pmid: 6100855].
Stergiou GS, Yiannes NJ, Rarra VC, Alamara CV. White-coat hypertension and masked hypertension in children. Blood Press Monit. 2005;10(6):297-300. [pmid: 16496441].
Stevenson DR. Blood pressure and age in cross-cultural perspective. Hum Biol. 1999;71(4):529-51. [pmid: 10453101].
Stranges S, Cappuccio FP. Children under pressure: an underestimated burden?. Arch Dis Child. 2007;92(4):288-90. [pmid: 17376935].
Strong WB, Deckelbaum RJ, Gidding SS, Kavey RE, Washington R, Wilmore JH, et al. Integrated cardiovascular health promotion in childhood A statement for health professionals from the Subcommittee on Atherosclerosis and Hypertension in Childhood of the Council on Cardiovascular Disease in the Young, American Heart Association. Circulation. 1992;85(4):1638-50. [pmid: 1555307].
Temple ME, Nahata MC. Treatment of pediatric hypertension. Pharmacotherapy. 2000;20(2):140-50. [pmid: 10678292].
Torok E, Gyarfas I, Csukas M. International collaborative study on juvenile hypertension. 1. Study procedures and screening data. Bull World Health Organ. 1981;59(2):295-304. [pmid: 6972820].
Torrance B, McGuire KA, Lewanczuk R, McGavock J. Overweight, physical activity and high blood pressure in children: a review of the literature. Vascular Health & Risk Management. 2007;3(1):139-49. [pmid: 17583184].
Toyo-Oka T, Nayler WG. Third Generation Calcium Entry Blockers. Blood Press. 1996;5(4):206-8. [pmid: 8809370].
Treiber FA, McCaffrey F, Musante L, Rhodes T, Davis H, Strong WB, et al. Ethnicity, family history of hypertension and patterns of hemodynamic reactivity in boys. Psychosom Med. 1993;55(1):70-7. [pmid: 8446745].
Truttmann AC, Zehnder-Schlapbach S, Bianchetti MG. A moratorium should be placed on the use of short acting nifedipine for hypertensive crises. Pediatr Nephrol. 1998;12(3):259. [pmid: 9630050].
Uhari M, Nuutinen M, Turtinen J, Pokka T. Pulse sounds and measurement of diastolic blood pressure in children. Lancet. 1991;338(8760):159-61. [pmid: 1677074].
Varda NM, Gregorič A. A diagnostic approach for the child with hypertension. Pediatr Nephrol. 2005;20(4):499-506. [pmid: 15723196].
Vessey JA, Ben-Or K, Mebane DJ, Krapac NE, Cobb N, Poltrack M, et al. Evaluating the value of screening for hypertension: an evidence-based approach. J Sch Nurs. 2001;17(1):44-9. [pmid: 11885106].
von Vigier RO, Bianchetti MG. Arterial hypertension in childhood and adolescence. [German]. Ther Umsch. 1999;56(1):12-8. [pmid: 10067129].
von Vigier RO, Mozzettini S, Truttmann AC, Meregalli P, Ramelli GP, Bianchetti MG. Cough Is Common in Children Prescribed Converting Enzyme Inhibitors. Nephron. 2000;84(1):98. [pmid: 10644922].
Warner GT, Jarvis B. Olmesartan Medoxomil. Drugs. 2002;62(9):1345-53. [pmid: 12076183].
Watt GC, Foy CJ, Holton DW, Edwards HE. Prediction of high blood pressure in young people: the limited usefulness of parental blood pressure data. J Hypertens. 1991;9(1):55-8. [pmid: 1848260].
Weidman WH. High blood pressure [hypertension] and the school-age child. J Sch Health. 1979;49(4):213-4. [pmid: 256591].
Weidmann P, Schneider MP, Bohlen L. Therapeutic efficacy of different antihypertensive drugs in human diabetic nephropathy: an updated meta-analysis. Nephrol Dial Transplant. 1995;10(Supplement 9):39-45. [pmid: 8643207].
Wells TG. Antihypertensive therapy: basic pharmacokinetic and pharmacodynamic principles as applied to infants and children. Am J Hypertens. 2002;15(2 Pt 2):34S-7S. [pmid: 11866226].
Wenzel U. Aldosterone antagonists: Silver bullet or just sodium excretion and potassium retention?. Kidney Int. 2007;71(5):374-6. [pmid: 17315004].
Wolf GL. Adolescent hypertension and cardiovascular disease prevention. J Am Coll Health Assoc. 1973;22(2):113-9. [pmid: 4781432].
Wood JE, Barrow JG, Freis ED, Gifford RW Jr., Kirkendall WM, Lee RE, et al. Guidelines for the Detection, Diagnosis and management of hypertensive populations. Circulation. 1971;44:A263-A72. PMID: N/A. [pmid: 5000456].
Yoshikawa N, Tanaka R, Iijima K. Pathophysiology and treatment of IgA nephropathy in children. Pediatr Nephrol. 2001;16(5):446-57. [pmid: 11405121].

### Not English Language

Cichocka E, Januszewicz P, Wyszynska T. Evaluation of the efficacy and tolerance of three antihypertensive agents used as single-drug therapy, nifedipine, prazosin and acebutolol in severe, idiopathic hypertension in adolescents. Ann Pediatr (Paris). 1993;40(2):119-26. [pmid: 8457132].
Murata K, Saito I. Tracking of blood pressure. Nihon Rinsho. Suppl 2. 2000;58:397-401. [pmid: 11028365].

### Systematic Review, Not Directly Used

Kelley GA, Kelley KS, Tran ZV. The effects of exercise on resting blood pressure in children and adolescents: a meta-analysis of randomized controlled trials. Prev Cardiol. 2003;6(1):8-16. [pmid: 12624556].
Li JS, Baker-Smith CM, Smith PB, Hasselblad V, Murphy MD, Califf RM, et al. Racial differences in blood pressure response to angiotensin-converting enzyme inhibitors in children: a meta-analysis. Clin Pharmacol Ther. 2008;84(3):315-9. [pmid: 18548000].
Simonetti GD, Rizzi M, Donadini R, Bianchetti MG. Effects of antihypertensive drugs on blood pressure and proteinuria in childhood. J Hypertens. 2007;25(12):2370-6. [pmid: 17984655].

### Inadequate Duration

Andre JL, Deschamps JP, Petit JC, Gueguen R. Change of blood pressure over five years in childhood and adolescence. Clin Exp Hypertens A. 1986;8(4-5):539-45. [pmid: 3757275].
Burke V, Beilin LJ, Dunbar D. Tracking of blood pressure in Australian children. J Hypertens. 2001;19(7):1185-92. [pmid: 11446707].
de Swiet M, Fayers P, Shinebourne EA. Systolic blood pressure in a population of infants in the first year of life: the Brompton study. Pediatrics. 1980;65(5):1028-35. [pmid: 7367116].
Gillman MW, Rosner B, Evans DA, Smith LA, Taylor JO, Hennekens CH, et al. Use of multiple visits to increase blood pressure tracking correlations in childhood. Pediatrics. 1991;87(5):708-11. [pmid: 2020518].
Hait HI, Lemeshow S, Rosenman KD. A longitudinal study of blood pressure in a national survey of children. Am J Public Health. 1982;72(11):1285-7. [pmid: 7125033].
Kelder SH, Osganian SK, Feldman HA, Webber LS, Parcel GS, Leupker RV, et al. Tracking of Physical and Physiological Risk Variables among Ethnic Subgroups from Third to Eighth Grade: The Child and Adolescent Trial for Cardiovascular Health Cohort Study. Prev Med. 2002;34(3):324-33. [pmid: 11902849].
Kemper HC, Snel J, Verschuur R, Storm-van Essen L. Tracking of health and risk indicators of cardiovascular diseases from teenager to adult: Amsterdam Growth and Health Study. Prev Med. 1990;19(6):642-55. [pmid: 2263575].
Lattuada S, Rindi M, Antivalle M, Salvaggio A, Grillo A, Libretti A. Blood pressure levels in adolescents: the Milan Study. J Cardiovasc Pharmacol. Suppl 5. 1986;8:S113-5. [pmid: 2427867].
Lauer RMMD, Anderson ARBS, Beaglehole RMDFRACP, Burns TLPD. Factors Related to Tracking of Blood Pressure in Children: U.S. National Center for Health Statistics Health Examination Surveys Cycles II and III. Hypertension. 1984;6(3):307-14. [pmid: 6735452].
Levine RS, Hennekens CH, Klein B, Ferrer PL, Gourley J, Cassady J, et al. A longitudinal evaluation of blood pressure in children. Am J Public Health. 1979;69(11):1175-7. [pmid: 507251].
Levine RS, Hennekens CH, Klein B, Gourley J, Briese FW, Hokanson J, et al. Tracking correlations of blood pressure levels in infancy. Pediatrics. 1978;61(1):121-5. [pmid: 263843].
McCue CM, Miller WW, Mauck HP Jr., Robertson L, Parr EL. Adolescent blood pressure in Richmond, Virginia, schools. Va Med. 1979;106(3):210-20. [pmid: 442787].
Parker FC, Croft JB, Cresanta JL, Freedman DS, Burke GL, Webber LS, et al. The association between cardiovascular response tasks and future blood pressure levels in children: Bogalusa Heart Study. Am Heart J. 1987;113(5):1174-9. [pmid: 3495163].
Sanchez-Bayle M, Munoz-Fernandez MT, Gonzalez-Requejo A. A longitudinal study of blood pressure in Spanish schoolchildren. Working Group of Cardiovascular Risk Factors in Childhood and Adolescence. Arch Dis Child. 1999;81(2):169-71. [pmid: 10490530].
Schachter J, Kuller LH, Perkins JM, Radin ME. Infant blood pressure and heart rate: relation to ethnic group (black or white), nutrition and electrolyte intake. Am J Epidemiol. 1979;110(2):205-18. [pmid: 223439].
Shasha SM, Cohen-Tal I, Epstein L, Tamir A. Tracking of blood pressure in children: results of 7 years' follow-up. The Nahariya Study. Isr J Med Sci. 1988;24(11):671-5. [pmid: 3215759].
Suh I, Nam CM, Lee ES, Kim IS, Lee SY. Blood pressure tracking in Korean schoolchildren. Int J Epidemiol. 1994;23(4):710-5. [pmid: 8002183].
Torok E, Gyarfas I, Csukas M. Prediction of stable high blood pressure in adolescents. Clin Exp Hypertens A. 1986;8(4-5):547-55. [pmid: 3757276].
Voors AW, Webber LS, Berenson GS. Time course studies of blood pressure in children--the Bogalusa Heart Study. Am J Epidemiol. 1979;109(3):320-34. [pmid: 453169].
Voors AW, Webber LS, Berenson GS. Time course study of blood pressure in children over a three-year period. Bogalusa Heart Study. Hypertension. 1980;2(4 Pt 2):102-8. [pmid: 7399641].
Wada J, Ueda K, Takeshita M, Shikata T, Fujii I, Yanai T, et al. Blood pressure tracking in Japanese adolescents. Five-year follow-up in Hisayama, Japan. Jpn Heart J. 1985;26(6):943-53. [pmid: 3831412].
Webber LS, Cresanta JL, Voors AW, Berenson GS. Tracking of cardiovascular disease risk factor variables in school-age children. J Chronic Dis. 1983;36(9):647-60. [pmid: 6619260].
Zinner SH, Rosner B, Oh W, Kass EH. Significance of blood pressure in infancy. Familial aggregation and predictive effect on later blood pressure. Hypertension. 1985;7(3 Pt 1):411-6. [pmid: 3997223].

### Sample Size Too Small

Bachmann H. Propranolol versus chlorthalidone--a prospective therapeutic trial in children with chronic hypertension. Helv Paediatr Acta. 1984;39(1):55-61. [pmid: 6373679].
Blumer JL, Daniels SR, Dreyer WJ, Batisky D, Walson PD, Roman D, et al. Pharmacokinetics of Quinapril in Children: Assessment during Substitution for Chronic Angiotensin-Converting Enzyme Inhibitor Treatment. J Clin Pharmacol. 2003;43(2):128-32. [pmid: 12616664].
Boyar RM, Fixler DF, Kaplan NM, Graham RM, Price KP, Chipman JJ, et al. Effects of clonidine on 24-hour hormonal secretory patterns, cardiovascular hemodynamics, and central nervous function in hypertensive adolescents. Hypertension. 1980;2(1):83-9. [pmid: 6768672].
Danforth JS, Allen KD, Fitterling JM, Danforth JA, Farrar D, Brown M, et al. Exercise as a treatment for hypertension in low-socioeconomic-status black children. J Consult Clin Psychol. 1990;58(2):237-9. [pmid: 2335640].
Falkner B, Koffler S, Lowenthal DT. Effects of antihypertensive drugs on cognitive function in adolescents. Pediatr Pharmacol (New York). 1984;4(4):239-44. [pmid: 6522132].
Falkner B, Onesti G, Lowenthal DT, Affrime MB. Effectiveness of centrally acting drugs and diuretics in adolescent hypertension. Clin Pharmacol Ther. 1982;32(5):577-83. [pmid: 7127998].
Falkner B, Onesti G, Lowenthal DT, Affrime MB. The use of clonidine monotherapy in adolescent hypertension. Chest. 1983;83(2 Suppl):425-7. [pmid: 6822143].
Falkner B, Thanki B, Lowenthal DT. Transdermal clonidine in the treatment of adolescent hypertension. J Hypertens - Supplement. 1985;3(4):S61-3. [pmid: 3868713].
Feig DI, Soletsky B, Johnson RJ. Effect of allopurinol on blood pressure of adolescents with newly diagnosed essential hypertension: a randomized trial. JAMA. 2008;300(8):924-32. [pmid: 18728266].
Franks AM, O'Brien CE, Stowe CD, Wells TG, Gardner SF. Candesartan cilexetil effectively reduces blood pressure in hypertensive children. Ann Pharmacother. 2008;42(10):1388-95. [pmid: 18664605].
Hagberg JM, Ehsani AA, Goldring D, Hernandez A, Sinacore DR, Holloszy JO. Effect of weight training on blood pressure and hemodynamics in hypertensive adolescents. J Pediatr. 1984;104(1):147-51. [pmid: 6690660].
Hagberg JM, Goldring D, Ehsani AA, Heath GW, Hernandez A, Schechtman K, et al. Effect of exercise training on the blood pressure and hemodynamic features of hypertensive adolescents. Am J Cardiol. 1983;52(7):763-8. [pmid: 6624669].
Johnson CC, Nicklas TA, Arbeit ML, Harsha DW, Mott DS, Hunter SM, et al. Cardiovascular intervention for high-risk families: the Heart Smart Program. South Med J. 1991;84(11):1305-12. [pmid: 1948212].
Mongeau JG, Biron P, Pichardo ML. Propranolol efficacy in essential hypertension in adolescents. Can Med Assoc J. 1977;116(6):589. [pmid: 608152].
Pfammatter JP, Clericetti-Affolter C, Truttmann AC, Busch K, Laux-End R, Bianchetti MG. Amlodipine once-daily in systemic hypertension. Eur J Pediatr. 1998;157(8):618-21. [pmid: 9727842].
Ryan A, Rosen DA, Tobias JD. Preliminary experience with nesiritide in pediatric patients less than 12 months of age. J Intensive Care Med. 2008;23(5):321-8. [pmid: 18603536].
Sakarcan A, Tenney F, Wilson JT, Stewart JJ, Adcock KG, Wells TG, et al. The pharmacokinetics of irbesartan in hypertensive children and adolescents. J Clin Pharmacol. 2001;41(7):742-9. [pmid: 11452706].
Simonetti GD, von Vigier RO, Konrad M, Rizzi M, Fossali E, Bianchetti MG. Candesartan cilexetil in children with hypertension or proteinuria: preliminary data. Pediatr Nephrol. 2006;21(10):1480-2. [pmid: 16802178].
Tallian KB, Nahata MC, Turman MA, Mahan JD, Hayes JR, Mentser MI. Efficacy of amlodipine in pediatric patients with hypertension. Pediatr Nephrol. 1999;13(4):304-10. [pmid: 10454779].

### No or Inadequate Reference Standard

Berenson GS, Dalferes E Jr., Savage D, Webber LS, Bao W. Ambulatory blood pressure measurements in children and young adults selected by high and low casual blood pressure levels and parental history of hypertension: the bogalusa heart study. Am J Med Sci. 1993;305(6):374-82. [pmid: 8506897].
Burke GL, Webber LS, Shear CL, Zinkgraf SA, Smoak CG, Berenson GS. Sources of error in measurement of children's blood pressure in a large epidemiologic study: Bogalusa Heart Study. J Chronic Dis. 1987;40(1):83-9. [pmid: 3805236].
Cook NR, Gillman MW, Rosner BA, Taylor JO, Hennekens CH. Combining annual blood pressure measurements in childhood to improve prediction of young adult blood pressure. Stat Med. 2000;19(19):2625-40. [pmid: 10986538].
Cretens ML, Mattson MJ. Hypertension screening program follow-up of previously identified children with elevated blood pressure. J Fam Pract. 1978;6(4):891-2. [pmid: 641472].
Drake EH, Wallis WM. Hypertension screening of adolescents in Central Wisconsin-a Ward Ford Memorial Institute. Wis Med J. 1980;79(8):32-5. [pmid: 7415201].
Falkner B, Gidding SS, Portman R, Rosner B. Blood Pressure Variability and Classification of Prehypertension and Hypertension in Adolescence. Pediatrics. 2008;122(2):238-42. [pmid: 18676538].
Fixler DE, Laird WP, Fitzgerald V, Stead S, Adams R. Hypertension screening in schools: results of the Dallas study. Pediatrics. 1979;63(1):32-6. [pmid: 440800].
Furusawa E, Ruiz M, Saito M, Koch V. Evaluation of the Omron 705-CP blood pressure measuring device for use in adolescents and young adults. Arq Bras Cardiol. 2005;84(5):367-70. Epub 2005 May 24. [pmid: 15917967].
Garbus SB, Young CJ, Hassinger G, Johnson W. Screening for hypertension in adolescents: the search for normal values. South Med J. 1980;73(2):174-82. [pmid: 7355315].
Genovesi S, Giussani M, Pieruzzi F, Vigorita F, Arcovio C, Cavuto S, et al. Results of blood pressure screening in a population of school-aged children in the province of Milan: role of overweight. J Hypertens. 2005;23(3):493-7. [pmid: 15716688].
Gillman MW, Cook NR, Rosner B, Evans DA, Keough ME, Taylor JO, et al. Assessing the validity of childhood blood pressure screening: unbiased estimates of sensitivity, specificity, and predictive values. Epidemiology. 1992;3(1):40-6. [pmid: 1554809].
Gillman MW. Inverse association of dietary calcium with systolic blood pressure in young children. JAMA. 1992;267:2340-3. [pmid: 1564773].
Jenner DA. Diet and blood pressure in 9-year-old Australian children. Am J Clin Nutr. 1988;47:1052-9. [pmid: 2837079].
Kelsall JE, Watson AR. Should school nurses measure blood pressure?. Public Health. 1990;104(3):191-4. [pmid: 2359839].
Lurbe E, Torro I, Alvarez V, Nawrot T, Paya R, Redon J, et al. Prevalence, persistence, and clinical significance of masked hypertension in youth. Hypertension. 2005;45(4):493-8. [pmid: 15767467].
Michaud PA. Adolescent hypertension: a follow-up study in the community. Rev Epidemiol Sante Publique. 1989;37(1):23-8. [pmid: 2710975].
Miller RA, Shekelle RB. Blood pressure in tenth-grade students: results from the Chicago Heart Association Pediatric Heart Screening Project. Circulation. 1976;54(6):993-1000. [pmid: 991417].
Moore WE, Eichner JE, Cohn EM, Thompson DM, Kobza CE, Abbott KE. Blood pressure screening of school children in a multiracial school district: the healthy kids project. Am J Hypertens. 2009;22(4):351-6. [pmid: 19214168].
Nishibata K, Nagashima M, Tsuji A, Hasegawa S, Nagai N, Goto M, et al. Comparison of casual blood pressure and twenty-four-hour ambulatory blood pressure in high school students. J Pediatr. 1995;127(1):34-9. [pmid: 7608808].
Nuutinen M, Turtinen J, Uhari M. Random-zero sphygmomanometer, Rose's tape, and the accuracy of the blood pressure measurements in children. Pediatr Res. 1992;32(2):243-7. [pmid: 1508618].
Orchard TJ, Hedley AJ, Mitchell JR. The distribution and associations of blood pressure in an adolescent population. J Epidemiol Community Health. 1982;36(1):35-42. [pmid: 6978373].
Rames LK, Clarke WR, Connor WE, Reiter MA, Lauer RM. Normal blood pressure and the evaluation of sustained blood pressure elevation in childhood: the Muscatine study. Pediatrics. 1978;61(2):245-51. [pmid: 634679].
Reichman LB, Cooper BM, Blumenthal S, Block G, O'Hare D, Chaves AD, et al. Hypertension testing among high school students. I. Surveillance procedures and results. J Chronic Dis. 1975;28(3):161-71. [pmid: 1123422].
Sailors EL. Project “hypertension alert”. J Sch Health. 1983;53(6):374-6. [pmid: 6555439].
Saint-Remy A, Rorive G. Predictive value and rate of change of blood pressure throughout adolescence: a Belgian prospective study. J Hypertens Supplement. 1991;9(6). [pmid: 1818963].
Silverberg DS, Nostrand CV, Juchli B, Smith ES, Dorsser EV. Screening for hypertension in a high school population. Can Med Assoc J. 1975;113(2):103-8. [pmid: 124624].
Sinaiko AR, Gomez-Marin O, Prineas RJ. “Significant” diastolic hypertension in pre-high school black and white children. The children and adolescent blood pressure program. Am J Hypertens. 1988;1(2):178-80. [pmid: 3401357].
Sinaiko AR, Gomez-Marin O, Prineas RJ. Prevalence of “significant” hypertension in junior high school-aged children: the Children and Adolescent Blood Pressure Program. J Pediatr. 1989;114(4 Pt 1):664-9. [pmid: 2784501].
Stern B, Heyden S, Miller D, Latham G, Klimas A, Pilkington K. Intervention study in high school students with elevated blood pressures. Dietary experiment with polyunsaturated fatty acids. Nutr Metab. 1980;24(3):137-47. [pmid: 7443094].
Wattigney WA, Webber LS, Lawrence MD, Berenson GS. Utility of an automatic instrument for blood pressure measurement in children. The Bogalusa Heart Study. Am J Hypertens. 1996;9(3):256-62. [pmid: 8695025].

## Appendix A5 U.S. Preventive Services Task Force Quality Rating Criteria

### Diagnostic Accuracy Studies

Criteria
- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate results in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test
- Random or consecutive selection of patients
- Screening cutoff pre-determined
- All patients undergo the reference standard

Definition of ratings based on above criteria

Good: | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease; study attempts to enroll a random or consecutive sample of patients who meet inclusion criteria screening cutoffs pre-stated.
Fair: | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients (i.e. applicable to most screening settings).
Poor: | Has important limitation such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size of very narrow selected spectrum of patients.

### Randomized Controlled Trials (RCTs) and Cohort Studies

Criteria
- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of ratings based on above criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

### Reference

Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].

## Appendix A6 Expert Reviewers of the Draft Report

- Doug Campos-Outcalt, MD, MPA
  Associate Head, Clinical Professor, Department of Family and Community Medicine, University of Arizona
- Shifan Dai, MD, PhD
  Epidemiologist, Centers for Disease Control and Prevention
- Stephen R. Daniels, MD, PhD, MPH
  Professor and Chairman, Department of Pediatrics, University of Colorado School of Medicine; Pediatrician-in-Chief, Children's Hospital Colorado
- Joseph Flynn, MD, MS
  Professor of Pediatrics, Division of Nephrology, Seattle Children's Hospital, University of Washington School of Medicine
- Samuel S. Gidding, MD
  Cardiology Division Head, Nemours Cardiac Center, DuPont Hospital for Children
- Matthew Gillman, MD, SM
  Professor, Director of Obesity Prevention Program, Department of Population Medicine, Harvard Medical School
- David C. Kaelber, MD, PhD, MPH
  Chief Medical Informatics Officer, Assistant Professor, Case Western University School of Medicine
- Richard McManus, PhD MBBS FRCGP
  Professor of Cardiovascular Primary Care Research, Oxford University
- Julia Steinberger, MD, MS
  Director of Pediatric Lipid Clinic, Medical Director of the Pediatric Echocardiography Laboratory, University of Minnesota