# REFERENCES

1 Nelson HD, Bougatsos C, Blazina I. Screening Women for Intimate Partner Violence and Elderly and Vulnerable Adults for Abuse: Systematic Review to Update the 2004 U.S. Preventive Services Task Force Recommendation, Evidence Synthesis No. 92. AHRQ Publication No. 12-05167-EF-1. Rockville, MD. Agency for Healthcare Research and Quality. 2012. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK97297/ on. 14 December 2012.
2 Nelson HD, Bougatsos C, Blazina I. Screening women for intimate partner violence: a systematic review to update the 2004 U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2012;156(11):796-808. [pmid: 22565034].
3 Nelson H, Nygren P, McInerney Y. Screening for Family and Intimate Partner Violence, Systematic Evidence Review No. 28. Rockville, MD. Agency for Healthcare Research and Quality. 2004. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK42851/ on. 14 December 2012.
4 Nygren P, Nelson HD, Klein J. Screening children for family violence: a review of the evidence for the U.S. Preventive Services Task Force. Ann Fam Med. 2004;2(2):161-9. [pmid: 15083858].
5 U.S. Preventive Services Task Force. Screening for family and intimate partner violence: recommendation statement. Ann Fam Med. 2004;2(2):156-60. [pmid: 15083857].
6 US Preventive Services Task Force. Screening for Family and Intimate Partner Violence: Recommendation Statement. Rockville, MD. Agency for Healthcare Research and Quality. 2004. Accessed at http://www.uspreventiveservicestaskforce.org/3rduspstf/famviolence/famviolrs.htm on. 14 December 2012.
7 Centers for Disease Control and Prevention. Understanding Intimate Partner Violence: Fact Sheet. Atlanta. Centers for Disease Control and Prevention. 2012. Accessed at http://www.cdc.gov/ViolencePrevention/pdf/IPV_Factsheet2012-a.pdf on. 14 December 2012.
8 Leeb RT, Paulozzi LJ, Melanson C, Simon TR, Arias I. Child Maltreatment Surveillance: Uniform Definitions for Public Health and Recommended Data Elements. Version 1.0. Atlanta. Centers for Disease Control and Prevention. 2008. Accessed at http://www.cdc.gov/violenceprevention/pdf/CM_Surveillance-a.pdf on. 14 December 2012.
9 Child Abuse Prevention and Treatment Act Amendments of 1996 (PL 104-235, Oct. 3, 1996). United States Statutes at Large. 1996;104:3063-92.
10 U.S. Department of Health and Human Services. Administration for Children and Families, Administration on Children, Youth, and Families, Children’s Bureau, Office on Child Abuse and Neglect. The Child Abuse Prevention and Treatment Act as Amended by the Keeping Children and Families Safe Act of 2003. Washington, DC. U.S. Department of Health and Human Services. 2003. Accessed at http://www.acf.hhs.gov/sites/default/files/cb/capta2003.pdf on. 14 December 2012.
11 U.S. Department of Health and Human Services. Administration for Children and Families, Administration on Children, Youth, and Families, Children’s Bureau. Child Maltreatment 2009. Washington, DC. U.S. Department of Health and Human Services. 2010. Accessed at http://archive.acf.hhs.gov/programs/cb/pubs/cm09/cm09.pdf on. 14 December 2012.
12 Child Welfare Information Gateway. Definitions of Child Abuse and Neglect. Washington, DC. U.S. Department of Health and Human Services. 2011. Accessed at http://www.childwelfare.gov/systemwide/laws_policies/statutes/define.cfm%20 on. 14 December 2012.
13 Saltzman LE, Fanslow JL, McMahon PM, Shelley GA. Intimate Partner Violence Surveillance: Uniform Definitions and Recommended Data Elements. Version 1.0. Atlanta. Centers for Disease Control and Prevention. 1999. Accessed at http://www.cdc.gov/ncipc/pub-res/ipv_surveillance/Intimate%20Partner%20Violence.pdf on. 14 December 2012.
14 U.S. Department of Health and Human Services. Administration for Children and Families, Administration on Children, Youth, and Families, Children’s Bureau. Child Maltreatment 2010. Washington, DC. U.S. Department of Health and Human Services. 2011. Accessed at http://archive.acf.hhs.gov/programs/cb/pubs/cm10/cm10.pdf on. 14 December 2012.
15 Hussey JM, Chang JJ, Kotch JB. Child maltreatment in the United States: prevalence, risk factors, and adolescent health consequences. Pediatrics. 2006;118(3):933-42. [pmid: 16950983].
16 Shaffer A, Huston L, Egeland B. Identification of child maltreatment using prospective and self-report methodologies: a comparison of maltreatment incidence and relation to later psychopathology. Child Abuse Negl. 2008;32(7):682-92. [pmid: 18638626].
17 McFarlane JM, Groff JY, O’Brien JA, Watson K. Behaviors of children who are exposed and not exposed to intimate partner violence: an analysis of 330 black, white, and Hispanic children. Pediatrics. 2003;112(3 Pt 1):e202-7. [pmid: 12949313].
18 Goodwin RD, Stein MB. Association between childhood trauma and physical disorders among adults in the United States. Psychol Med. 2004;34(3):509-20. [pmid: 15259836].
19 Wegman HL, Stetler C. A meta-analytic review of the effects of childhood abuse on medical outcomes in adulthood. Psychosom Med. 2009;71(8):805-12. [pmid: 19779142].
20 Pederson CL, Wilson JF. Childhood emotional neglect related to posttraumatic stress disorder symptoms and body mass index in adult women. Psychol Rep. 2009;105(1):111-26. [pmid: 19810438].
21 Whitaker RC, Phillips SM, Orzol SM, Burdette HL. The association between maltreatment and obesity among preschool children. Child Abuse Negl. 2007;31(11–12):1187-99. [pmid: 18023869].
22 Davis DA, Luecken LJ, Zautra AJ. Are reports of childhood abuse related to the experience of chronic pain in adulthood? A meta-analytic review of the literature. Clin J Pain. 2005;21(5):398-405. [pmid: 16093745].
23 Brown J, Berenson K, Cohen P. Documented and self-reported child abuse and adult pain in a community sample. Clin J Pain. 2005;21(5):374-7. [pmid: 16093742].
24 Leeners B, Stiller R, Block E, Görres G, Rath W. Pregnancy complications in women with childhood sexual abuse experiences. J Psychosom Res. 2010;69(5):503-10. [pmid: 20955870].
25 Chartier MJ, Walker JR, Naimark B. Childhood abuse, adult health, and health care utilization: results from a representative community sample. Am J Epidemiol. 2007;165(9):1031-8. [pmid: 17309899].
26 Cutajar MC, Mullen PE, Ogloff JR, Thomas SD, Wells DL, Spataro J. Psychopathology in a large cohort of sexually abused children followed up to 43 years. Child Abuse Negl. 2010;34(11):813-22. [pmid: 20888636].
27 Lown AE, Nayak MB, Korcha RA, Greenfield TK. Child physical and sexual abuse: a comprehensive look at alcohol consumption patterns, consequences, and dependence from the National Alcohol Survey. Alcohol Clin Exp Res. 2011;35(2):317-25. [pmid: 21083668].
28 Schneider R, Baumrind N, Kimerling R. Exposure to child abuse and risk for mental health problems in women. Violence Vict. 2007;22(5):620-31. [pmid: 18064973].
29 Battle CL, Shea MT, Johnson DM, Yen S, Zlotnick C, Zanarini MC, et al. Childhood maltreatment associated with adult personality disorders: findings from the Collaborative Longitudinal Personality Disorders Study. J Pers Disord. 2004;18(2):193-211. [pmid: 15176757].
30 Bierer LM, Yehuda R, Schmeidler J, Mitropoulou V, New AS, Silverman JM, et al. Abuse and neglect in childhood: relationship to personality disorder diagnoses. CNS Spectr. 2003;8(10):737-54. [pmid: 14712172].
31 Sickel AE, Noll JG, Moore PJ, Putnam FW, Trickett PK. The long-term physical health and healthcare utilization of women who were sexually abused as children. J Health Psychol. 2002;7(5):583-97. [pmid: 22113143].
32 Trickett P, Putnam F, Noll J. Child Abuse Team/Mayerson Center for Safe and Healthy Children: Longitudinal Study on Childhood Sexual Abuse—Summary. Cincinatti, OH. Cincinnati Children’s Hospital Medical Center. 2005.
33 Thompson R, Tabone JK. The impact of early alleged maltreatment on behavioral trajectories. Child Abuse Negl. 2010;34(12):907-16. [pmid: 21111247].
34 Centers for Disease Control and Prevention. Child Maltreatment: Risk and Protective Factors. Atlanta. Centers for Disease Control and Prevention. 2012. Accessed at http://www.cdc.gov/ViolencePrevention/childmaltreatment/riskprotectivefactors.html on. 14 December 2012.
35 Sullivan PM, Knutson JF. Maltreatment and disabilities: a population-based epidmiology study. Child Abuse Negl. 2000;24(10):1257-73. [pmid: 11075694].
36 Dubowitz H, Kim J, Black MM, Weisbart C, Semiatin J, Magder LS. Identifying children at high risk for a child maltreatment report. Child Abuse Negl. 2011;35(2):96-104. [pmid: 21376396].
37 Palazzi S, de Girolamo G, Liverani T. IChilMa (Italian Child Maltreatment Study Group). Observational study of suspected maltreatment in Italian paediatric emergency departments. Arch Dis Child. 2005;90(4):406-10. [pmid: 15781934].
38 Taylor J, Baldwin N, Spencer N. Predicting child abuse and neglect: ethical, theoretical and methodological challenges. J Clin Nurs. 2008;17(9):1193-200. [pmid: 18416795].
39 Bugental DB, Schwartz A. A cognitive approach to child mistreatment prevention among medically at-risk infants. Dev Psychol. 2009;45(1):284-8. [pmid: 19210009].
40 Avellar S, Paulsell D, Sama-Miller E, Del Grosso P. Home Visiting Evidence of Effectiveness Review: Executive Summary. Washington, DC. U.S. Department of Health and Human Services. 2012. Accessed at http://homvee.acf.hhs.gov/HomVEE_Executive_Summary_2012.pdf on. 14 December 2012.
41 Child Welfare Information Gateway. Mandatory Reporters of Child Abuse and Neglect: Summary of State Laws. Washington, DC. U.S. Department of Health and Human Services. 2010. Accessed at http://www.childwelfare.gov/systemwide/laws_policies/statutes/manda.pdf on. 14 December 2012.
42 Flaherty EG, Stirling J Jr. American Academy of Pediatrics, Committee on Child Abuse and Neglect. Clinical report—the pediatrician’s role in child maltreatment prevention. Pediatrics. 2010;126(4):833-41. [pmid: 20945525].
43 Bair-Merritt MH, Giardino AP, Turner M, Ganetsky M, Christian CW. Pediatric residency training on domestic violence: a national survey. Ambul Pediatr. 2004;4(1):24-7. [pmid: 14731096].
44 Lapidus G, Cooke MB, Gelven E, Sherman K, Duncan M, Banco L. A statewide survey of domestic violence screening behaviors among pediatricians and family physicians. Arch Pediatr Adolesc Med. 2002;156(4):332-6. [pmid: 11929365].
45 Starling SP, Heisler KW, Paulson JF, Youmans E. Child abuse training and knowledge: a national survey of emergency medicine, family medicine, and pediatric residents and program directors. Pediatrics. 2009;123(4):e595-602. [pmid: 19273504].
46 Lane WG, Dubowitz H. Primary care pediatricians’ experience, comfort and competence in the evaluation and management of child maltreatment: do we need child abuse experts?. Child Abuse Negl. 2009;33(2):76-83. [pmid: 19278726].
47 Flaherty EG, Sege R, Price LL, Christoffel KK, Norton DP, O’Connor KG. Pediatrician characteristics associated with child abuse identification and reporting: results from a national survey of pediatricians. Child Maltreat. 2006;11(4):361-9. [pmid: 17043321].
48 American Medical Association. Opinion 2.02: Physicians’ Obligations in Preventing, Identifying, and Treating Violence and Abuse. Chicago. American Medical Association. 2008. Accessed at http://www.ama-assn.org/ama/pub/physician-resources/medical-ethics/code-medical-ethics/opinion202.page on. 14 December 2012.
49 American Academy of Family Physicians. Family and Intimate Partner Violence and Abuse. Leawood, KS. American Academy of Family Physicians. 2009. Accessed at http://www.aafp.org/online/en/home/policy/policies/f/familyandintimatepartner-violenceandabuse.html on. 14 December 2012.
50 Emergency Nurses Association. Emergency Nurses Association Position Statement: Intimate Partner and Family Violence, Maltreatment, and Neglect. Des Plaines, IL. Emergency Nurses Association. 2006. Accessed at http://www.ena.org/SiteCollectionDocuments/Position%20Statements/Violence_-_Intimate_Partner_and_Family_-_ENA_PS.pdf on. 14 December 2012.
51 Family Violence Prevention Fund. National Consensus Guidelines on Identifying and Responding to Domestic Violence Victimization in Health Care Settings. San Francisco. Family Violence Prevention Fund. 2004. Accessed at http://www.futureswithoutviolence.org/userfiles/file/Consensus.pdf on. 14 December 2012.
52 Council of International Neonatal Nurses. Council of International Neonatal Nurses Position Statement on Routine Screening for Intimate Partner Violence. Boston. Council of International Neonatal Nurses. 2010. Accessed at http://www.coinnurses.org/1_documents/resources/p_statement/Position_Stat_Intimate_Partner_Violence.pdf on. 14 December 2012.
53 MacMillan HL. Canadian Task Force on Preventive Health Care. Preventive health care, 2000 update: prevention of child maltreatment. CMAJ. 2000;163(11):1451-8. [pmid: 11192650].
54 Guide to Community Preventive Services. Violence Prevention: Early Childhood Home Visitation. Atlanta. Centers for Disease Control and Prevention. 2010. Accessed at http://www.thecommunityguide.org/violence/home/index.html on. 14 December 2012.
55 Guide to Community Preventive Services. Early Childhood Home Visitation to Prevent Violence. Atlanta. Centers for Disease Control and Prevention. 2012. Accessed at http://www.thecommunityguide.org/violence/home/homevisitation.html on. 14 December 2012.
56 Nelson HD, Nygren P, McInerney Y, Klein J. U.S. Preventive Services Task Force. Screening women and elderly adults for family and intimate partner violence: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140(5):387-96. [pmid: 14996681].
57 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, et al. Methods Work Group, Third US Preventive Services Task Force. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
58 Hussey DL, Guo S. Characteristics and trajectories of treatment foster care youth. Child Welfare. 2005;84(4):485-506. [pmid: 16117260].
59 Leeflang MM, Deeks JJ, Gatsonis C, Bossuyt PM. Cochrane Diagnostic Test Accuracy Working Group. Systematic reviews of diagnostic test accuracy. Ann Intern Med. 2008;149(12):889-97. [pmid: 19075208].
60 Armstrong KL, Fraser JA, Dadds MR, Morris J. A randomized, controlled trial of nurse home visiting to vulnerable families with newborns. J Paediatr Child Health. 1999;35(3):237-44. [pmid: 10404442].
61 Hardy JB, Streett R. Family support and parenting education in the home: an effective extension of clinic-based preventive health care services for poor children. J Pediatr. 1989;115(6):927-31. [pmid: 2585229].
62 Krysik J, LeCroy CW. The evaluation of Healthy Families Arizona: a multisite home visitation program. J Prev Interv Community. 2007;34(1–2):109-27. [pmid: 17890196].
63 Larson CP. Efficacy of prenatal and postpartum home visits on child health and development. Pediatrics. 1980;66(2):191-7. [pmid: 7402804].
64 Starn JR. Community health nursing visits for at-risk women and infants. J Community Health Nurs. 1992;9(2):103-10. [pmid: 1624977].
65 Stevens-Simon C, Nelligan D, Kelly L. Adolescents at risk for mistreating their children, II: a home-and clinic-based prevention program. Child Abuse Negl. 2001;25(6):753-69. [pmid: 11525524].
66 Atkins D, Chang SM, Gartlehner G, Buckley DI, Whitlock EP, Berliner E, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
67 Dubowitz H, Feigelman S, Lane W, Kim J. Pediatric primary care to help prevent child maltreatment: the Safe Environment for Every Kid (SEEK) Model. Pediatrics. 2009;123(3):858-64. [pmid: 19255014].
68 Olds DL, Kitzman H, Hanks C, Cole R, Anson E, Sidora-Arcoleo K, et al. Effects of nurse home visiting on maternal and child functioning: age-9 follow-up of a randomized trial. Pediatrics. 2007;120(4):e832-45. [pmid: 17908740].
69 Barlow J, Davis H, McIntosh E, Jarrett P, Mockford C, Stewart-Brown S. Role of home visiting in improving parenting and health in families at risk of abuse and neglect: results of a multicentre randomised controlled trial and economic evaluation. Arch Dis Child. 2007;92(3):229-33. [pmid: 17068074].
70 Duggan A, McFarlane E, Fuddy L, Burrell L, Higman SM, Windham A, et al. Randomized trial of a statewide home visiting program: impact in preventing child abuse and neglect. Child Abuse Negl. 2004;28(6):597-622. [pmid: 15193851].
71 Duggan A, Caldera D, Rodriguez K, Burrell L, Rohde C, Crowne SS. Impact of a statewide home visiting program to prevent child abuse. Child Abuse Negl. 2007;31(8):801-27. [pmid: 17822764].
72 DuMont K, Mitchell-Herzfeld S, Greene R, Lee E, Lowenfels A, Rodriguez M, et al. Healthy Families New York (HFNY) randomized trial: effects on early child abuse and neglect. Child Abuse Negl. 2008;32(3):295-315. [pmid: 18377991].
73 Fergusson DM, Grant H, Horwood LJ, Ridder EM. Randomized trial of the Early Start program of home visitation. Pediatrics. 2005;116(6):e803-9. [pmid: 16322138].
74 Lowell DI, Carter AS, Godoy L, Paulicin B, Briggs-Gowan MJ. A randomized controlled trial of Child FIRST: a comprehensive home-based intervention translating research into early childhood practice. Child Dev. 2011;82(1):193-208. [pmid: 21291437].
75 El-Mohandes AA, Katz KS, El-Khorazaty MN, McNeely-Johnson D, Sharps PW, Jarrett MH, et al. The effect of a parenting education program on the use of preventive pediatric health care services among low-income, minority mothers: a randomized, controlled study. Pediatrics. 2003;111(6 Pt 1):1324-32. [pmid: 12777548].
76 Koniak-Griffin D, Verzemnieks IL, Anderson NL, Brecht ML, Lesser J, Kim S, et al. Nurse visitation for adolescent mothers: two-year infant health and maternal outcomes. Nurs Res. 2003;52(2):127-36. [pmid: 12657988].
77 Olds DL, Henderson CR Jr, Chamberlin R, Tatelbaum R. Preventing child abuse and neglect: a randomized trial of nurse home visitation. Pediatrics. 1986;78(1):65-78. [pmid: 2425334].
78 Olds DL, Henderson CR Jr, Kitzman H. Does prenatal and infancy nurse home visitation have enduring effects on qualities of parental caregiving and child health at 25 to 50 months of life?. Pediatrics. 1994;93(1):89-98. [pmid: 8265329].
79 Eckenrode J, Ganzel B, Henderson CR Jr, Smith E, Olds DL, Powers J, et al. Preventing child abuse and neglect with a program of nurse home visitation: the limiting effects of domestic violence. JAMA. 2000;284(11):1385-91. [pmid: 10989400].
80 Kitzman H, Olds DL, Henderson CR Jr, Hanks C, Cole R, Tatelbaum R, et al. Effect of prenatal and infancy home visitation by nurses on pregnancy outcomes, childhood injuries, and repeated childbearing: a randomized trial. JAMA. 1997;278(8):644-52. [pmid: 9272896].
81 Barth RP. An experimental evaluation of in-home child abuse prevention services. Child Abuse Negl. 1991;15(4):363-75. [pmid: 1959070].
82 Bugental DB, Ellerson PC, Lin EK, Rainey B, Kokotovic A, O’Hara N. A cognitive approach to child abuse prevention. J Fam Psychol. 2002;16(3):243-58. [pmid: 12238408].
83 Duggan AK, McFarlane EC, Windham AM, Rohde CA, Salkever DS, Fuddy L, et al. Evaluation of Hawaii’s Healthy Start Program. Future Child. 1999;9(1):66-90. [pmid: 10414011].
84 Fraser JA, Armstrong KL, Morris JP, Dadds MR. Home visiting intervention for vulnerable families with newborns: follow-up results of a randomized controlled trial. Child Abuse Negl. 2000;24(11):1399-429. [pmid: 11128173].
85 Siegel E, Bauman KE, Schaefer ES, Saunders MM, Ingram DD. Hospital and home support during infancy: impact on maternal attachment, child abuse and neglect, and health care utilization. Pediatrics. 1980;66(2):183-90. [pmid: 7402803].
86 Olds DL, Sadler L, Kitzman H. Programs for parents of infants and toddlers: recent evidence from randomized trials. J Child Psychol Psychiatry. 2007;48(3–4):355-91. [pmid: 17355402].
87 Dubowitz H, Lane WG, Semiatin JN, Magder LS. The SEEK model of pediatric primary care: can child maltreatment be prevented in a low-risk population?. Acad Pediatr. 2012;12(4):259-68. [pmid: 22658954].
88 Hussey JM, Marshall JM, English DJ, Knight ED, Lau AS, Dubowitz H, et al. Defining maltreatment according to substantiation: distinction without a difference?. Child Abuse Negl. 2005;29(5):479-92. [pmid: 15970321].
89 Olds DL, Robinson J, O’Brien R, Luckey DW, Pettitt LM, Henderson CR Jr, et al. Home visiting by paraprofessionals and by nurses: a randomized, controlled trial. Pediatrics. 2002;110(3):486-96. [pmid: 12205249].
90 Dias MS, Smith K, DeGuehery K, Mazur P, Li V, Shaffer ML. Preventing abusive head trauma among infants and young children: a hospital-based, parent education program. Pediatrics. 2005;115(4):e470-7. [pmid: 15805350].
91 Chaffin M, Silovsky JF, Funderburk B, Valle LA, Brestan EV, Balachova T, et al. Parent-child interaction therapy with physically abusive parents: efficacy for reducing future abuse reports. J Consult Clin Psychol. 2004;72(3):500-10. [pmid: 15279533].
92 Prevent Child Abuse America. Healthy Families America. Chicago. Prevent Child Abuse America. 2012. Accessed at http://www.healthyfamiliesamerica.org on. 14 December 2012.
93 Berger RP. The use of serum biomarkers to predict outcome after traumatic brain injury in adults and children. J Head Trauma Rehabil. 2006;21(4):315-33. [pmid: 16915008].
94 Berger RP, Ta’asan S, Rand A, Lokshin A, Kochanek PM. Multiplex assessment of serum biomarker concentrations in well-appearing children with inflicted traumatic brain injury. Pediatr Res. 2009;65(1):97-102. [pmid: 18787505].
95 Lane WG, Dubowitz H, Langenberg P. Screening for occult abdominal trauma in children with suspected physical abuse. Pediatrics. 2009;124(6):1595-602. [pmid: 19933726].
96 Zolotor AJ, Theodore AD, Chang JJ, Berkoff MC, Runyan DK. Speak softly—and forget the stick: corporal punishment and child physical abuse. Am J Prev Med. 2008;35(4):364-9. [pmid: 18779030].
97 Taylor B, Stein N, Burden F. The effects of gender violence/harassment prevention programming in middle schools: a randomized experimental evaluation. Violence Vict. 2010;25(2):202-23. [pmid: 20514817].
98 El-Mohandes AA, Kiely M, Blake SM, Gantz MG, El-Khorazaty MN. An intervention to reduce environmental tobacco smoke exposure improves pregnancy outcomes. Pediatrics. 2010;125(4):721-8. [pmid: 20211945].
99 El-Mohandes AA, Kiely M, Gantz MG, El-Khorazaty MN. Very preterm birth is reduced in women receiving an integrated behavioral intervention: a randomized controlled trial. Matern Child Health J. 2011;15(1):19-28. [pmid: 20082130].
100 Kiely M, El-Mohandes AA, El-Khorazaty MN, Blake SM, Gantz MG. An integrated intervention to reduce intimate partner violence in pregnancy: a randomized controlled trial. Obstet Gynecol. 2010;115(2 Pt 1):273-83. [pmid: 20093899].
101 Olds DL, Kitzman H, Cole R, Robinson J, Sidora K, Luckey DW, et al. Effects of nurse home-visiting on maternal life course and child development: age 6 follow-up results of a randomized trial. Pediatrics. 2004;114(6):1550-9. [pmid: 15574614].
102 Taylor JE, Harvey ST. A meta-analysis of the effects of psychotherapy with adults sexually abused in childhood. Clin Psychol Rev. 2010;30(6):749-67. [pmid: 20579790].
103 McGuigan WM, Vuchinich S, Pratt CC. Domestic violence, parents’ view of their infant, and risk for child abuse. J Fam Psychol. 2000;14(4):613-24. [pmid: 11132484].