# DISCUSSION

## Summary of Review Findings

Table 10 summarizes the evidence reviewed for this update. Key question 1 was addressed by 11 trials of interventions, and no studies provided data to address key question 2. An RCT of a clinic-based intervention to prevent child abuse and neglect using the SEEK Model screened families of young children for risk of abuse and offered educational materials and social work services to families with increased risk. Families in the intervention group had fewer CPS reports, episodes of severe or very severe physical assault, nonadherence to medical care, and delays in immunizations than those in the usual care group 3 years after the intervention. Although not reported in the publication, investigators indicated that no harms were identified. The SEEK Model is currently under further evaluation in a second trial that includes 66 pediatricians and 24 nurse practitioners in 18 private practices.36 In this trial, mothers in SEEK practices reported less psychological aggression and minor physical assault than mothers in usual care practices.87 Additional outcomes from this trial have not yet been published.

Table 10 Summary of Evidence

Studies, n | Design | Limitations | Consistency | Applicability | Overall quality | Findings
Key Question 1. For children without obvious signs and symptoms of abuse or neglect, but who are potentially at increased risk, how well do behavioral interventions and counseling initiated in primary care settings reduce exposure to abuse or neglect, physical or mental harms, or mortality?
1 trial of a clinic-based program and 10 trials of early childhood home visitation | RCT | Trials were limited by heterogeneity, low adherence, high loss to followup, and lack of standardized measures | Inconsistent for some outcomes | Moderate | Fair | A trial in a pediatric clinic showed reduced physical assault, CPS reports, medical care nonadherence, and immunization delay among screened children. 10 trials of early childhood home visitation reported reduced CPS reports, emergency visits, hospitalizations, and self-reports of abuse and neglect and improved adherence to immunizations and well-child care, although results were inconsistent
Key Question 2. What are the adverse effects of behavioral interventions and counseling to reduce harm from abuse and neglect?
1 trial of a clinic-based intervention (based on communication with investigators) | RCT | Studies of adverse effects were lacking | Not relevant | Moderate | Not relevant | The clinic-based trial reported no adverse effects from the interventions

RCT = randomized, controlled trial; CPS = Child Protective Services.

Ten new trials evaluated the effectiveness of early childhood home visitation for children with identified risk factors for abuse and neglect. Studies varied by design, outcomes, and intensity of the intervention. Differences between intervention and control groups were reported for several outcomes, including reduced CPS reports, emergency visits, hospitalizations, and self-reports of abuse, and improved adherence to immunizations and well-child care. However, adherence was low and results were inconsistent across trials for most outcomes.

The trials provide support for specific features of home visitation interventions. Results varied depending on who administered the intervention, the duration of home visits, the number or proportion of planned home visits actually accomplished, and if the intervention included additional educational components. Most of the statistically significant benefits were demonstrated by the trials with the more intense interventions, such as several nurse visits for 24 months or longer, suggesting that they are the most effective.77,80 However, no studies directly compared the effectiveness of different lengths or intensities of home visitation.

The use of CPS reports as an outcome measure is complicated by the various types of reports available. Although trials differed regarding the reporting of total CPS reports or substantiated reports only, a study comparing types of reports found that child health and behavior outcomes between the two groups were minimal, and that close to 90 percent of children with at least one substantiated CPS report also had at least one unsubstantiated report.88

## Limitations

Limitations of this review include using only English-language articles and studies applicable to the United States, and excluding studies of interventions for children who did not undergo risk assessment.

The primary limitation of the intervention trials concerns an almost complete focus on home visitation as the principle intervention. All of the trials assessed parents for child abuse risk based on the presence or absence of risk factors rather than screening the children themselves. Also, trials were limited to very young children. Although these are all important areas of research, no trials extend beyond this focus.

The home visitation trials are also highly heterogeneous, with the actual interventions differing widely. Interventions were performed by paraprofessionals with a high school diploma and some additional training70,72 as well as by experienced nurses or other health care professionals.77,80 They also differed in the number of home visitation sessions offered, from as few as nine85 to as many as 41 sessions69 over a time period ranging from 3 months85 to 3 years after birth.73 This heterogeneity contributes to the inconsistency of results.

For many trials, the approach to evaluating interventions often lacked a priori identification of primary and secondary outcomes. Outcomes also varied, and were expressed in different ways, such as prevalence rates or total numbers of events, and include some self-reported outcomes that are subject to bias. All of these differences limit comparisons. Additionally, this review did not evaluate child development outcomes, although several of the home visitation trials included in this review provided them.69,73,74,80,83,89 Surveillance bias also confounded some outcomes, and two studies reported that CPS referrals were made by the home visitor.70,71 Long-term followup beyond the intervention period would provide a less biased approach.

This review focuses on the primary prevention of child abuse and neglect identified through screening or risk assessment. Universal primary prevention programs, in which screening or risk assessment is not necessary because all caregivers are provided with the intervention, were not included. Nonetheless, these are also valuable strategies. Shaken baby prevention education in hospitals for parents of newborns is one such approach.90 Studies of secondary prevention programs to prevent child abuse and neglect among caregivers with a history of abusing children,91 treatment of abused children, and community-based programs were also outside the scope of this review.

The applicability of the intervention trials may be limited, and it is unclear if results would be similar for families who are not enrolled in the trials. However, several home visitation trials were conducted in the Healthy Families Program.71,72 The Healthy Families America Program currently has home visitation programs in 35 States and the District of Columbia with 383 total sites, providing resources beyond the research trials.92

## Emerging and Future Research

The use of biomarkers as screening tools for physical violence is an area of ongoing research. In a study of well-appearing infants with nonspecific symptoms and no history of trauma, those with elevations in serum and/or cerebrospinal fluid levels of neuron-specific enolase and myelin-basic protein were more likely to have inflicted traumatic brain injuries.93 In another study, 44 serum biomarkers were studied in infants with mild inflicted traumatic brain injury and in those without known brain injury.94 Discrimination between abused and nonabused infants was determined with 87 percent sensitivity and 90 percent specificity using classification algorithms. Use of pancreatic and liver enzymes to screen for occult abdominal trauma in situations of possible physical abuse has also been explored.95

The relationship between harsh punishment, such as spanking, and child abuse needs to be further explored. In an anonymous telephone survey of mothers with children younger than age 18 years, the odds of physical child abuse were greatly elevated if the parents used an object to spank their children (OR, 8.9 [95% CI, 4.1 to 19.6]).96 When spanking was confined to with the hands only, the association with physical abuse was less (OR, 1.03 [95% CI, 1.01 to 1.06]).96 Escalation of violence along this continuum could be prevented if harsh punishment practices are recognized and alternatives considered.

The relationship between IPV and child abuse also requires additional research. In households where both partners assault each other, the odds that one or both parents used physical punishment with their children is twice that of households with no IPV, even after controlling for parenting stress, depression, and substance abuse.97 Studies of IPV with child abuse outcomes are summarized in Table 11. Although few studies have addressed this issue, some of the most compelling results indicate worse birth outcomes for women experiencing IPV during pregnancy, including very low birth weight and very preterm birth.98 Interventions directed at identifying and reducing IPV also result in benefits to children. Neonatal outcomes improve for women experiencing IPV who undergo counseling interventions during pregnancy.99,100

Table 11 Studies of Intimate Partner Violence Reporting Child Abuse Outcomes

Author, year Study | Findings
Eckenrode et al, 2000^79^ Elmira Trial | Of women who reported 28 or fewer incidents of IPV (79% of sample), home-visited mothers had significantly fewer child maltreatment reports during the 15-year period than mothers not receiving the intervention (p=0.01); the treatment effect of home visitation decreased as IPV increased.
Duggan et al, 2007^71^ Healthy Families Alaska | Program impact on IPV: psychological abuse (p=0.23), physical abuse (0.38), any injury (p=0.55).
Olds et al, 2004^101^ Memphis Trial | There were no statistically significant program effects on IPV (birth to age 6, p=0.87).
Olds et al, 2007^68^ Memphis Trial | Adjusted estimate of program effects on IPV from birth to age 6 (p=0.373).
Taylor et al, 2010^102^ | Of couples who reported any family aggression (87%), 54% reported that both harsh punishment and IPV occurred. The most prevalent patterns of abuse involved both parents as aggressors toward either each other or the child. The presence of bilateral IPV doubled the odds that one or both parents would use corporal punishment, even after controlling for potential confounders such as parenting stress, depression, and alcohol or other drug use.
Kiely et al, 2010^100^ | Women receiving tailored counseling sessions for IPV had significantly fewer very preterm neonates (p=0.03).
El-Mohandes et al, 2010^98^ | IPV at baseline significantly increased the chances of very low birth weight and very preterm birth outcomes in neonates (OR, 3.75 and 2.71, respectively [p<0.05]).
McGuigan et al, 2000^103^ | Mothers and fathers experiencing IPV viewed the child more negatively compared with mothers and fathers not experiencing IPV (p<0.001).

IPV = intimate partner violence; OR = odds ratio.

Additional research is also needed to determine effective methods for physicians and other health care clinicians to identify asymptomatic children at risk or currently experiencing abuse or neglect. Instruments applicable to children of all ages need to be developed, validated, and tested in the screening population. The lack of studies of older children, which was identified in the previous USPSTF report as an important evidence gap, has yet to be addressed. Efforts to improve the identification of abused and neglected children need to be coupled with the development and evaluation of effective interventions to which they can be referred once identified.

Research is also needed to confirm the efficacy of the observed benefits reported in the included intervention studies and expand their applicability. Standardization of interventions and outcomes would strengthen the evidence and allow quantitative meta-analysis. This research should also determine whether there are unintended harms as a result of screening, risk assessment, and interventions.

## Conclusions

A trial of screening for risk of abuse and neglect among families with children age 5 years and younger in pediatric clinics indicated reductions in physical assault, CPS reports, episodes of nonadherence to medical care, and delays in immunizations among screened children. Risk factors were identified using an office-based questionnaire and were addressed by pediatricians supported by social work services in the clinic using existing health resources. Trials of early childhood home visitation reported reduced CPS reports, emergency visits, hospitalizations, and self-reports of abuse and neglect, as well as improved adherence to immunizations and well-child care. Clinicians are well positioned to identify children at risk for abuse and neglect and to connect families with appropriate prevention interventions. More research is needed in key areas to provide clinicians with methods to do so, and to demonstrate the effectiveness of interventions once risk for abuse and neglect is identified.