# RESULTS

## Key Question 1 For Children Without Obvious Signs and Symptoms of Abuse or Neglect, but Potentially at Increased Risk, How Well Do Behavioral Interventions and Counseling Initiated in Primary Care Settings Reduce Exposure to Abuse or Neglect, Physical or Mental Harms, or Mortality?

### Summary

Eleven fair-quality RCTs of interventions published since the previous review met inclusion criteria. One trial of risk assessment and interventions for abuse and neglect was conducted in pediatric clinics for families with children ages 5 years or younger. Results indicated significantly reduced physical assault, CPS reports, medical care nonadherence, and immunization delay among children randomized to screening compared with usual care 3 years after the intervention. Ten trials of early childhood home visitation reported reduced CPS reports, emergency visits, hospitalizations, and self-reports of severe abuse and neglect and improved adherence to immunizations and well-child care. Results were inconsistent across trials for most outcomes. Trials were limited by heterogeneity, low adherence, high loss to followup, and lack of standardized measures.

### Evidence

Clinic-based intervention trial. A trial based in a pediatric clinic compared outcomes of children whose parents underwent risk assessment followed by physician and clinic-based social work interventions as needed with outcomes of children receiving usual primary care67 (Appendix B1 and B2). The trial was based on the Safe Environment for Every Kid (SEEK) Model, which includes risk assessment during the course of usual primary care services, physician training in addressing risk factors for abuse and neglect, informational resources for parents and physicians, and social work services for families desiring them. Outcome measures were obtained from CPS reports, children’s medical charts, and parent responses on the Parent-Child Conflict Tactics Scale. Outcome data were collected at baseline and 3 years later.

The trial enrolled 729 participants from university-affiliated pediatric primary care resident continuity clinics serving low-income families in Baltimore. Children ranged from newborn to age 5 years, and most were African American with single mothers receiving Medicaid or State Children’s Health Insurance Programs. Clinics were cluster randomized to either the SEEK Model or usual care based on clinic day of the week. The usual care control group received standard pediatric care and an onsite human services worker with similar responsibilities as the social worker for the intervention group. For those randomized to the intervention group, risk factor assessment was conducted using the Parent Screening Questionnaire, a 20-item self-reported questionnaire of safety issues, including major risk factors for child abuse and neglect, such as parental depression and substance abuse (see Appendix C1). For those with positive responses, trained physicians addressed concerns and provided educational materials, treatment, and referrals as needed. A social worker provided clinic-based interventions on a case-by-case basis (personal communication with Howard Dubowitz, March 3, 2011).67

Seventy-six percent of enrolled participants completed the study protocol. Results indicated that while 12 percent of families in both groups were involved with CPS prior to the trial, families in the intervention group had fewer CPS reports than the usual care group up to 44 months after the intervention (13% vs. 19%; p=0.03). These findings represent all CPS reports except cases where abuse or neglect were explicitly ruled out. Also, parents in the intervention group reported fewer episodes of severe or very severe physical assault than usual care parents (average weighted Parent-Child Conflict Tactics Scale score, 0.11 vs. 0.33; p=0.04), fewer instances of nonadherence to medical care (5% vs. 8%; p=0.05), and fewer delays in immunizations (3% vs. 10%; p=0.002).

Factors reducing differences between groups include diffusion of the SEEK Model to the control clinics when physicians changed clinic days or communicated with colleagues, similarity of services for intervention and control groups, and surveillance bias that increased detection of abuse and neglect even in the absence of formal risk assessment. The study met criteria for fair quality because loss to followup was >20 percent, analysis was not intention-to-treat or not described, and randomized groups were not similar at followup. Applicability of the trial was limited by enrollment of participants from only one pediatric clinic setting serving a narrowly defined population, but was enhanced by using existing health care services within primary care practices to integrate risk assessment into usual health care processes.

Home visitation intervention trials. Ten trials that enrolled children on the basis of risk assessment for abuse and neglect and evaluated outcomes of home visitation interventions have been published since the previous USPSTF evidence review and met inclusion criteria (Appendix B1).39,68–76 The new publications contribute to results of trials that were included in the previous report.60,77–85 All trials used the same basic approach, but differed by enrollment criteria, duration of intervention and followup, type of provider, outcome measures, and other important factors.

All of the new included trials met criteria for fair quality because of specific methodological limitations or lack of information about methods (Appendix B2). These consist of inadequate inclusion and exclusion criteria,69 randomization or allocation concealment,39,69–74,76 or blinding;39,73, 75 low adherence with the intervention (≤50%);70–72 high loss to followup (>20%);39,71,73–76 dissimilar groups at baseline or followup;70,72,74,76 and lack of intention-to-treat analysis.39,68–76

Enrollment eligibility for most trials was based on the presence of risk factors for child abuse and neglect, such as inadequate prenatal care; young age of parents; limited finances, education, and social support; or substance abuse history (Table 2).69,73–75,77,80,81,84,85 In some studies, a two-step process was used that included an assessment of risk factors followed by an evaluation using a standardized instrument, such as the Kempe Family Stress Checklist.70–72,82

Table 2 Enrollment Criteria for Intervention Trials With Significant Benefit Outcomes

Criteria | | Elmira77–79 | Memphis68, 80 | Healthy Families Alaska 71 | Hawaii Healthy Start 70, 83 | Bugental 2002^82^ | Bugental 2009^39^ | Early Start Program 73 | Child First74 | Early Intervention Program76 | El-Mohandes 2003^75^ | Healthy Families New York72
Pregnancy-related factors | First pregnancy | XX | XX | | | | | | | XX
Pregnancy-related factors | Unplanned pregnancy | | | | | | | X^d^
Pregnancy-related factors | <26 or <29 weeks’ gestation | | XX | | | | | | | XX | XX
Pregnancy-related factors | Late, none, or poor prenatal care | | | | X
Pregnancy-related factors | History of abortion unsuccessfully sought | | | | X
Pregnancy-related factors | Adoption sought | | | | X
Parent-related factors | Parent age <18, <19, or <20 years | X^a^ | | | | | | X^d^ | | XX | | X^l^
Parent-related factors | Single parent | X^a^ | X^b^ | | X | | | | | | | X^l^
Parent-related factors | Low income or low socioeconomic status | X^a^ | | | X | X^c^ | | X^d^
Parent-related factors | <12 years education | | X^b^ | | X | X^c^ | | | | | | X^l^
Parent-related factors | Parent unemployed | | X^b^ | | X | X^c^
Parent-related factors | Unstable housing | | | | X | X^c^ | | | | | | X^l^
Parent-related factors | Low social support | | | | X | | | X^d^
Parent-related factors | History of substance abuse | | | X | X | | | X^d^
Parent-related factors | Parent in permanent caregiving environment | | | | | | | | X^g^
Parent-related factors | Parent requested participation | X^a^
Parent-related factors | Poor mental health/depression/psychiatric care | | | X | X
Parent-related factors | Domestic violence | | | X | | | | X^d^
Parent-related factors | No phone | | | | X
Parent-related factors | Marital or family problems | | | | X
Child-related factors | Child ages 6–36 months | | | | | | | | XX
Child-related factors | Child ages 0–5 years
Child-related factors | Infant at medical risk (Cesarean section, preterm, medical issue) | | | | | | XX
Child-related factors | Child with social-emotional or behavior problem: BITSEA^j^ | | | | | | | | X^g^
Health care– related factors | Parental risk factors on hospital chart | | | | XX
Health care– related factors | Nurse has concerns | | | | | | | X
Parent Screening | Kempe Family Stress Checklist^i^ | | | X^e^ | X^e^ | X^f^ | | | | | | X^h^
Parent Screening | Parent Screening Questionnaire
Parent Screening | Parent Risk Questionnaire | | | | | | | | X^g^
Parent Screening | Preliminary Screening Questionnaire | | | | | XX

X = Enrollment criteria.

XX = Required enrollment criteria.

a Need 1 of 3 criteria in addition to required.

b Need 2 of 3 criteria in addition to required.

c Need 2 or more criteria from Preliminary Screening Questionnaire.

d Need 2 or more criteria or nurse had concerns.

e Kempe Family Stress Checklist score ≥25.

f After meeting initial criteria, Kempe Family Stress Checklist score of 25–40 required.

g Child or adult may qualify. Child must be ages 6–36 months with social/emotional/behavioral problems or parent must screen high for risk on Parent Risk Questionnaire and be in a permanent caregiving environment.

h After meeting initial criteria; either parent must score ≥25.

i Kempe items include: abuse history, prior Child Protective Services involvement, current crisis, history of partner violence, belief in harsh punishment, perception that child is difficult, unrealistic child expectations, parental ambivalence about the child.

j Brief Infant-Toddler Social and Emotional Assessment.

k Intervention group only took the Parent Screening Questionnaire.

l These risk factors were given as an example, others may be used.

Home visits began either before or after birth and continued for 3 to 36 months after birth. The intervention was provided by either a paraprofessional, such as a lay person who had participated in a 9-week training course (nine trials),69–73,75,81,82,85 or a professional, typically a nurse (five trials).74,76–80,84,86

The trials were conducted in the United States, Canada, Australia, New Zealand, and the United Kingdom. Most were modeled after trials initiated more than 15 years ago in Elmira, New York77 and Memphis, Tennessee.80 In these trials, subjects were randomized to one of four groups, including: 1) no home visitation; 2) developmental screening and referral, with transportation services to the medical clinic during pregnancy; 3) home visitation during pregnancy every 2 weeks and two postpartum visits, in addition to transportation services; and 4) home visitation continuing through the child’s second birthday, in addition to transportation services. In the Elmira study, the goals of home visitation included parent education, enhancement of support systems for the mother, and engagement of family members with health and social services.77 In the Memphis study, goals included improvement of health-related behaviors for better pregnancy outcomes and child health, financial stability of families by helping parents find employment and complete their educations, and family planning.80

Trials evaluated child mortality,68 CPS reports (six trials),69–74 legal removal of the child from home (two trials),69,70 emergency visits (three trials),71,73,76 and hospitalizations (five trials).69–71,73,76 Trials also reported additional relevant measures of medical neglect that were not included in the previous report, including adherence with early childhood immunizations (eight trials)73,75,76,78,80,83–85 and adherence with well-child visits (five trials).73,75,80,83,85 Six trials described self-reports of severe abuse and slapping or spanking of infants.39,70–73,82

Child mortality. In a long-term followup study of the Memphis trial that included 743 children, those receiving home visits by a nurse as infants were less likely to die by age 9 years than those in the usual care control group, although results were of borderline statistical significance (1 vs. 10 deaths; p=0.08) (Table 3).68 In this study, the one death in the home visit group was the result of chromosomal abnormalities, whereas, of the 10 children who died in the control group, three died from complications of prematurity, three from Sudden Infant Death Syndrome, three from injury (homicide assault by firearm, accidental injury from firearm, and motor vehicle accident), and one from an intestinal infection.

Table 3 Home Visitation Trial Reporting Child Mortality

Author, Year Study | N; Study Duration | Referral Method; Country | Results, Intervention vs. Control | Quality
Olds et al, 2007^68^ Memphis Trial | 743; 9 years | Prenatal clinics; United States | 1 vs. 10 deaths; OR, 0.22 (95% CI, 0.03 to 1.74); p=0.08 | Fair

CI = confidence interval; OR = odds ratio.

CPS reports. Six trials provided CPS reports as an outcome, including confirmed CPS reports,70–72 all types of CPS reports,69,74 and parent descriptions of CPS reports73 (Table 4). No trials found differences in rates of CPS reports between home-visited and control groups while the studies were ongoing.69–74 However, one trial found that children visited by a professional clinical team had decreased CPS involvement at 3 years after enrollment (odds ratio [OR] for effect of the intervention, 2.1 [95% CI, 1.0 to 4.4]).74 Three trials had very low (<50%) rates of family participation.70–72

Table 4 Home Visitation Trials Reporting Child Protective Services Reports

Author, Year; Study | N; Study Duration | Referral Method; Country | Results, Intervention vs. Control | Quality
Current Report
Barlow et al, 2007^69^ Family Partnership Model | 121; 18 months | Prenatal clinics; United Kingdom | Child protection register or care proceedings: RR, 2.02 (95% CI, 0.46–2.54) Child protection issues: 17% vs. 15%; NS Removal of child from home: 6% (4/68) vs. 0% (0/63); NS | Fair
Duggan et al, 2007^71^ Healthy Families Alaska | 364; 2 years | Community agencies; United States | Substantiated or overall CPS reports: no difference | Fair
Duggan et al, 2004^70^ Hawaii Healthy Start Program | 643; 3 years | Prenatal clinics; United States | No difference | Fair
DuMont et al, 2008^72^ Healthy Families New York | 1173; 2 years | University hospital; United States | CPS reports: no difference | Fair
Fergusson et al, 2005^73^ | 433; 3 years | Communitywide screening; New Zealand | CPS reports: no difference | Fair
Lowell et al, 2011^74^ | 157; 3 years | Primary care clinics, WIC programs; United States | CPS involvement at 36 months: 14% vs. 31%; OR, 2.1 (95% CI, 1.1–4.4); p<0.05 | Fair
Previous Report
Barth et al, 1991^81^ Child Parent Enrichment Project | 191; 6 months | Various agencies; United States | By family: increase in number of unsubstantiated reports: 13 vs. 10; NS; increase in number of substantiated reports: 10 vs. 13; NS By report: increase in number of unsubstantiated reports: 20 vs. 41; NS; increase in number of substantiated reports: 19 vs. 5; NS | Fair
Olds et al, 1986^77^ Elmira Trial | 400; 2 years | Prenatal clinics; United States | Higher risk subgroup (poor, unmarried teens): confirmed reports of abuse/neglect, 4% vs. 19%; p=0.07 Entire sample: no difference | Good
Olds et al, 1994,^78^ Elmira Trial | 400; 4 years | Prenatal clinics; United States | New cases, whole sample: OR, 0.56 (95% CI, 0.00–1.37) | Good
Eckenrode et al, 2000^79^ Elmira Trial | 400; 15 years | Prenatal clinics; United States | Incidence rate for substantiated child maltreatment reports involving mother as perpetrator: 0.32 vs. 0.65; p=0.01 Incidence rate for substantiated reports involving the study child as subject: 0.44 vs. 0.73; p=0.04 | Good
Siegel et al, 1980^85^ | 321; 1 year | Prenatal clinic; United States | 14 vs. 9 reports; NS | Fair

CI = confidence interval; CPS = Child Protective Services; NS = not significant; OR = odds ratio; RR = relative risk; WIC = supplementary nutrition program for Women, Infants, and Children.

The previous USPSTF review found inconsistent effects on CPS reports (Table 4). In the only good-quality trial,77 results of a subgroup analysis at 2-year followup found that poor, high-risk teenage mothers who were visited by nurses were less likely to commit acts of confirmed child abuse and neglect compared with those without visits (4% vs. 19%; p=0.07). However, there were no differences for the entire sample, and results at 3- and 4-year followup showed no differences.78 At the 15-year followup, children in the nurse-visited group were less likely to be involved in substantiated CPS reports (incidence rate, 0.44 vs. 0.73; p=0.04).79 Also, nurse-visited mothers were less likely to be a substantiated perpetrator of child abuse (incidence rate, 0.32 vs. 0.65; p=0.01), regardless of the child involved (study child or other child), over the same 15-year period. Two other fair-quality trials of visits by paraprofessionals found no differences in total CPS reports after either 1^85^ or 3^81^ years of followup.

Removal of the child from the home. Two trials reported removal of the child from the home (Table 5).69,70 Although both reported higher proportions of children removed from the home in the home-visited group than in the control group, differences were not statistically significant over 18 (6% vs. 0%; p=not significant)69 or 36 months of followup (1.8% vs. 0.8%; p=not significant).70 The previous USPSTF review found no studies evaluating this outcome.

Table 5 Home Visitation Trials Reporting Removal of the Child From the Home

Author, Year Study | N; Study Duration | Referral Method; Country | Results, Intervention vs. Control | Quality
Barlow et al, 2007^69^ Family Partnership Model | 121; 18 months | Prenatal clinics; United Kingdom | Removal of child from home: 6% (4/68) vs. 0% (0/63); NS | Fair
Duggan et al, 2004^70^ Hawaii Healthy Start Program | 643; 3 years | Prenatal clinic; United States | Placement in foster care: 1.8% vs. 0.8%; NS | Fair

NS = not significant.

Emergency visits. Three trials evaluated hospital emergency visits by enrolled children (Table 6).71, 73,76 A trial specifically evaluating visits for injuries or ingestions reported reduced hospital visits for home-visited children (OR, 0.59 [95% CI, 0.36 to 0.98]).73 Two other trials reported no differences in emergency visits for ambulatory care sensitive conditions (i.e., visits that might have been prevented if timely and appropriate care had been provided),71 or total number of all types of indications.76 However, the latter trial found that a significantly greater number of mothers in the intervention group never used the emergency room for child health problems compared with those in the control group (36% vs. 11%; p<0.05).

Table 6 Home Visitation Trials Reporting Emergency Department Visits

Author, Year Study | N; Study Duration | Referral Method; Country | Results, Intervention vs. Control | Quality
Current Report
Duggan et al, 2007^71^ Healthy Families Alaska | 364; 2 years | Prenatal clinics; United States | Emergency visits in first 2 years: 81% vs. 78%; p=0.42 | Fair
Fergusson et al, 2005^73^ Early Start Program | 433; 3 years | Community nurses; New Zealand | Proportion seen in hospital for accident/injury or accidental poisoning (0 to 36 months): 17.5% vs. 26.3%; p<0.05; OR, 0.59 (95% CI, 0.36–0.98) | Fair
Koniak Griffin et al, 2003^76^ | 101; 2 years | Community Health Services; United States | Total number of children with emergency visits: 64% vs. 89%; NS Never used emergency services for child health problems: 36% vs. 11%; p<0.05 | Fair
Previous Report
Duggan et al, 1999^83^ Hawaii Healthy Start Program | 643; 3 years | Prenatal clinic; United States | Ever used emergency services, first 2 years: 58% vs. 60%; p=0.69 | Fair
Kitzman et al, 1997^80^ Memphis Trial | 1139; 2 years | Public obstetric clinic; United States | Adjusted incidence of emergency visits for injuries/ingestions during first 2 years: 0.33 vs. 0.34; NS | Fair
Olds et al, 1986^77^ Elmira Trial | 400; 2 years | Prenatal clinics; United States | Intervention children had fewer visits to emergency room during their 1st and 2nd years (p<0.05 and p<0.01, respectively) and presented with fewer accidents and poisonings at 2 years (p<0.05) | Good
Olds et al, 1994,^78^ Elmira Trial | 400; 4 years | Prenatal clinics; United States | Nurse-visited children made 35% fewer visits to emergency department than controls (p=0.0008) | Good
Siegel et al, 1980^85^ | 321; 1 year | Prenatal clinic; United States | No difference in health care utilization, including emergency visits | Fair

CI = confidence interval; NS = not significant; OR = odds ratio.

The previous USPSTF review included three trials80,83,85 showing no differences in emergency visits and one trial indicating fewer visits for home-visited children77,78 (Table 6). In this good-quality trial, nurse-visited children were less likely to visit hospital emergency services at several points of followup during their first 4 years (p<0.05).77,78 They were also less likely to be seen specifically for accidents and poisoning during their second year (p<0.01), although this difference was not significant for longer followup. A fair-quality trial found no difference in emergency visits specifically for injuries and ingestions, but reported that nurse-visited children had fewer outpatient visits for injuries and ingestions than children in the control group (p<0.05).80 Two other trials found no difference in total emergency visits for children visited by a paraprofessional during their first83,85 or second year.83

Hospitalizations. Five new trials reported no significant effects of home visitation on the number or percentage of children hospitalized in general,69,76 due to child abuse and neglect,73 or for ambulatory care sensitive conditions70,71 (Table 7). A trial with a 12-month nurse visitation intervention and followup of an additional 12 months found that nurse-visited children had fewer episodes of hospitalizations for all indications (19 vs. 36; p<0.01), and fewer mean hospitalization days (211 vs. 143; p<0.001) at 24 months than children in the control group.76

Table 7 Home Visitation Trials Reporting Hospitalizations

Author, Year Study | N; Study Duration | Referral Method; Country | Results, Intervention vs. Control | Quality
Current Report
Barlow et al, 2007^69^ Family Partnership Model | 121; 18 months | Prenatal clinics; United Kingdom | Proportion of admissions to hospital (maternal report): 8.1% vs. 14.3%; RR, 1.38 (95% CI, 0.68–2.8) | Fair
Duggan et al, 2004^70^ Hawaii Healthy Start Program | 643; 3 years | Prenatal clinic; United States | For those with complete hospitalization data: trauma admissions, 1.5% vs. 1.7%; NS; ambulatory care sensitive conditions, 12% vs. 10%; p=0.39 | Fair
Duggan et al, 2007^71^ Healthy Families Alaska | 364; 2 years | Prenatal clinics; United States | Child hospitalized for ambulatory care sensitive conditions: 9% vs. 9%; p=0.80 | Fair
Fergusson et al, 2005^73^ Early Start Program | 433; 3 years | Community nurses; New Zealand | Admitted to hospital for child abuse or neglect: 1% vs. 2%; p=0.31 | Fair
Koniak Griffin et al, 2003^76^ | 101; 2 years | Community Health Services; United States | Children hospitalized: 21% vs. 36%; NS Episodes of hospitalizations for all indications: 19 vs. 36; p<0.01 Days infants hospitalized: 143 vs. 211 days; p<0.001 | Fair
Previous Report
Duggan et al, 1999^83^ Hawaii Healthy Start Program | 643; 3 years | Prenatal clinic; United States | Ever hospitalized for any reason during the first 2 years: 19% vs. 22%; p=0.44 | Fair
Kitzman et al, 1997^80^ Memphis Trial | 1139; 2 years | Prenatal clinic; United States | Adjusted incidence of hospitalizations for injuries or ingestions: 0.01 vs. 0.03; NS Days hospitalized for injuries or ingestions: 7 vs. 89; p=0.001 | Fair
Olds et al, 1994,^78^ Elmira Trial | 400; 4 years | Prenatal clinics; United States | Mean number of hospitalizations: 0.14 vs. 0.11; NS | Good
Siegel et al, 1980^85^ | 321; 1 year | Prenatal clinic; United States | Number of hospitalizations: no difference | Fair

CI = confidence interval; NS = not significant; RR = relative risk.

Four trials from the previous review reporting hospitalizations found no differences between groups,78,80,83,85 however, one reported significantly fewer hospital days for nurse-visited children (7 vs. 89 days; p=0.001).80 This trial also reported differences in the types of injuries. The three nurse-visited children were hospitalized for burns to the face, coin ingestion, and ingestion of iron medication for a total of 7 hospital days. The 13 control-group children were hospitalized for fractures (fibula, tibia, skull [two children]), head trauma without skull fracture (three children), strangulated hernia with delay in care, coin ingestion, suspected child abuse and neglect, burns (face and neck, both legs), and finger injury with osteomyelitis for a total of 89 hospital days.80

Adherence with child immunizations and well-child visits. Since 2003, three trials included measures of potential medical neglect, either nonadherence with recommended immunizations or well-child visits or both73,75,76 (Table 8). In one trial, home-visited children received immunizations at an earlier age than children in the control group, resulting in significant differences between groups through age 9 months (2.20 vs. 1.64 mean visits; p=0.01), but not at 12 months, although the trend continued.75 Other trials indicated no differences in the second76 or third year.73 A trial reporting significant differences in the mean number of well-child visits at 9 (3.14 vs. 2.18 mean visits; p=0.0098) and 12 months (3.51 vs. 2.68 mean visits; p=0.0098) also found that the more contact the children had with study personnel, the more well-child visits they experienced at 12 months, for up to at least four visits (p=0.036).75 In another trial of home visitation for the first 24 months, home-visited children were more likely to be up to date with well-child visits (42% vs. 30%; p<0.05) and enrolled for dental care (72% vs. 63%; p<0.05) over a 36-month period than children not in the program.73

Table 8 Home Visitation Trials Reporting Adherence With Immunizations and Well-Child Visits

Author, Year Study | N; Study Duration | Referral Method; Country | Immunization Results, Intervention vs. Control | Well-Child Visit Results, Intervention vs. Control | Quality
Current Report
El-Mohandes et al, 2003^75^ | 286; 1 year | Obstetric hospital; United States | Mean # of immunization visits: At 4 mo: 1.01 vs. 0.77; p=0.0498 At 6 mo: 1.50 vs. 1.13; p=0.0295 At 9 mo: 2.20 vs. 1.64; p=0.0125 At 12 mo: 2.44 vs. 2.00; p=0.08 | Well-infant care: Mean # of visits at 9 mo: 3.14 vs. 2.18; p=0.0098 Mean # of visits at 12 mo: 3.51 vs. 2.68; p=0.0098 Intensity of well-infant visits (12 mo): At least 1 visit: 93.6% vs. 75.3%; p=0.0022 At least 2 visits: 89.4% vs. 63.6%; p=0.0007 At least 3 visits: 78.7% vs. 51.9%; p=0.0018 At least 4 visits: 59.6% vs. 41.6%; p=0.0363 At least 5 visits: 27.7% vs. 23.4%; p=0.3475 | Fair
Fergusson et al, 2005^73^ Early Start Program | 433; 3 years | Community nurses; New Zealand | Up to date with immunizations: 92.5% vs. 91.9%; p=0.83 | Up to date with well-child visits: 41.9% vs. 30.1%; p<0.05 Enrolled for dental care: 72% vs. 63%; p<0.05 | Fair
Koniak-Griffin et al, 2003^76^ | 101; 2 years | Community Health Services; United States | Adequately immunized: 77% vs. 87%; NS | Not reported | Fair
Older Trials
Duggan et al, 1999^83^ Hawaii Healthy Start Program | 643; 3 years | Prenatal clinic; United States | Immunizations up to date: 87% vs. 85%; p=0.45 | Adequate # of well-child visits: 60% vs. 59%; p=0.95 | Fair
Fraser et al, 2000^84^ | 181; 1 year | Obstetric hospital; Australia | Age-appropriate completed immunizations: no difference (values not reported) | Not reported | Fair
Kitzman et al, 1997^80^ Memphis Trial | 1139; 2 years | Prenatal clinic; United States | Immunizations: 70% vs. 68%, OR, 1.1 (95% CI, 0.7–1.5) | Mean # of well-child visits (0–24 mo): 4.6 vs. 4.8; NS | Fair
Olds et al, 1994^78^ Elmira Trial | 400; 4 years | Prenatal clinics; United States | Mean # of health supervision visits: 1.26 vs. 1.56; NS | Not reported | Good
Siegel et al, 1980^85^ | 321; 1 year | Prenatal clinic; United States | Immunizations: no difference | Preventive care visits: no difference | Fair

CI = confidence interval; NS = not significant; OR = odds ratio.

Adherence with immunizations and well-child visits was not addressed by the previous review. Five trials published before 2003 indicate no significant differences between groups.78,80,83–85

Self-reports of abusive behavior toward the child. Five trials used the Parent-Child subscale of the Conflict Tactics Scale to assess mothers’ self reports of severe abusive behaviors toward their children or infants39,70–73 (Table 9). One trial found a significant difference in self-reported severe physical assault at 36 months (4% of home-visited mothers vs. 12% of control-group mothers; p<0.01).73 While another trial indicated no differences in the prevalence of abuse at 24 months, home-visited mothers reported one fourth as many acts of serious physical abuse, such as kicking or hitting the child with a fist, compared with control-group mothers (p=0.03).72 Two other trials reported no differences in severe child maltreatment between groups.70,71 In a trial comparing a cognitive-based extension of the Healthy Start home visitation program with the usual Healthy Start program, there were few instances of self-reported infant abuse on the Conflict Tactics Scale.39

Table 9 Home Visitation Trials Reporting Self-Reports of Child Abuse and Neglect

Author, Year Study | N; Study Duration | Referral Method; Country | Results, Intervention vs. Control | Quality
Current Report
Bugental et al, 2009^39^ | 110; 1 year | Health care providers, social workers; United States | Self-reported physical abuse: 4% vs. 5% | Fair
Duggan et al, 2004^70^ Hawaii Healthy Start Program | 643; 3 years | Prenatal clinic; United States | Self-reported severe physical abuse (year 3): 22% vs. 15%; p=0.17 Self-reported very severe physical abuse (year 3): 6% vs. 7% | Fair
Duggan et al, 2007^71^ Healthy Families Alaska | 364; 2 years | Prenatal clinics; United States | Self-reported severe assault: 9% vs. 7%; p=0.67 | Fair
DuMont et al, 2008^72^ Healthy Families New York | 1173; 2 years | Various agencies; United States | Self-reported episodes of very serious abuse: 0.01 vs. 0.08; p=0.04 (significant at year 1 only) Self-reported episodes of serious physical abuse: 0.01 vs. 0.04; p=0.03 (significant at year 2 only) | Fair
Fergusson et al, 2005^73^ Early Start Program | 433; 3 years | Community nurses; New Zealand | Proportion of parents reporting severe physical punishment: 4.4% vs. 11.7%; p<0.01; OR, 0.35 (95% CI, 0.15–0.80) | Fair
Older Trials
Bugental et al, 2002^82^ | 96; 1 year | Primary care clinics; United States | Prevalence of infant spanking/slapping: 18% vs. 42%; p<0.05 | Fair

CI = confidence interval; OR = odds ratio.

Self-reported child abuse was not addressed by the previous USPSTF review. One trial published before 2003 found that parents of high-risk infants (i.e., preterm infants or infants with low Apgar scores) in an enhanced home visitation group reported less infant spanking and slapping than parents of high-risk infants in unenhanced home visitation and control groups (18% vs. 42% in the unenhanced and control groups combined; p<0.05).82

## Key Question 2 What Are the Adverse Effects of Behavioral Interventions and Counseling to Reduce Harm From Abuse and Neglect?

Adverse effects of interventions were not explicitly evaluated in the trials, and additional studies of adverse effects were not identified by the literature searches. Although not described in the publication, during the SEEK trial, investigators maintained regular contact with the pediatric primary care practices involved in the trial and actively monitored potential adverse effects. No adverse effects were reported by participants (personal communication with Howard Dubowitz, March 3, 2011).