# METHODS

## Key Questions and Analytic Framework

Based on evidence gaps identified from the previous review,3,4,56 the USPSTF and Agency for Healthcare Research and Quality (AHRQ) determined the key questions for this update using the methods of the USPSTF.57 Investigators created an analytic framework incorporating the key questions and outlining the patient populations, interventions, outcomes, and potential adverse effects (Figure).

Figure Analytic Framework

* Child Protective Services reports, removal of the child from the home, and reports of abuse or neglect.

** Physical injuries, mental health conditions, use of health care services, adherence with immunizations and well-child visits, and other relevant health measures.

Key Questions

1. For children without obvious signs and symptoms of abuse or neglect, but potentially at increased risk, how well do behavioral interventions and counseling initiated in primary care settings reduce exposure to abuse or neglect, physical or mental harms, or mortality?
2. What are the adverse effects of behavioral interventions and counseling to reduce harm from abuse and neglect?

### Key Questions

1. For children without obvious signs and symptoms of abuse or neglect, but potentially at increased risk, how well do behavioral interventions and counseling initiated in primary care settings reduce exposure to abuse or neglect, physical or mental harms, or mortality?
2. What are the adverse effects of behavioral interventions and counseling to reduce harm from abuse and neglect?

The target population includes children from birth to age 18 years and their caregivers who interact with health care providers in clinical settings where primary care is delivered to children. The review does not include studies of children with signs, symptoms, or complaints of abuse or neglect because children with these findings would undergo evaluations outside the scope of primary prevention recommendations.

The outcomes included in this review incorporate current accepted definitions of child abuse and neglect, an understanding of a continuum of potential outcomes, and acknowledgement that only some outcomes are actually measureable in research studies. Intermediate outcomes, such as referral rates or measures of parent-child bonding, are outside the scope of this review. Based on these considerations, main outcomes include measures of reduced exposure to abuse and neglect (CPS reports, removal of the child from home, and caregiver self-reports of abuse or neglect), measures of health outcomes related to abuse (physical injuries, mortality, emergency department visits, and hospitalizations), and measures of child neglect (adherence with immunizations and well-child visits). For self-reported measures of abuse, we report severe and very severe abuse and harsh parenting (spanking and slapping) directed at infants.

## Search Strategies

In conjunction with a research librarian, investigators used the National Library of Medicine’s medical subject headings keyword nomenclature to search the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews through the second quarter of 2012, and MEDLINE and PsycINFO from 2002 to June 2012 for relevant English-language studies, systematic reviews, and meta-analyses. Search strategies are listed in Appendix A1. Secondary referencing was done by manually reviewing reference lists of papers and reviewing citations of key studies using Scopus.

## Study Selection

Investigators developed inclusion and exclusion criteria for abstracts and articles based on the target population, key questions, and outcome measures (Appendix A2). Research conducted in the United States or in similar populations who receive services and interventions applicable to medical practice in the United States published in 2003 or later was considered. After an initial review of abstracts, full-text articles were reviewed using additional inclusion criteria. Studies rated poor-quality were excluded. Appendix A3 shows the results of the literature search and selection process and Appendix A4 lists excluded studies with reasons for their exclusion.

Randomized, controlled trials (RCTs) of the effectiveness of behavioral interventions and counseling to reduce exposure to abuse or neglect or improve health outcomes were included. Studies were eligible for inclusion if they enrolled children without obvious signs or symptoms of abuse or neglect, used a method to identify families or children at risk that was applicable to primary care, evaluated an intervention that primary care clinicians could access or provide referral to, measured outcomes related to abuse or neglect (specified above), and compared outcomes between intervention and nonintervention groups. All types of CPS reports (confirmed/not confirmed) were included because research indicates no association between substantiation status and behavioral and developmental outcomes.58 Studies that focused on clinician education, methods to increase screening rates, perceptions and attitudes of physicians and other clinicians, studies of public awareness campaigns or other interventions not applicable to primary care settings, and studies of interventions directed at perpetrators were not included. Studies that reported use of services or referral for services as outcome measures without also reporting abuse or health outcomes were also not included.

Studies of any design were included to describe potential adverse effects of behavioral interventions and counseling. Potential adverse effects include escalating levels of abuse and neglect; false-positive evaluations; adverse consequences as a result of the investigation process; labeling, stigmatizing, and psychological distress; dissolution of families; and legal issues, among others.

## Data Abstraction and Quality Rating

An investigator abstracted data about the study design and setting, participant characteristics, data collection procedures, numbers enrolled and lost to followup, methods of exposure and outcome ascertainment, analytic methods including adjustment for confounders, and outcomes. A second investigator confirmed the accuracy of data. By using predefined criteria developed by the USPSTF (described in Appendix A5),57,59 two investigators rated the quality of studies (good, fair, poor) and resolved discrepancies by consensus. Studies that met basic inclusion criteria but had important design or methodologic flaws that compromised results (i.e., poor-quality rating) were not included in this report.60–65 The applicability of studies was determined using the PICOTS (population, intervention, comparator, outcomes, timing of outcomes measurement, and setting) format, adapted to this topic.66

## Data Synthesis

We assessed the aggregate quality of the body of evidence for each key question (good, fair, poor) using methods developed by the USPSTF based on the number, quality, and size of studies and consistency of results between studies.57 Studies were considered consistent if outcomes were generally in the same direction of effect and ranges of effect sizes were narrow. No meta-analysis was performed because of the heterogeneity of the participants, interventions, outcome measurements, and followup periods, and because data were provided and analyzed in a variety of ways.

## External Review

The draft report was reviewed by content experts, USPSTF members, AHRQ Project Officers, and collaborative partners (Appendix A6).