# Supplemental Materials

Appendix C1 Parent Screening Questionnaire