# Evidence Tables and Quality Tables

Appendix B1 Data Abstraction of Intervention Trials

Appendix B2 Quality Ratings of Intervention Trials