# Detailed Methods

## Appendix A1 Search Strategies

Search strategies of various populations (children, elder/vulnerable individuals, and adult women) were combined into one library and reviewed concurrently; therefore, strategies for all of these populations are included below.

### Searches for Randomized, Controlled Trials

#### Children

Database: EBM Reviews – Cochrane Central Register of Controlled Trials

1. ((domestic$ or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. ((baby or babies or infan$ or toddler$ or child$ or teen$ or adolescen$) adj5 (violen$ or abus$ or batter$ or assault$)).mp.
3. from 2 keep 1–808

#### Elder

Database: EBM Reviews – Cochrane Central Register of Controlled Trials

1. ((domestic$ or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. ((baby or babies or infan$ or toddler$ or child$ or teen$ or adolescen$) adj5 (violen$ or abus$ or batter$ or assault$)).mp.
3. ((elder$ or parent$ or mother$ or father$) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
4. from 3 keep 1–396

#### Spouse

Database: EBM Reviews – Cochrane Central Register of Controlled Trials

1. ((domestic$ or family or families or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. from 1 keep 1–387

### Searches for Systematic Reviews

#### Children

Database: EBM Reviews – Cochrane Database of Systematic Reviews

1. ((domestic$ or family or families or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. ((baby or babies or infan$ or toddler$ or child$ or teen$ or adolescen$) adj5 (violen$ or abus$ or batter$ or assault$)).mp.
3. from 2 keep 1–88

#### Elder

Database: EBM Reviews – Cochrane Database of Systematic Reviews

1. ((domestic$ or family or families or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. ((baby or babies or infan$ or toddler$ or child$ or teen$ or adolescen$) adj5 (violen$ or abus$ or batter$ or assault$)).mp.
3. ((elder$ or parent$ or mother$ or father$) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
4. from 3 keep 1–56

#### Spouse

Database: EBM Reviews – Cochrane Database of Systematic Reviews

1. ((domestic$ or family or families or spous$ or husband$ or wife or wives or cohabitat$ or (intimat$ adj2 partner$)) adj5 (violen$ or abus$ or batter$ or assault$ or attack$ or aggressi$ or altercat$)).mp.
2. from 1 keep 1–59

### Searches for Interventions

#### Domestic

Database: Ovid MEDLINE

1. exp domestic violence/
2. exp battered women/
3. 1 or 2
4. exp Family Practice/
5. exp Primary Health Care/
6. exp Physicians, Family/
7. exp Emergency Medicine/
8. exp Emergency Medical Services/
9. 4 or 5 or 6
10. 7 or 8
11. exp Preventive Health Services/
12. exp Counseling/
13. exp Mental Health Services/
14. exp "Outcome and Process Assessment (Health Care)"/
15. 3 and 9
16. 3 and 10
17. 3 and 11
18. 3 and 12
19. 3 and 13
20. 3 and 14
21. 15 or 16 or 17 or 18 or 19 or 20
22. limit 21 to (english language and yr="2002 -Current")
23. from 22 keep 1–1687

Database: PsycINFO

1. exp Domestic Violence/
2. exp pediatrics/
3. (pediatrician$ or paediatrician$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
4. exp gerontology/
5. gerontologist$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
6. exp Family Medicine/
7. exp Primary Health Care/
8. exp General Practitioners/
9. exp Family Physicians/
10. (primary care or family medicine or family practice or general practice or gp).mp. [mp=title, abstract, heading word, table of contents, key concepts]
11. exp Emergency Services/
12. (emergency or emergencies).mp. [mp=title, abstract, heading word, table of contents, key concepts]
13. 2 or 3
14. 4 or 5
15. 6 or 7 or 8 or 9 or 10
16. 11 or 12
17. 1 and 13
18. 1 and 14
19. 1 and 15
20. 1 and 16
21. 17 or 18 or 19 or 20
22. from 21 keep 1–205

#### Children

Database: Ovid MEDLINE

1. exp Child Abuse/
2. exp Domestic Violence/
3. limit 2 to "all child (0 to 18 years)"
4. 1 or 3
5. exp Schools/
6. crime/or exp crime victims/or exp homicide/or exp sex offenses/or exp violence/
7. 5 and 6
8. limit 7 to "all child (0 to 18 years)"
9. 4 or 8
10. exp Family Practice/
11. exp Primary Health Care/
12. exp Physicians, Family/
13. pediatrician$.mp.
14. exp Pediatrics/
15. exp Emergency Medicine/
16. exp Emergency Medical Services/
17. 10 or 11 or 12
18. 9 and 17
19. 13 or 14
20. 9 and 19
21. 15 or 16
22. 9 and 21
23. 18 or 20 or 22
24. exp Preventive Health Services/
25. exp Counseling/
26. 9 and 24
27. 9 and 25
28. exp Mental Health Services/
29. 9 and 28
30. limit 9 to clinical trial, all
31. exp "Outcome and Process Assessment (Health Care)"/
32. 9 and 31
33. 23 or 26 or 27 or 30 or 32
34. limit 33 to english language
35. limit 34 to yr="2002 -Current"
36. from 35 keep 1–1317

Database: PsycINFO

1. exp Child Abuse/
2. exp Child Neglect/
3. 1 or 2
4. exp Domestic Violence/
5. limit 4 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
6. exp Physical Abuse/
7. exp Emotional Abuse/
8. exp Sexual Abuse/
9. 6 or 7 or 8
10. limit 9 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
11. 3 or 5 or 10
12. exp Pediatrics/
13. (pediatrician$ or paediatrician$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
14. exp Family Medicine/
15. exp Primary Health Care/
16. exp General Practitioners/
17. exp Family Physicians/
18. (primary care or family medicine or family practice or general practice or gp).mp. [mp=title, abstract, heading word, table of contents, key concepts]
19. exp Emergency Services/
20. (emergency or emergencies).mp. [mp=title, abstract, heading word, table of contents, key concepts]
21. 12 or 13
22. 11 and 21
23. 14 or 15 or 16 or 17 or 18
24. 11 and 23
25. 19 or 20
26. 11 and 25
27. 22 or 24 or 26
28. limit 27 to yr="2002 -Current"
29. from 28 keep 1–243

#### Elder

Database: Ovid MEDLINE

1. exp elder abuse/
2. exp Domestic Violence/
3. limit 2 to "all aged (65 and over)"
4. 1 or 3
5. exp residential facilities/
6. crime/or exp crime victims/or exp homicide/or exp sex offenses/or exp violence/
7. 5 and 6
8. limit 7 to "all aged (65 and over)"
9. 4 or 8
10. exp Family Practice/
11. exp Primary Health Care/
12. exp Physicians, Family/
13. gerontologist$.mp.
14. exp geriatrics/
15. exp Emergency Medicine/
16. exp Emergency Medical Services/
17. 10 or 11 or 12
18. 9 and 17
19. 13 or 14
20. 9 and 19
21. 15 or 16
22. 9 and 21
23. 18 or 20 or 22
24. exp Preventive Health Services/
25. exp Counseling/
26. 9 and 24
27. 9 and 25
28. exp Mental Health Services/
29. 9 and 28
30. limit 9 to clinical trial, all
31. exp "Outcome and Process Assessment (Health Care)"/
32. 9 and 31
33. 23 or 26 or 27 or 29 or 30 or 32
34. limit 33 to (english language and yr="2002 -Current")
35. from 34 keep 1–250

Database: PsycINFO

1. exp elder abuse/
2. exp Domestic Violence/
3. limit 2 to "380 aged <age 65 yrs and older>"
4. exp Physical Abuse/
5. exp patient abuse/
6. exp Emotional Abuse/
7. exp Sexual Abuse/
8. 4 or 5 or 6 or 7
9. limit 8 to "380 aged <age 65 yrs and older>"
10. 1 or 3 or 9
11. exp gerontology/
12. gerontologist$.mp. [mp=title, abstract, heading word, table of contents, key concepts]
13. exp Family Medicine/
14. exp Primary Health Care/
15. exp General Practitioners/
16. exp Family Physicians/
17. (primary care or family medicine or family practice or general practice or gp).mp. [mp=title, abstract, heading word, table of contents, key concepts]
18. exp Emergency Services/
19. (emergency or emergencies).mp. [mp=title, abstract, heading word, table of contents, key concepts]
20. 11 or 12
21. 10 and 20
22. 13 or 14 or 15 or 16 or 17
23. 10 and 22
24. 18 or 19
25. 10 and 24
26. 21 or 23 or 25
27. limit 26 to yr="2002 -Current"
28. from 27 keep 1–63

#### Spouse

Database: Ovid MEDLINE

1. Spouse Abuse/
2. ((spous$ or wife or husband or boyfriend$ or girlfriend$ or married or marriage$ or intimate partner$ or common law or cohabitat$) adj5 (abus$ or violen$ or attack$ or assault$ or batter$)).mp.
3. exp Family Practice/
4. exp Primary Health Care/
5. exp Physicians, Family/
6. exp Emergency Medicine/
7. exp Emergency Medical Services/
8. 3 or 4 or 5
9. 6 or 7
10. exp Preventive Health Services/
11. exp Counseling/
12. exp Mental Health Services/
13. exp "Outcome and Process Assessment (Health Care)"/
14. 2 and 8
15. 2 and 9
16. 2 and 10
17. 2 and 11
18. 2 and 12
19. 2 and 13
20. 14 or 15 or 16 or 17 or 18 or 19
21. limit 20 to (english language and yr="2002 -Current")
22. from 21 keep 1–611

Database: PsycINFO

1. exp partner abuse/
2. exp battered women/
3. 1 or 2
4. exp Domestic Violence/
5. exp marriage/
6. exp marital status/
7. exp cohabitation/
8. exp spouses/
9. exp couples/
10. living arrangements/
11. 5 or 6 or 7 or 8 or 9 or 10
12. 4 and 11
13. exp Physical Abuse/
14. exp Emotional Abuse/
15. exp Sexual Abuse/
16. 13 or 14 or 15
17. 11 and 16
18. 3 or 12 or 17
19. exp Family Medicine/
20. exp Primary Health Care/
21. exp General Practitioners/
22. exp Family Physicians/
23. (primary care or family medicine or family practice or general practice or gp).mp. [mp=title, abstract, heading word, table of contents, key concepts]
24. exp Emergency Services/
25. (emergency or emergencies).mp. [mp=title, abstract, heading word, table of contents, key concepts]
26. 19 or 20 or 21 or 22 or 23
27. 18 and 26
28. 24 or 25
29. 18 and 28
30. 27 or 29
31. limit 30 to yr="2002 -Current"
32. from 31 keep 1–148

### Searches for Screening

#### Domestic

Database: Ovid MEDLINE

1. exp domestic violence/
2. exp battered women/
3. 1 or 2
4. exp Mass Screening/
5. 3 and 4
6. screen$.mp.
7. exp questionnaires/
8. exp risk assessment/
9. exp diagnosis/
10. di.fs.
11. 9 or 10
12. 7 and 11
13. 3 and 6
14. 3 and 8
15. 3 and 12
16. 13 or 14 or 15
17. limit 16 to (english language and yr="2002 -Current")
18. from 17 keep 1–1686

Database: PsycINFO

1. exp Domestic Violence/
2. exp Screening/
3. exp Screening Tests/
4. 2 or 3
5. 1 and 4
6. screen$.mp.
7. 1 and 6
8. exp Measurement/
9. (diagnos$ or assess$ or discover$ or recogni$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
10. 8 and 9
11. 1 and 10
12. 5 or 7 or 11
13. limit 12 to yr="2002 -Current"
14. from 13 keep 1–327

#### Children

Database: Ovid MEDLINE

1. exp Child Abuse/
2. exp Domestic Violence/
3. limit 2 to "all child (0 to 18 years)"
4. 1 or 3
5. exp Schools/
6. crime/or exp crime victims/or exp homicide/or exp sex offenses/or exp violence/
7. 5 and 6
8. limit 7 to "all child (0 to 18 years)"
9. 4 or 8
10. exp Mass Screening/
11. 9 and 10
12. screen$.mp.
13. 9 and 12
14. exp questionnaires/
15. 9 and 14
16. exp risk assessment/
17. 9 and 16
18. 11 or 13
19. exp diagnosis/
20. di.fs.
21. 19 or 20
22. 15 and 21
23. 17 or 18 or 22
24. limit 23 to yr="2002 -Current"
25. limit 24 to english language
26. from 25 keep 1–1094

Database: PsycINFO

1. exp Child Abuse/
2. exp Child Neglect/
3. 1 or 2
4. exp Domestic Violence/
5. limit 4 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
6. exp Physical Abuse/
7. exp Emotional Abuse/
8. exp Sexual Abuse/
9. 6 or 7 or 8
10. limit 9 to (100 childhood <birth to age 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
11. 3 or 5 or 10
12. exp Screening/
13. exp Screening Tests/
14. 12 or 13
15. 11 and 14
16. screen$.mp.
17. 11 and 16
18. 15 or 17
19. exp Measurement/
20. (diagnos$ or assess$ or discover$ or recogni$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
21. 19 and 20
22. 11 and 21
23. 18 or 22
24. limit 23 to yr="2002 -Current"
25. limit 24 to english language
26. from 25 keep 1–512

#### Elder

Database: Ovid MEDLINE

1. exp elder abuse/
2. exp Domestic Violence/
3. limit 2 to "all aged (65 and over)"
4. 1 or 3
5. exp residential facilities/
6. crime/or exp crime victims/or exp homicide/or exp sex offenses/or exp violence/
7. 5 and 6
8. limit 7 to "all aged (65 and over)"
9. 4 or 8
10. exp Mass Screening/
11. 9 and 10
12. screen$.mp.
13. 9 and 12
14. exp questionnaires/
15. 9 and 14
16. exp risk assessment/
17. 9 and 16
18. 11 or 13 or 15 or 17
19. limit 18 to (english language and yr="2002 -Current")
20. from 19 keep 1–412

Database: PsycINFO

1. exp elder abuse/
2. exp Domestic Violence/
3. limit 2 to "380 aged <age 65 yrs and older>"
4. exp Physical Abuse/
5. exp patient abuse/
6. exp Emotional Abuse/
7. exp Sexual Abuse/
8. 4 or 5 or 6 or 7
9. limit 8 to "380 aged <age 65 yrs and older>"
10. 1 or 3 or 9
11. exp Screening/
12. exp Screening Tests/
13. 11 or 12
14. 10 and 13
15. screen$.mp.
16. 10 and 15
17. 14 or 16
18. exp Measurement/
19. (diagnos$ or assess$ or discover$ or recogni$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
20. 18 and 19
21. 10 and 20
22. 17 or 21
23. limit 22 to yr="2002 -Current"
24. limit 23 to english language
25. from 24 keep 1–95

#### Spouse

Database: Ovid MEDLINE

1. Spouse Abuse/
2. ((spous$ or wife or husband or boyfriend$ or girlfriend$ or married or marriage$ or intimate partner$ or common law or cohabitat$) adj5 (abus$ or violen$ or attack$ or assault$ or batter$)).mp.
3. exp Mass Screening/
4. 2 and 3
5. screen$.mp.
6. exp questionnaires/
7. exp risk assessment/
8. exp diagnosis/
9. di.fs.
10. 2 and 5
11. 2 and 6
12. 2 and 7
13. 8 or 9
14. 11 and 13
15. 4 or 10 or 12 or 14
16. limit 15 to (english language and yr="2002 -Current")
17. from 16 keep 1–664

Database: PsycINFO

1. exp partner abuse/
2. exp battered women/
3. 1 or 2
4. exp Domestic Violence/
5. exp marriage/
6. exp marital status/
7. exp cohabitation/
8. exp spouses/
9. exp couples/
10. living arrangements/
11. 5 or 6 or 7 or 8 or 9 or 10
12. 4 and 11
13. exp Physical Abuse/
14. exp Emotional Abuse/
15. exp Sexual Abuse/
16. 13 or 14 or 15
17. 11 and 16
18. 3 or 12 or 17
19. exp Screening/
20. exp Screening Tests/
21. 19 or 20
22. screen$.mp.
23. exp Measurement/
24. (diagnos$ or assess$ or discover$ or recogni$).mp. [mp=title, abstract, heading word, table of contents, key concepts]
25. 23 and 24
26. 18 and 21
27. 18 and 22
28. 18 and 25
29. 26 or 27 or 28
30. limit 29 to yr="2002 -Current"
31. from 30 keep 1–366

## Appendix A2 Inclusion and Exclusion Criteria

| Inclusion Criteria | Exclusion Criteria
All Key Questions
Population | Asymptomatic children, newborns through age 18 years. | Symptomatic children undergoing diagnostic evaluations for conditions related to abuse or neglect (e.g., those presenting with a broken bone or other signs of physical abuse or neglect).
Languages | Full text published in English. | NonEnglish language.
Settings | Pediatrician, primary care/family medicine, or other settings where primary care services are offered, such as emergency departments; services that could result from an assessment by a clinician; research conducted in the United States or in populations similar to U.S. populations with services and interventions applicable to U.S. practice. | Nonclinically-based settings or nonapplicable settings; populations or services/interventions not applicable to U.S. practice.
Key Question 1. Interventions
Interventions | Services that could result from an assessment by a clinician; services may be implemented by nonclinicians (e.g., nurse home visitation). | Public awareness campaigns without specific interventions linked to clinical settings.
Outcomes | Decreasing levels of abuse or neglect; Child Protective Services reports; removal of the child from the home; medical outcomes including emergency department visits, hospitalizations, well-child visits, and immunizations; and self-reported “severe” or “very severe” physical abuse or spanking/slapping of an infant in the first year of life.
Study Designs | Randomized, controlled trials. | Nonrandomized, controlled trials.
Key Question 2. Harms of Interventions
Interventions | Services that could result from an assessment by a clinician; services may be implemented by nonclinicians (e.g., nurse home visitation). | Public awareness campaigns without specific interventions linked to clinical settings.
Outcomes | Any harms that result as an effect of interventions. | All considered.
Study Designs | Any. | All considered.

## Appendix A3 Literature Flow Diagram

^a^ Cochrane databases include the Cochrane Central Register of Controlled Trials and the Cochrane Database of Systematic Reviews.

^b^ Identified from reference lists, prior report, or suggested by experts.

^c^ Includes search results for child, adult, and elderly populations. Studies of adults and elderly populations are included in a separate report.

## Appendix A4 List of Excluded Studies

### Wrong Population (adults, elderly, symptomatic, perpetrator-focused)

Telephone intervention works to stop intimate partner violence. J Psychosoc Nurs Ment Health Serv. 2004;42(6):12-3. [pmid: 15237787].
Acierno R, Lawyer SR, Rheingold A, Kilpatrick DG, Resnick HS, Saunders BE. Current psychopathology in previously assaulted older adults. J Interpers Violence. 2007;22(2):250-8. [pmid: 17202579].
Acierno R, Resnick H, Kilpatrick D, Stark-Riemer W. Assessing elder victimization—demonstration of a methodology. Soc Psychiatry Psychiatr Epidemiol. 2003;38(11):644-53. [pmid: 14614553].
Ahmad F. Computer-assisted screening for intimate partner violence in family practice: University of Toronto, Canada [Dissertation]. Diss Abstr Int B Sci Eng. 2007;68(5B):NR27718.
Ahmad F, Hogg-Johnson S, Stewart DE, Skinner HA, Glazier RH, Levinson W. Computer-assisted screening for intimate partner violence and control: a randomized trial. Ann Intern Med. 2009;151(2):93-102. [pmid: 19487706].
Ameh N, Shittu SO, Abdul MA. Risk scoring for domestic violence in pregnancy. Niger J Clin Pract. 2008;11(1):18-21. [pmid: 18689133].
Anderson BA, Marshak HH, Hebbeler DL. Identifying intimate partner violence at entry to prenatal care: clustering routine clinical information. J Midwifery Womens Health. 2002;47(5):353-9. [pmid: 12361347].
Anderst J, Hill TD, Siegel RM. A comparison of domestic violence screening methods in a pediatric office. Clin Pediatr. 2004;43(1):103-5. [pmid: 14968901].
Aneja S, Gottlieb AS, Feller E. Physician intervention for intimate partner violence. Med Health R I. 2009;92(9):307-9. [pmid: 19842528].
Annan S. Sexual violence in rural areas: a review of the literature. Fam Community Health. 2006;29(3):164-8. [pmid: 16775466].
Anthony EK, Lehning AJ, Austin MJ, Peck MD. Assessing elder mistreatment: instrument development and implications for adult protective services. J Gerontol Soc Work. 2009;52(8):815-36. [pmid: 19830609].
Ast E. The Development and Validation of the Ast Physical Discipline Inventory, 2006 (ADPI). Fresno, CA. Alliant International University. 2007.
Auchter B. Interventing with domestic violence offenders: introduction. Violence Against Women. 2008;14(2):131-5. [pmid: 18335639].
Ayranci U, Yenilmez C, Balci Y, Kaptanoglu C. Identification of violence in Turkish health care settings. J Interpers Violence. 2006;21(2):276-96. [pmid: 16368766].
Ayub M, Irfan M, Nasr T, Lutufullah M, Kingdon D, Naeem F. Psychiatric morbidity and domestic violence: a survey of married women in Lahore. Soc Psychiatry Psychiatr Epidemiol. 2009;44(11):953-60. [pmid: 19277437].
Babcock JC, Green CE, Robie C. Does batterers’ treatment work? A meta-analytic review of domestic violence treatment. Clin Psychol Rev. 2004;23(8):1023-53. [pmid: 14729422].
Backos AK. Indicators of PTSD in the Draw-a-Person and Kinetic Family Drawing With Mothers and Children Exposed to Domestic Violence. San Francisco. Alliant International University. 2010.
Baird S, Jenkins SR. Vicarious traumatization, secondary traumatic stress, and burnout in sexual assault and domestic violence agency staff. Violence Vict. 2003;18(1):71-86. [pmid: 12733620].
Bair-Merritt MH, Feudtner C, Mollen CJ, Winters S, Blackstone M, Fein JA. Screening for intimate partner violence using an audiotape questionnaire: a randomized clinical trial in a pediatric emergency department. Arch Pediatr Adolesc Med. 2006;160(3):311-6. [pmid: 16520452].
Bair-Merritt MH, Jennings JM, Chen R, Burrell L, McFarlane E, Fuddy L, et al. Reducing maternal intimate partner violence after the birth of a child: a randomized controlled trial of the Hawaii healthy start home visitation program. Arch Pediatr Adolesc Med. 2010;164(1):16-23. [pmid: 20048237].
Baldry AC, Winkel FW. Intimate Partner Violence Prevention and Intervention: The Risk Assessment and Management Approach. Hauppauge, NY. Nova Science Publishers. 2008.
Barlow J, Johnston I, Kendrick D, Polnay L, Stewart-Brown S. Individual and group-based parenting programmes for the treatment of physical child abuse and neglect. Cochrane Database Syst Rev. 2006;3:CD005463. [pmid: 16856097].
Barth RP, Hacking S, Ash JR. Preventing child abuse: an experimental evaluation of the child parent enrichment project. J Prim Prev. 1988;8(41):201-17.
Basile KC, Hertz MF, Back SE. Intimate Partner Violence and Sexual Violence Victimization Assessment Instruments for Use in Healthcare Settings. Atlanta. Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. 2007.
Begun AL, Brondino MJ, Bolt D, Weinstein B, Strodthoff T, Shelley G. The revised Safe at Home instrument for assessing readiness to change intimate partner violence. Murphy CM, Maiuro RD, editors. Motivational Interviewing and Stages of Change in Intimate Partner Violence. New York. Springer. 2009:199-223.
Begun AL, Murphy C, Bolt D, Weinstein B, Strodthoff T, Short L, et al. Characteristics of the Safe at Home instrument for assessing readiness to change intimate partner violence. Res Soc Work Pract. 2003;13(1):80-107.
Bennett C, Macdonald G, Dennis JA, Coren E, Patterson J, Astin M, et al. Home-based support for disadvantaged adult mothers. Cochrane Database Syst Rev. 2007;3:CD003759. [pmid: 17636732].
Bennett L, Riger S, Schewe P, Howard A, Wasco S. Effectiveness of hotline, advocacy, counseling, and shelter services for victims of domestic violence: a statewide evaluation. J Interpers Violence. 2004;19(7):815-29. [pmid: 15186538].
Berk RA, Campbell A, Klap R, Western B. The deterrent effect of arrest in incidents of domestic violence: a Bayesian analysis of four field experiments. Am Sociol Rev. 1992;57(5):698-708.
Berk RA, He Y, Sorenson SB. Developing a practical forecasting screener for domestic violence incidents. Eval Rev. 2005;29(4):358-83. [pmid: 15985524].
Blackmore ER, Carroll J, Reid A, Biringer A, Glazier RH, Midmer D, et al. The use of the Antenatal Psychosocial Health Assessment (ALPHA) tool in the detection of psychosocial risk factors for postpartum depression: a randomized controlled trial. J Obstet Gynaecol Can. 2006;28(10):873-8. [pmid: 17140502].
Bomba PA. Use of a single page elder abuse assessment and management tool: a practical clinician’s approach to identifying elder mistreatment. J Gerontol Soc Work. 2006;46(3–4):103-22. [pmid: 16803779].
Bonds DE, Ellis SD, Weeks E, Lichstein P, Burke K, Posey C. Patient attitudes toward screening. N C Med J. 2007;68(1):23-9. [pmid: 17500428].
Bonomi AE, Thompson RS, Anderson M, Rivara FP, Holt VL, Carrell D, et al. Ascertainment of intimate partner violence using two abuse measurement frameworks. Inj Prev. 2006;12(2):121-4. [pmid: 16595428].
Bowen E, Gilchrist E, Beech AR. Change in treatment has no relationship with subsequent re-offending in U.K. domestic violence sample: a preliminary study. Int J Offender Ther Comp Criminol. 2008;52(5):598-614. [pmid: 18505816].
Bradford K. Screening couples for intimate partner violence. J Fam Psychother. 2010;21(1):76-82.
Brown K, Streubert GE, Burgess AW. Effectively detect and manage elder abuse. Nurse Pract. 2004;29(8):22-7. [pmid: 15553915].
Brownell P, Berman J, Salamone A. Mental health and criminal justice issues among perpetrators of elder abuse. J Elder Abuse Negl. 1999;11:81-94. [pmid: 21877986].
Bullock L, Bloom T, Davis J, Kilburn E, Curry MA. Abuse disclosure in privately and Medicaid-funded pregnant women. J Midwifery Womens Health. 2006;51(5):361-9. [pmid: 16945784].
Bullock LF, Browning C, Geden E. Telephone social support for low-income pregnant women. J Obstet Gynecol Neonatal Nurs. 2002;31(6):658-64. [pmid: 12465861].
Burgess AW, Roberts AR, Valentine PV. The stress-crisis continuum: its application to domestic violence. Roberts AR, editor. Battered Women and Their Families: Intervention Strategies and Treatment Programs. 3rd ed. New York. Springer. 2007:133-60.
Buri HM, Daly JM, Jogerst GJ. Elder abuse telephone screen reliability and validity. J Elder Abuse Negl. 2009;21(1):58-73. [pmid: 19197621].
Calderon SH, Gilbert P, Jackson R, Kohn MA, Gerbert B. Cueing prenatal providers effects on discussions of intimate partner violence. Am J Prev Med. 2008;34(2):134-7. [pmid: 18201643].
Campbell J, Glass N. Safety planning, danger, and lethality assessment. Mitchell C, Anglin D, editors. Intimate Partner Violence: A Health-Based Perspective. New York. Oxford University Press. 2009:319-34.
Campbell JC. Health consequences of intimate partner violence. Lancet. 2002;359(9314):1331-6. [pmid: 11965295].
Campbell JC, Coben JH, McLoughlin E, Dearwater S, Nah G, Glass N, et al. An evaluation of a system-change training model to improve emergency department response to battered women. Acad Emerg Med. 2001;8(2):131-8. [pmid: 11157288].
Campbell JC, Webster DW, Glass N. The danger assessment: validation of a lethality risk assessment instrument for intimate partner femicide. J Interpers Violence. 2009;24(4):653-74. [pmid: 18667689].
Carbone-Lopez K, Kruttschnitt C, Macmillan R. Patterns of intimate partner violence and their associations with physical health, psychological distress, and substance use. Public Health Rep. 2006;121(4):382-92. [pmid: 16827439].
Carney DM, McKibbin L. Screening for domestic violence. Nurs Manag. 2003;34(9):35-6. [pmid: 14501530].
Carter-Visscher RM, Naugle AE, Bell KM, Suvak MK. Ethics of asking trauma-related questions and exposing participants to arousal-inducing stimuli. J Trauma Dissociation. 2007;8(3):27-55. [pmid: 18032343].
Cattaneo LB, Bell ME, Goodman LA, Dutton MA. Intimate partner violence victims’ accuracy in assessing their risk of re-abuse. J Fam Violence. 2007;22(6):429-40.
Chaffin M, Funderburk B, Bard D, Valle LA, Gurwitch R. A combined motivation and parent-child interaction therapy package reduces child welfare recidivism in a randomized dismantling field trial. J Consult Clin Psychol. 2011;79(1):84-95. [pmid: 21171738].
Chaffin M, Silovsky JF, Funderburk B, Valle LA, Brestan EV, Balachova T, et al. Parent-child interaction therapy with physically abusive parents: efficacy for reducing future abuse reports. J Consult Clin Psychol. 2004;72(3):500-10. [pmid: 15279533].
Chan E, Cavacuiti C. Gay Abuse Screening Protocol (GASP): screening for abuse in gay male relationships. J Homosex. 2008;54(4):423-38. [pmid: 18826169].
Chang JC, Decker M, Moracco KE, Martin SL, Petersen R, Frasier PY. What happens when health care providers ask about intimate partner violence? A description of consequences from the perspectives of female survivors. J Am Med Wom Assoc. 2003;58(2):76-81. [pmid: 12744419].
Chapin MG, Mackie CF. Research evidence to update practice guidelines for domestic violence screening in military settings. Mil Med. 2007;172(7):ii-iv. [pmid: 17691676].
Chen PH, Rovi S, Vega M, Jacobs A, Johnson MS. Screening for domestic violence in a predominantly Hispanic clinical setting. Fam Pract. 2005;22(6):617-23. [pmid: 16055473].
Chen PH, Rovi S, Washington J, Jacobs A, Vega M, Pan KY, et al. Randomized comparison of 3 methods to screen for domestic violence in family practice. Ann Fam Med. 2007;5(5):430-5. [pmid: 17893385].
Chen W, Balaban R, Stanger V, Haruvi Ra, Zur S, Augarten A. Suspected child abuse and neglect: assessment in a hospital setting. Isr Med Assoc J. 2002;4(8):617-23. [pmid: 12183867].
Cleary BS, Keniston A, Havranek EP, Albert RK. Intimate partner violence in women hospitalized on an internal medicine service: prevalence and relationship to responses to the review of systems. J Hosp Med. 2008;3(4):299-307. [pmid: 18698603].
Cohen M, Halevi-Levin S, Gagin R, Friedman G. Development of a screening tool for identifying elderly people at risk of abuse by their caregivers. J Aging Health. 2006;18(5):660-85. [pmid: 16980634].
Cohen M, Levin SH, Gagin R, Friedman G. Elder abuse: disparities between older people’s disclosure of abuse, evident signs of abuse, and high risk of abuse. J Am Geriatr Soc. 2007;55(8):1224-30. [pmid: 17661961].
Coker AL, Flerx VC, Smith PH, Whitaker DJ, Fadden MK, Williams M. Partner violence screening in rural health care clinics. Am J Public Health. 2007;97(7):1319-25. [pmid: 17538065].
Coker AL, Flerx VC, Smith PH, Whitaker DJ, Fadden MK, Williams M. Intimate partner violence incidence and continuation in a primary care screening program. Am J Epidemiol. 2007;165(7):821-7. [pmid: 17255117].
Colarossi LG, Breitbart V, Betancourt GS. Screening for intimate partner violence in reproductive health centers: an evaluation study. Womens Health. 2010;50(4):313-26. [pmid: 20711946].
Cole TB. Is domestic violence screening helpful?. JAMA. 2000;284(5):551-3. [pmid: 10918685].
Colombini M, Mayhew S, Watts C. Health-sector responses to intimate partner violence in low- and middle-income settings: a review of current models, challenges and opportunities. Bull World Health Organ. 2008;86(8):635-42. [pmid: 18797623].
Connelly CD, Newton RR, Aarons GA. A psychometric examination of English and Spanish versions of the Revised Conflict Tactics Scales. J Interpers Violence. 2005;20(12):1560-79. [pmid: 16246917].
Conners NA, Whiteside-Mansell L, Deere D, Ledet T, Edwards MC. Measuring the potential for child maltreatment: the reliability and validity of the Adult Adolescent Parenting Inventory-2. Child Abuse Negl. 2006;30(1):39-53. [pmid: 16406026].
Conrad KJ, Iris M, Ridings JW, Langley K, Wilber KH. Self-report measure of financial exploitation of older adults. Gerontologist. 2010;50(6):758-73. [pmid: 20667945].
Constantino R, Kim Y, Crane PA. Effects of a social support intervention on health outcomes in residents of a domestic violence shelter: a pilot study. Issues Ment Health Nurs. 2005;26(6):575-90. [pmid: 16020071].
Cooper C, Katona C, Finne-Soveri H, Topinkova E, Carpenter GI, Livingston G. Indicators of elder abuse: a crossnational comparison of psychiatric morbidity and other determinants in the Ad-HOC study. Am J Geriatr Psychiatry. 2006;14(6):489-97. [pmid: 16731717].
Cooper C, Manela M, Katona C, Livingston G. Screening for elder abuse in dementia in the LASER-AD study: prevalence, correlates and validation of instruments. Int J Geriatr Psychiatry. 2008;23(3):283-8. [pmid: 17621366].
Cooper C, Maxmin K, Selwood A, Blanchard M, Livingston G. The sensitivity and specificity of the modified Conflict Tactics Scale for detecting clinically significant elder abuse. Int Psychogeriatr. 2009;21(4):774-8. [pmid: 19493378].
Coulthard P, Yong LS, Adamson L, Warburton A, Worthington HV, Esposito M, et al. Domestic violence screening and intervention programmes for adults with dental or facial injury. Cochrane Database Syst Rev. 2010;12:CD004486. [pmid: 21154356].
Coulthard P, Yong S, Adamson L, Warburton A, Worthington HV, Esposito M. Domestic violence screening and intervention programmes for adults with dental or facial injury. Cochrane Database Syst Rev. 2004;2:CD004486. [pmid: 15106255].
Curry MA, Durham L, Bullock L, Bloom T, Davis J. Nurse case management for pregnant women experiencing or at risk for abuse. J Obstet Gynecol Neonatal Nurs. 2006;35(2):181-92. [pmid: 16620243].
Curry MA, Powers LE, Oschwald M. Development of an abuse screening tool for women with disabilities. J Aggress Maltreat Trauma. 2003;8(4):123-41.
Curry MA, Renker P, Hughes RB, Robinson-Whelen S, Oschwald M, Swank PR, et al. Development of measures of abuse among women with disabilities and the characteristics of their perpetrators. Violence Against Women. 2009;15(9):1001-25. [pmid: 19622789].
Daly JM, Jogerst GJ. Readability and content of elder abuse instruments. J Elder Abuse Negl. 2005;17(4):31-52. [pmid: 17050491].
Datner EM, O’Malley M, Schears RM, Shofer FS, Baren J, Hollander JE. Universal screening for interpersonal violence: inability to prove universal screening improves provision of services. Eur J Emerg Med. 2004;11(1):35-8. [pmid: 15167191].
Datner EM, Wiebe DJ, Brensinger CM, Nelson DB. Identifying pregnant women experiencing domestic violence in an urban emergency department. J Interpers Violence. 2007;22(1):124-35. [pmid: 17151383].
Daugherty JD, Houry DE. Intimate partner violence screening in the emergency department. J Postgrad Med. 2008;54(4):301-5. [pmid: 18953150].
Davis RC, Taylor BG. A proactive response to family violence: the results of a randomized experiment. Criminology. 1997;35(2):307-33.
DePanfilis D, Zuravin SJ. The effect of services on the recurrence of child maltreatment. Child Abuse Negl. 2002;26(2):187-205. [pmid: 11933989].
Dichter ME, Rhodes KV. Reports of police calls for service as a risk indicator for intimate partner violence. Acad Emerg Med. 2009;16(1):83-6. [pmid: 19007347].
Dienemann J, Glass N, Hanson G, Lunsford K. The Domestic Violence Survivor Assessment (DVSA): a tool for individual counseling with women experiencing intimate partner violence. Issues Ment Health Nurs. 2007;28(8):913-25. [pmid: 17729174].
Dietz TL, Jasinski JL. The effect of item order on partner violence reporting: an examination of four versions of the revised Conflict Tactics Scales. Soc Sci Res. 2007;36(1):353-73.
Dong X, Simon MA. Is greater social support a protective factor against elder mistreatment?. Gerontology. 2008;54(6):381-8. [pmid: 18600021].
Dong X, Simon MA. Is impairment in physical function associated with increased risk of elder mistreatment? Findings from a community-dwelling Chinese population. Public Health Rep. 2010;125(5):743-53. [pmid: 20873291].
Dubowitz H, Prescott L, Feigelman S, Lane W, Kim J. Screening for intimate partner violence in a pediatric primary care clinic. Pediatrics. 2008;121(1):e85-91. [pmid: 18166548].
Easton CJ, Mandel DL, Hunkele KA, Nich C, Rounsaville BJ, Carroll KM. A cognitive behavioral therapy for alcohol-dependent domestic violence offenders: an integrated substance abuse-domestic violence treatment approach (SADV). Am J Addict. 2007;16(1):24-31. [pmid: 17364418].
Eckenrode J, Ganzel B, Henderson CR, Smith E, Olds DL, Powers J, et al. Preventing child abuse and neglect with a program of nurse home visitation: the limiting effects of domestic violence. JAMA. 2000;284(11):1385-91. [pmid: 10989400].
Edelen MO, McCaffrey DF, Marshall GN, Jaycox LH. Measurement of teen dating violence attitudes: an item response theory evaluation of differential item functioning according to gender. J Interpers Violence. 2009;24(8):1243-63. [pmid: 18701746].
El-Mohandes A, Kiely M, El Khorazaty N, Gantz M, Blake S, Subramanian S. Reduction of intimate partner violence in pregnancy: the effect of an integrated intervention in an African-American low income population. Pediatric Academic Societies Annual Meeting. 2005.
El-Mohandes AA, Kiely M, Gantz MG, El-Khorazaty MN. Very preterm birth is reduced in women receiving an integrated behavioral intervention: a randomized controlled trial. Matern Child Health J. 2011;15(1):19-28. [pmid: 20082130].
El-Mohandes AA, Kiely M, Joseph JG, Subramanian S, Johnson AA, Blake SM, et al. An integrated intervention in pregnant African-Americans reduces postpartum risk: a randomized controlled trial. Obstet Gynecol. 2008;112(3):611-20. [pmid: 18757660].
El-Mohandes AA. A psycho-behavioral intervention on African American pregnant women with a history of intimate partner violence (IPV) improves birth weight distribution of their newborns. Pediatric Academic Societies Annual Meeting. 2006.
Elzevier HW, Voorham-van der Zalm PJ, Pelger RC. How reliable is a self-administered questionnaire in detecting sexual abuse: a retrospective study in patients with pelvic-floor complaints and a review of literature. J Sex Med. 2007;4(4 Pt 1):956-63. [pmid: 17627742].
Enriquez M, Cheng AL, Kelly PJ, Witt J, Coker AD, Kashubeck-West S. Development and feasibility of an HIV and IPV prevention intervention among low-income mothers receiving services in a Missouri day care center. Violence Against Women. 2010;16(5):560-78. [pmid: 20388931].
Ergonen AT, Ozdemir MH, Can IO, Sonmez E, Salacin S, Berberoglu E, et al. Domestic violence on pregnant women in Turkey. J Forensic Leg Med. 2009;16(3):125-9. [pmid: 19239961].
Erlingsson CL, Carlson SL, Saveman BI. Elder abuse risk indicators and screening questions: results from a literature search and a panel of experts from developed and developing countries. J Elder Abuse Negl. 2003;15(3–4):185-203.
Ernst AA, Weiss SJ, Cham E, Hall L, Nick TG. Detecting ongoing intimate partner violence in the emergency department using a simple 4-question screen: the OVAT. Violence Vict. 2004;19(3):375-84. [pmid: 15631287].
Escriba-Aguir V, Ruiz-Perez I, Saurel-Cubizolles MJ. Screening for domestic violence during pregnancy. J Psychosom Obstet Gynaecol. 2007;28(3):133-4. [pmid: 17577754].
Falk DR, Shepard MF, Elliott BA. Evaluation of a domestic violence assessment protocol used by employee assistance counselors. Employee Assistance Q. 2002;17(3):1-15.
Fanslow JL, Norton RN, Robinson EM, Spinola CG. Outcome evaluation of an emergency department protocol of care on partner abuse. Aust N Z J Public Health. 1998;22(5):598-603. [pmid: 9744216].
Feder G, Ramsay J, Dunne D, Rose M, Arsene C, Norman R, et al. How far does screening women for domestic (partner) violence in different health-care settings meet criteria for a screening programme? Systematic reviews of nine UK National Screening Committee criteria. Health Technol Assess. 2009;13(16):iii-iv. xi. xiii. 1. 113. 137. 347. [pmid: 19272272].
Feindler EL, Rathus JH, Silver LB. Assessment of Family Violence: A Handbook for Researchers and Practitioners. Washington, DC. American Psychological Association. 2003.
Feindler EL, Rathus JH, Silver LB. Interview methods. Assessment of Family Violence: A Handbook for Researchers and Practitioners. Washington, DC. American Psychological Association. 2003:63-124.
Feindler EL, Rathus JH, Silver LB. Self-report inventories for the assessment of children. Assessment of Family Violence: A Handbook for Researchers and Practitioners. Washington, DC. American Psychological Association. 2003:125-227.
Feindler EL, Rathus JH, Silver LB. Self-report inventories. Assessment of Family Violence: A Handbook for Researchers and Practitioners. Washington, DC. American Psychological Association. 2003:387-431.
Fergusson DM, Grant H, Horwood LJ, Ridder EM. Randomized trial of the Early Start program of home visitation: parent and family outcomes. Pediatrics. 2006;117(3):781-6. [pmid: 16510658].
Fernandez-Fuertes AA, Fuertes A, Pulido RF. Assessment of violence in adolescent couples: validation of the Conflict in Adolescent Dating Relationships Inventory (CADRI)—Spanish version. Int J Clin Health Psychol. 2006;6(2):339-58.
Finn J, Atkinson T. Promoting the safe and strategic use of technology for victims of intimate partner violence: evaluation of the technology safety project. Violence Against Women. 2009;15(11):1402-14. [pmid: 19809100].
Fleegler EW, Lieu TA, Wise PH, Muret-Wagstaff S. Families’ health-related social problems and missed referral opportunities. Pediatrics. 2007;119(6):e1332-41. [pmid: 17545363].
Fogarty CT, Brown JB. Screening for abuse in Spanish-speaking women. J Am Board Fam Pract. 2002;15(2):101-11. [pmid: 12002193].
Foran HM, O’Leary D. Alcohol and intimate partner violence: a meta-analytic review. Clin Psychol Rev. 2008;28:1222-34. [pmid: 18550239].
Ford-Gilboe M, Wuest J, Varcoe C, Merritt-Gray M. Developing an evidence-based health advocacy intervention for women who have left an abusive partner. Can J Nurs Res. 2006;38(1):147-67. [pmid: 16671285].
Fraser JA, Armstrong KL, Morris JP, Dadds MR. Home visiting intervention for vulnerable families with newborns: follow-up results of a randomized controlled trial. Child Abuse Negl. 2000;24(11):1399-429. [pmid: 11128173].
Fulfer JL, Tyler JJ, Choi NJ, Young JA, Verhulst SJ, Kovach R, et al. Using indirect questions to detect intimate partner violence: the SAFE-T questionnaire. J Interpers Violence. 2007;22(2):238-49. [pmid: 17202578].
Fulmer T. Screening for mistreatment of older adults. Am J Nurs. 2008;108(12):52-9. [pmid: 19033914].
Fulmer T, Guadagno L, Bitondo Dyer C, Connolly MT. Progress in elder abuse screening and assessment instruments. J Am Geriatr Soc. 2004;52(2):297-304. [pmid: 14728644].
Fulmer T, Paveza G, Weerd CV, Guadagno L, Fairchild S, Norman R, et al. Neglect assessment in urban emergency departments and confirmation by an expert clinical team. J Gerontol A Biol Sci Med Sci. 2005;60(8):102-1006. [pmid: 16127103].
Furniss K, McCaffrey M, Parnell V, Rovi S. Nurses and barriers to screening for intimate partner violence. Am J Matern Child Nurs. 2007;32(4):238-43. [pmid: 17667289].
Gagnon AJ, Tuck J, Barkun L. A systematic review of questionnaires measuring the health of resettling refugee women. Health Care Women Int. 2004;25(2):111-49. [pmid: 14766429].
Gielen AC, O’Campo PJ, Campbell JC, Schollenberger J, Woods AB, Jones AS, et al. Women’s opinions about domestic violence screening and mandatory reporting. Am J Prev Med. 2000;19(4):279-85. [pmid: 11064232].
Gillum TL. The benefits of a culturally specific intimate partner violence intervention for African American survivors. Violence Against Women. 2008;14(8):917-43. [pmid: 18667406].
Gillum TL. Improving services to African American survivors of IPV: from the voices of recipients of culturally specific services. Violence Against Women. 2009;15(1):57-80. [pmid: 19015390].
Gillum TL, Sun CJ, Woods AB. Can a health clinic-based intervention increase safety in abused women? Results from a pilot study. J Womens Health (Larchmt). 2009;18(8):1259-64. [pmid: 19627223].
Glowa PT, Frasier PY, Newton WP. Increasing physician comfort level in screening and counseling patients for intimate partner violence: hands-on practice. Patient Educ Couns. 2002;46(3):213-20. [pmid: 11932119].
Glowa PT, Frazier PY, Wang L, Eaker K, Osterling WL. What happens after we identify intimate partner violence? The family physician’s perspective. Fam Med. 2003;35(10):730-6. [pmid: 14603406].
Goetz AT, Shackelford TK, Schipper LD, Stewart-Williams S. Adding insult to injury: development and initial validation of the Partner-Directed Insults Scale. Violence Vict. 2006;21(6):691-706. [pmid: 17220014].
Goff HW, Shelton A, Byrd TL, Parcel GS. Preparedness of health care practitioners to screen women for domestic violence in a border community. Health Care Women Int. 2003;24(2):135-48. [pmid: 12746023].
Goldbeck L, Laib-Koehnemund A, Fegert JM. A randomized controlled trial of consensus-based child abuse case management. Child Abuse Negl. 2007;31(9):919-33. [pmid: 17870161].
Gomez-Beloz A, Williams MA, Sanchez SE, Lam N. Intimate partner violence and risk for depression among postpartum women in Lima, Peru. Violence Vict. 2009;24(3):380-98. [pmid: 19634363].
Goodman L, Dutton MA, Vankos N, Weinfurt K. Women’s resources and use of strategies as risk and protective factors for reabuse over time. Violence Against Women. 2005;11(3):311-36. [pmid: 16043552].
Goodyear-Smith F. National screening policies in general practice: a case study of routine screening for partner abuse. Appl Health Econ Health Policy. 2002;1(4):197-209. [pmid: 14619249].
Grafton D, Wright BL, Gutmanis I, Ralyea S. Successful implementation of universal woman abuse inquiry. Public Health Nurs. 2006;23(6):535-40. [pmid: 17096779].
Graham-Bermann SA, Lynch S, Banyard V, DeVoe ER, Halabu H. Community-based intervention for children exposed to intimate partner violence: an efficacy trial. J Consult Clin Psychol. 2007;75(2):199-209. [pmid: 17469878].
Grant TM, Ernst CC, Streissguth AP. An intervention with high-risk mothers who abuse alcohol and drugs: the Seattle advocacy model. Am J Public Health. 1996;86(12):1816-7. [pmid: 9003147].
Green CE Jr. Intimate Partner Violence and Health Care Utilization: A Randomized Controlled Trial. Houston. University of Houston. 2005.
Grietens H, Geeraert L, Hellinckx W. A scale for home visiting nurses to identify risks of physical abuse and neglect among mothers with newborn infants. Child Abuse Negl. 2004;28(3):321-37. [pmid: 15066349].
Grubaugh AL, Frueh B. Intimate partner violence victimization among adults with severe mental illness: results of a cross-sectional study. J Clin Psychiatry. 2006;67(9):1472-3. [pmid: 17017840].
Gupton S. Always believe. Ann Emerg Med. 2002;40(1):122-3. [pmid: 12085085].
Gutmanis I, Beynon C, Tutty L, Wathen CN, MacMillan HL. Factors influencing identification of and response to intimate partner violence: a survey of physicians and nurses. BMC Public Health. 2007;7:12. [pmid: 17250771].
Halpern LR. Orofacial injuries as markers for intimate partner violence. Oral Maxillofac Surg Clin North Am. 2010;22(2):239-46. [pmid: 20403555].
Halpern LR, Dodson TB. A predictive model to identify women with injuries related to intimate partner violence. J Am Dent Assoc. 2006;137(5):604-9. [pmid: 16739539].
Halpern LR, Parry BA, Hayward G, Peak D, Dodson TB. A comparison of 2 protocols to detect intimate partner violence. J Oral Maxillofac Surg. 2009;67(7):1453-9. [pmid: 19531417].
Halpern LR, Perciaccante VJ, Hayes C, Susarla S, Dodson TB. A protocol to diagnose intimate partner violence in the emergency department. J Trauma. 2006;60(5):1101-5. [pmid: 16688077].
Halpern LR, Susarla SM, Dodson TB. Injury location and screening questionnaires as markers for intimate partner violence. J Oral Maxillofac Surg. 2005;63(9):1255-61. [pmid: 16122587].
Hamby S, Sugarman DB, Boney-McCoy S. Does questionnaire format impact reported partner violence rates? An experimental study. Violence Vict. 2006;21(4):507-18. [pmid: 16897917].
Harris MH, Weber M. Providing crisis counselors on-site to victims of domestic violence in the emergency department: a report of a local pilot project. S D J Med. 2002;55(4):147-9. [pmid: 11977868].
Hawkins JW, Pearce CW, Skeith J, Dimitruk B, Roche R. Using technology to expedite screening and intervention for domestic abuse and neglect. Public Health Nurs. 2009;26(1):58-69. [pmid: 19154193].
Heckert D, Gondolf EW. Battered women’s perceptions of risk versus risk factors and instruments in predicting repeat reassault. J Interpers Violence. 2004;19(7):778-800. [pmid: 15186536].
Hegarty K. The health consequences of child sexual abuse and partner abuse for women attending general practice. Aust Fam Physician. 2003;32(9):760. [pmid: 14524222].
Hegarty K, Bush R, Sheehan M. The Composite Abuse Scale: further development and assessment of reliability and validity of a multidimensional partner abuse measure in clinical settings. Violence Vict. 2005;20(5):529-47. [pmid: 16248489].
Hegarty K, Gunn J, Chondros P, Taft A. Physical and social predictors of partner abuse in women attending general practice: a cross-sectional study. Br J Gen Pract. 2008;58(552):484-7. [pmid: 18611314].
Hegarty KL, Bush R. Prevalence and associations of partner abuse in women attending general practice: a cross-sectional survey. Aust N Z J Public Health. 2002;26(5):437-42. [pmid: 12413288].
Hegarty KL, Gunn JM, O’Doherty LJ, Taft A, Chondros P, Feder G, et al. Women’s evaluation of abuse and violence care in general practice: a cluster randomised controlled trial (WEAVE). BMC Public Health. 2010;10:2. [pmid: 20044929].
Heinzer MM, Krimm JR. Barriers to screening for domestic violence in an emergency department. Holist Nurs Pract. 2002;16(3):24-33. [pmid: 11913225].
Helfritch CA, Beer DW. Use of the FirstSTEp screening tool with children exposed to domestic violence and homelessness: a group case study. Phys Occup Ther Pediatr. 2007;27(2):63-76. [pmid: 17442655].
Helmus L, Bourgon G. Taking stock of 15 years of research on the Spousal Assault Risk Assessment Guide (SARA): a critical review. Int J Forensic Ment Health. 2011;10(1):64-75.
Heron SL, Thompson MP, Jackson E, Kaslow NJ. Do responses to an intimate partner violence screen predict scores on a comprehensive measure of intimate partner violence in low-income black women?. Ann Emerg Med. 2003;42(4):483-91. [pmid: 14520319].
Herzig K, Danley D, Jackson R, Petersen R, Chamberlain L, Gerbert B. Seizing the 9-month moment: addressing behavioral risks in prenatal patients. Patient Educ Couns. 2006;61(2):228-35. [pmid: 16256291].
Hewitt LN, Bhavsar P, Phelan HA. The secrets women keep: intimate partner violence screening in the female trauma patient. J Trauma. 2011;70(2):320-3. [pmid: 21307728].
Higgins LP, Hawkins JW. Screening for abuse during pregnancy: implementing a multisite program. Am J Matern Child Nurs. 2005;30(2):109-14. [pmid: 15775806].
Hiscock H, Bayer JK, Price A, Ukoumunne OC, Rogers S, Wake M. Universal parenting programme to prevent early childhood behavioural problems: cluster randomised trial. BMJ. 2008;336(7639):318-21. [pmid: 18244958].
Hokoda A, Ramos-Lira L, Celaya P, Vilhauer K, Angeles M, Ruiz S, et al. Reliability of translated measures assessing dating violence among Mexican adolescents. Violence Vict. 2006;21(1):117-27. [pmid: 16494137].
Holtrop TG, Fischer H, Gray SM, Barry K, Bryant T, Du W. Screening for domestic violence in a general pediatric clinic: be prepared!. Pediatrics. 2004;114(5):1253-7. [pmid: 15520104].
Houry D, Bay L, Maddox J, Kellermann A. Arrests for intimate partner violence in female detention patients. Am J Emerg Med. 2005;23(1):96-7. [pmid: 15672349].
Houry D, Feldhaus K, Peery B, Abbott J, Lowenstein SR, al-Bataa-de-Montero S, et al. A positive domestic violence screen predicts future domestic violence. J Interpers Violence. 2004;19(9):955-66. [pmid: 15296611].
Houry D, Kaslow NJ, Kemball RS, McNutt LA, Cerulli C, Straus H, et al. Does screening in the emergency department hurt or help victims of intimate partner violence?. Ann Emerg Med. 2008;51(4):433-42. [pmid: 18313800].
Houry D, Kemball RS, Click LA, Kaslow NJ. Development of a brief mental health screen for intimate partner violence victims in the emergency department. Acad Emerg Med. 2007;14(3):202-9. [pmid: 17242384].
Hsieh HF, Wang JJ, Yen M, Liu TT. Educational support group in changing caregivers’ psychological elder abuse behavior toward caring for institutionalized elders. Adv Health Sci Educ Theory Pract. 2009;14(3):377-86. [pmid: 18516696].
Humphreys J, Tsoh JY, Kohn MA, Gerbert B. Increasing discussions of intimate partner violence in prenatal care using Video Doctor plus provider cueing: a randomized, controlled trial. Womens Health Issues. 2011;21(2):136-44. [pmid: 21185737].
Hurley KF, Brown-Maher T, Campbell SG, Wallace T, Venugopal R, Baggs D. Emergency department patients’ opinions of screening for intimate partner violence among women. Emerg Med J. 2005;22(2):97-8. [pmid: 15662056].
Huth-Bocks AC, Levendosky AA, Bogat G. The effects of domestic violence during pregnancy on maternal and infant health. Violence Vict. 2002;17(2):169-85. [pmid: 12033553].
Irizarry-Irizarry A. Development and validation of a questionnaire about the attitude and exposure of aged-Puerto Ricans to abuse and neglect. P R Health Sci J. 2008;27(2):129-33. [pmid: 18616040].
Ishii T, Asukai N, Kimura Y, Nagasue T, Kurosaki M, Kishimoto J. Development of the Domestic Violence Screening Inventory (DVSI) and its reliability and validity. Seishin Igaku. 2003;45(8):817-23.
Jack SM, Jamieson E, Wathen CN, MacMillan HL. The feasibility of screening for intimate partner violence during postpartum home visits. Can J Nurs Res. 2008;40(2):150-70. [pmid: 18714904].
Janssen P, Dascal-Weichhendler H, McGregor M. Assessment for intimate partner violence: where do we stand?. J Am Board Fam Med. 2006;19(4):413-5. [pmid: 16809657].
Johnson JK, Haider F, Ellis K, Hay DM, Lindow SW. The prevalence of domestic violence in pregnant women. BJOG. 2003;110(3):272-5. [pmid: 12628266].
Johnson M, Stone S, Lou C, Ling J, Claassen J, Austin MJ. Assessing parent education programs for families involved with child welfare services: evidence and implications. J Evid Based Soc Work. 2008;5(1–2):191-236. [pmid: 19064449].
Johnson MA, Stone S, Lou C, Ling J, Claassen J, Austin MJ. Assessing Parent Education Programs for Families Involved With Child Welfare Services: Evidence and Implications. San Francisco. Bay Area Social Services Consortium, Zellerback Family Foundation. 2006.
Jonassen JA, Mazor KM. Identification of physician and patient attributes that influence the likelihood of screening for intimate partner violence. Acad Med. 2003;78(10 Suppl):S20-3. [pmid: 14557085].
Jones C, Bonner M. Screening for domestic violence in an antenatal clinic. Aust J Midwifery. 2002;15(1):14-20. [pmid: 12017039].
Jones S, Davidson WS 2nd, Bogat GA, Levendosky A, von Eye A. Validation of the subtle and overt psychological abuse scale: an examination of construct validity. Violence Vict. 2005;20(4):407-16. [pmid: 16250408].
Jory B. The Intimate Justice Scale: an instrument to screen for psychological abuse and physical violence in clinical practice. J Marital Fam Ther. 2004;30(1):29-44. [pmid: 14763207].
Joseph JG, El-Mohandes AA, Kiely M, El-Khorazaty MN, Gantz MG, Johnson AA, et al. Reducing psychosocial and behavioral pregnancy risk factors: results of a randomized clinical trial among high-risk pregnant African American women. Am J Public Health. 2009;99(6):1053-61. [pmid: 19372532].
Jouriles EN, McDonald R, Rosenfield D, Norwood WD, Spiller L, Stephens N, et al. Improving parenting in families referred for child maltreatment: a randomized controlled trial examining effects of Project Support. J Fam Psychol. 2010;24(3):328-38. [pmid: 20545406].
Kataoka Y, Yaju Y, Eto H, Horiuchi S. Self-administered questionnaire versus interview as a screening method for intimate partner violence in the prenatal setting in Japan: a randomised controlled trial. BMC Pregnancy Childbirth. 2010;10:84. [pmid: 21182802].
Katz KS, Blake SM, Milligan RA, Sharps PW, White DB, Rodan MF, et al. The design, implementation and acceptability of an integrated intervention to address multiple behavioral and psychosocial risk factors among pregnant African American women. BMC Pregnancy Childbirth. 2008;8(1):22. [pmid: 18578875].
Kaye DK, Mirembe FM, Bantebya G, Johansson A, Ekstrom AM. Domestic violence during pregnancy and risk of low birthweight and maternal complications: a prospective cohort study at Mulago Hospital, Uganda. Trop Med Int Health. 2006;11(10):1576-84. [pmid: 17002732].
Kaye LW, Kay D, Crittenden JA. Intervention with abused older males: conceptual and clinical perspectives. J Elder Abuse Negl. 2007;19(1–2):153-72. [pmid: 18077275].
Kearney MH, Haggerty LA, Munro BH, Hawkins JW. Birth outcomes and maternal morbidity in abused pregnant women with public versus private health insurance. J Nurs Scholarsh. 2003;35(4):345-9. [pmid: 14735677].
Kethineni S, Blimling L, Bozarth JM, Gaines C. Youth violence: an exploratory study of a treatment program in a central Illinois county. Int J Offender Ther Comp Criminol. 2004;48(6):697-720. [pmid: 15538027].
Kiely M, El-Mohandes AA, El-Khorazaty MN, Gantz MG. An integrated intervention to reduce intimate partner violence in pregnancy: a randomized controlled trial. Obstet Gynecol. 2010;115(2 Pt 1):273-83. [pmid: 20093899].
Kim J, Dubowitz H, Hudson-Martin E, Lane W. Comparison of 3 data collection methods for gathering sensitive and less sensitive information. Ambul Pediatr. 2008;8(4):255-60. [pmid: 18644548].
Kimerling R, Gima K, Smith MW, Street A, Frayne S. The Veterans Health Administration and military sexual trauma. Am J Public Health. 2007;97(12):2160-6. [pmid: 17971558].
Klevens J, Saltzman LE. The controversy on screening for intimate partner violence: a question of semantics?. J Womens Health. 2009;18(2):143-5. [pmid: 19183083].
Koenig LJ, Whitaker DJ, Royce RA, Wilson TE, Callahan MR, Fernandez MI, et al. Violence during pregnancy among women with or at risk for HIV infection. Am J Public Health. 2002;92(3):367-70. [pmid: 11867312].
Kottwitz D, Bowling S. A pilot study of the Elder Abuse Questionnaire. Kans Nurse. 2003;78(7):4-6. [pmid: 14528596].
Koziol-Mclain J, Campbell JC. Universal screening and mandatory reporting: an update on two important issues for victims/survivors of intimate partner violence. J Emerg Nurs. 2001;27(6):602-6. [pmid: 11712019].
Koziol-McLain J, Garrett N, Fanslow J, Hassall I, Dobbs T, Henare-Toka TA, et al. A randomized controlled trial of a brief emergency department intimate partner violence screening intervention. Ann Emerg Med. 2010;56(4):413-23. [pmid: 20538369].
Koziol-McLain J, Giddings L, Rameka M, Fyfe E. Intimate partner violence screening and brief intervention: experiences of women in two New Zealand health care settings. J Midwifery Womens Health. 2008;53(6):504-10. [pmid: 18984506].
Koziol-McLain J, Rameka M, Giddings L, Fyfe E, Gardiner J. Partner violence prevalence among women attending a Maori health provider clinic. Aust N Z J Public Health. 2007;31(2):143-8. [pmid: 17461005].
Kravitz JA. The SAFE ELDERS Scales: Identifying High Risk Cases of Elder Abuse. Malibu, CA. Pepperdine University. 2007.
Kropp P. Development of the Spousal Assault Risk Assessment Guide (SARA) and the Brief Spousal Assault Form for the Evaluation of Risk (B-SAFER). Baldry AC, Winkel FW, editors. Intimate Partner Violence Prevention and Intervention: The Risk Assessment and Management Approach. Hauppauge, NY. Nova Science Publishers. 2008:19-31.
Kropp P, Gibas A. The Spousal Assault Risk Assessment Guide (SARA): Handbook of Violence Risk Assessment. New York. Routledge/Taylor & Francis. 2010:227-50.
Kropp PR. Intimate partner violence risk assessment and management. Violence Vict. 2008;23(2):202-20. [pmid: 18624090].
Krugman SD, Witting MD, Furuno JP, Hirshon JM, Limcangco R, Perisse AR, et al. Perceptions of help resources for victims of intimate partner violence. J Interpers Violence. 2004;19(7):766-77. [pmid: 15186535].
Kumar S, Jeyaseelan L, Suresh S, Ahuja RC. Domestic violence and its mental health correlates in Indian women. Br J Psychiatry. 2005;187:62-7. [pmid: 15994573].
Lam WK, Fals-Stewart W, Kelley M. The Timeline Followback interview to assess children’s exposure to partner violence: reliability and validity. J Fam Violence. 2009;24(2):133-43.
Lane WG, Dubowitz H, Langenberg P. Screening for occult abdominal trauma in children with suspected physical abuse. Pediatrics. 2009;124(6):1595-602. [pmid: 19933726].
Lau AS, Weisz JR. Reported maltreatment among clinic-referred children: implications for presenting problems, treatment attrition, and long-term outcomes. J Am Acad Child Adolesc Psychiatry. 2003;42(11):1327-34. [pmid: 14566170].
Laughon K, Renker P, Glass N, Parker B. Revision of the Abuse Assessment Screen to address nonlethal strangulation. J Obstet Gynecol Neonatal Nurs. 2008;37(4):502-7. [pmid: 18754989].
Leppakoski T, Astedt-Kurki P, Paavilainen E. Identification of women exposed to acute physical intimate partner violence in an emergency department setting in Finland. Scand J Caring Sci. 2010;24(4):638-47. [pmid: 20487409].
Letarte MJ, Normandeau S, Allard J. Effectiveness of a parent training program “Incredible Years” in a child protection service. Child Abuse Negl. 2010;34(4):253-61. [pmid: 20356626].
Lewis-O’Connor A. When push comes to shove: screening mothers for intimate partner violence during a pediatric visit. Diss Abstr Int B Sci Eng. 2008;68(10B):3283887.
Liebschutz J, Battaglia T, Finley E, Averbuch T. Disclosing intimate partner violence to health care clinicians—what a difference the setting makes: a qualitative study. BMC Public Health. 2008;8:229. [pmid: 18601725].
Loxton D, Schofield M, Hussain R. History of domestic violence and health service use among mid-aged Australian women. Aust N Z J Public Health. 2004;28(4):383-8. [pmid: 15704705].
Lutz KF. Living two lives: a grounded theory of abuse during pregnancy. Commun Nurs Res. 2004;37:101-9. [pmid: 15320541].
Mackay K. To screen or not to screen: identification of domestic violence in Canadian emergency departments. CJEM. 2008;10(4):329-32. [pmid: 18652723].
MacMillan HL, Thomas BH, Jamieson E, Walsh CA, Boyle MH, Shannon HS, et al. Effectiveness of home visitation by public-health nurses in prevention of the recurrence of child physical abuse and neglect: a randomised controlled trial. Lancet. 2005;365(9473):1786-93. [pmid: 15910951].
MacMillan HL, Wathen C. Violence against women: integrating the evidence into clinical practice. CMAJ. 2003;169(6):570-1. [pmid: 12975225].
MacMillan HL, Wathen C, Jamieson E, Boyle M, McNutt LA, Worster A, et al. Approaches to screening for intimate partner violence in health care settings: a randomized trial. JAMA. 2006;296(5):530-6. [pmid: 16882959].
MacMillan HL, Wathen C, Jamieson E, Boyle MH, Shannon HS, Ford-Gilboe M, et al. Screening for intimate partner violence in health care settings: a randomized trial. JAMA. 2009;302(5):493-501. [pmid: 19654384].
Madera SR, Toro-Alfonso J. Description of a domestic violence measure for Puerto Rican gay males. J Homosex. 2005;50(1):155-73. [pmid: 16368669].
Martin SL, Young SK, Billings DL, Bross CC. Health care-based interventions for women who have experienced sexual violence: a review of the literature. Trauma Violence Abuse. 2007;8(1):3-18. [pmid: 17204597].
McCaw B, Bauer HM, Berman WH, Mooney L, Holmberg M, Hunkeler E. Women referred for on-site domestic violence services in a managed care organization. Womens Health. 2002;35(2–3):23-40. [pmid: 12201508].
McClennen JC, Summers AB, Daley JG. The Lesbian Partner Abuse Scale. Res Soc Work Pract. 2002;12(2):277-92.
McColgan MD, Cruz M, McKee J, Dempsey SH, Davis MB, Barry P, et al. Results of a multifaceted intimate partner violence training program for pediatric residents. Child Abuse Negl. 2010;34(4):275-83. [pmid: 20303591].
McCord-Duncan EC, Floyd M, Kemp EC, Bailey B, Lang F. Detecting potential intimate partner violence: which approach do women want?. Fam Med. 2006;38(6):416-22. [pmid: 16741840].
McFarlane J, Greenberg L, Weltge A, Watson M. Identification of abuse in emergency departments: effectiveness of a two-question screening tool. J Emerg Nurs. 1995;21(5):391-4. [pmid: 7500563].
McFarlane J, Hughes R, Nosek M, Groff JY, Swedland N, Mullens P. Abuse Assessment Screen–Disability (AAS-D): measuring frequency, type, and perpetrator of abuse toward women with physical disabilities. J Womens Health Gend Based Med. 2001;10:861-6. [pmid: 11747680].
McFarlane J, Malecha A, Gist J, Watson K, Batten E, Hall I, et al. Increasing the safety-promoting behaviors of abused women. Am J Nurs. 2004;104(3):40-50. [pmid: 15108570].
McFarlane J, Malecha A, Gist J, Watson K, Batten E, Hall I, et al. Protection orders and intimate partner violence: an 18-month study of 150 black, Hispanic, and white women. Am J Public Health. 2004;94(4):613-8. [pmid: 15054014].
McFarlane J, Malecha A, Watson K, Gist J, Batten E, Hall I, et al. Intimate partner physical and sexual assault and child behavior problems. Am J Matern Child Nurs. 2007;32(2):74-80. [pmid: 17356411].
McFarlane JM, Groff JY, O’Brien JA, Watson K. Behaviors of children following a randomized controlled treatment program for their abused mothers. Issues Compr Pediatr Nurs. 2005;28(4):195-211. [pmid: 16356894].
McFarlane JM, Groff JY, O’Brien JA, Watson K. Behaviors of children exposed to intimate partner violence before and 1 year after a treatment program for their mother. Appl Nurs Res. 2005;18(1):7-12. [pmid: 15812730].
McFarlane JM, Groff JY, O’Brien JA, Watson K. Behaviors of children who are exposed and not exposed to intimate partner violence: an analysis of 330 black, white, and Hispanic children. Pediatrics. 2003;112(3 Pt 1):e202-7. [pmid: 12949313].
McFarlane JM, Groff JY, O’Brien JA, Watson K. Secondary prevention of intimate partner violence: a randomized controlled trial. Nurs Res. 2006;55(1):52-61. [pmid: 16439929].
McNutt LA, Waltermaurer E, McCauley J, Campbell J, Ford DE. Rationale for and development of the computerized intimate partner violence screen for primary care. Fam Viol Prev Health Pract. 2005;3:1-12.
McRae RE. The Treatment of Child Neglect Through a Comprehensive Service Strategy Including Home-Based Therapy, Play Therapy, Parent Education, and Parent-Child Interaction Therapy. San Diego. Alliant International University. 2003.
McWhinney-Dehaney L. The Development and Psychometric Testing of the Risk for Abuse Assessment Scale and the Abuse Assessment Tool for Use in Jamaican Women. Atlanta. Emory University. 2007.
Meeks-Sjostrom D. A comparison of three measures of elder abuse. J Nurs Scholarsh. 2004;36(3):247-50. [pmid: 15495494].
Melendez RM, Hoffman S, Exner T, Leu CS, Ehrhardt AA. Intimate partner violence and safer sex negotiation: effects of a gender-specific intervention. Arch Sex Behav. 2003;32(6):499-511. [pmid: 14574094].
Miccio-Fonseca L. MEGA: an ecological risk assessment tool of risk and protective factors for assessing sexually abusive children and adolescents. J Aggress Maltreat Trauma. 2010;19(7):734-56.
Miller E, Decker MR, McCauley HL, Tancredi DJ, Levenson RR, Waldman J, et al. Pregnancy coercion, intimate partner violence and unintended pregnancy. Contraception. 2010;81(4):316-22. [pmid: 20227548].
Miller E, Decker MR, McCauley HL, Tancredi DJ, Levenson RR, Waldman J, et al. A family planning clinic partner violence intervention to reduce risk associated with reproductive coercion. Contraception. 2011;83(3):274-80. [pmid: 21310291].
Miller E, Decker MR, Raj A, Reed E, Marable D, Silverman JG. Intimate partner violence and health care-seeking patterns among female users of urban adolescent clinics. Matern Child Health J. 2010;14(6):910-7. [pmid: 19760162].
Mills TJ, Avegno JL, Haydel MJ. Male victims of partner violence: prevalence and accuracy of screening tools. J Emerg Med. 2006;31(4):447-52. [pmid: 17046494].
Milner JS, Gold RG. Screening spouse abusers for child abuse potential. J Clin Psychol. 1986;42(1):169-72. [pmid: 3950003].
Moon A, Benton D. Tolerance of elder abuse and attitudes toward third-party intervention among African American, Korean American, and white elderly. J Multicult Soc Work. 2000;8(3):283-303.
Moon A, Evans-Campbell T. Awareness of formal and informal sources of help for victims of elder abuse among Korean American and Caucasian elders in Los Angeles. J Elder Abuse Negl. 2000;11(3):1-23. [pmid: 21877981].
Moon A, Lawson K, Carpiac M, Spaziano E. Elder abuse and neglect among veterans in greater Los Angeles: prevalence, types, and intervention outcomes. J Gerontol Soc Work. 2006;46(3–4):187-204. [pmid: 16803784].
Moon A, Tomita SK, Jung-Kamei S. Elder mistreatment among four Asian American groups: an exploratory study on tolerance, victim blaming and attitudes toward third-party intervention. J Gerontol Soc Work. 2002;36(1):153-69.
Moonesinghe L, Rajapaksa L, Samarasinghe G. Development of a screening instrument to detect physical abuse and its use in a cohort of pregnant women in Sri Lanka. Asia Pac J Public Health. 2004;16(2):138-44. [pmid: 15624793].
Munoz-Rivas MJ, Rodriguez JM, Gomez JL, O’Leary DK, del Pilar Gonzalez M. Validation of the modified version of the Conflict Tactics Scale (M-CTS) in a Spanish population of youths. Psicothema. 2007;19(4):693-8. [pmid: 17959128].
Naik AD, Teal CR, Pavlik VN, Dyer CB, McCullough LB. Conceptual challenges and practical approaches to screening capacity for self-care and protection in vulnerable older adults. J Am Geriatr Soc. 2008;56(Suppl 2):S266-70. [pmid: 19016970].
Naumann P, Langford D, Torres S, Campbell J, Glass N. Women battering in primary care practice. Fam Pract. 1999;16(4):343-52. [pmid: 10493703].
Neale AV, Hwalek MA, Scott RO, Sengstock MC, Stahl C. Validation of the Hwalek-Sengstock Elder Abuse Screening Test. J Appl Gerontol. 1991;10(4):406-18.
Nelson CS, Higman SM, Sia C, McFarlane E, Fuddy L, Duggan AK. Medical homes for at-risk children: parental reports of clinician-parent relationships, anticipatory guidance, and behavior changes. Pediatrics. 2005;115(1):48-56. [pmid: 15629981].
Nelson HD. Screening for domestic violence: bridging the evidence gaps. Lancet. 2004;364(Suppl 1):S22-3. [pmid: 15967139].
Noether CD, Finkelstein N, VanDeMark NR, Savage A, Reed BG, Moses DJ. Design strengths and issues of SAMHSA’s Women, Co-occurring Disorders, and Violence Study. Psychiatr Serv. 2005;56(10):1233-6. [pmid: 16215188].
Norton IM, Schauer J. A hospital-based domestic violence group. Psychiatr Serv. 1997;48(9):1186-90. [pmid: 9285981].
Nucero P, O’Connor P. Identification of domestic violence in the emergency department. N J Nurse. 2002;32(7):15. [pmid: 12400198].
Nusbaum N, Cheung V, Cohen J, Keca M, Mailey B. Role of first responders in detecting and evaluating elders at risk. Arch Gerontol Geriatr. 2006;43(3):361-7. [pmid: 16513192].
O’Campo P, Kirst M, Tsamis C, Chambers C, Ahmad F. Implementing successful intimate partner violence screening programs in health care settings: evidence generated from a realist-informed systematic review. Soc Sci Med. 2011;72(6):855-66. [pmid: 21330026].
Ogioni L, Liperoti R, Landi F, Soldato M, Bernabei R, Onder G. Cross-sectional association between behavioral symptoms and potential elder abuse among subjects in home care in Italy: results from the Silvernet study. Am J Geriatr Psychiatry. 2007;15(1):70-8. [pmid: 17194817].
Olds DL, Kitzman H, Cole R, Robinson J, Sidora K, Luckey DW, et al. Effects of nurse home-visiting on maternal life course and child development: age 6 follow-up results of a randomized trial. Pediatrics. 2004;114(6):1550-9. [pmid: 15574614].
Ondersma SJ, Svikis DS, Schuster CR. Computer-based brief intervention: a randomized trial with postpartum women. Am J Prev Med. 2007;32(3):231-8. [pmid: 17236741].
O’Reilly R, Beale B, Gillies D. Screening and intervention for domestic violence during pregnancy care: a systematic review. Trauma Violence Abuse. 2010;11(4):190-201. [pmid: 20688785].
Oschwald M, Renker P, Hughes RB, Arthur A, Powers LE, Curry MA. Development of an accessible Audio Computer-Assisted Self-Interview (A-CASI) to screen for abuse and provide safety strategies for women with disabilities. J Interpers Violence. 2009;24(5):795-818. [pmid: 18515785].
Owen-Smith A, Hathaway J, Roche M, Gioiella ME, Whall-Strojwas D, Silverman J. Screening for domestic violence in an oncology clinic: barriers and potential solutions. Oncol Nurs Forum. 2008;35(4):625-33. [pmid: 18591166].
Padala PR, Madison J, Monnahan M, Marcil W, Price P, Ramaswamy S, et al. Risperidone monotherapy for post-traumatic stress disorder related to sexual assault and domestic abuse in women. Int Clin Psychopharmacol. 2006;21(5):275-80. [pmid: 16877898].
Papadakaki M, Tzamalouka GS, Chatzifotiou S, Chliaoutakis J. Seeking for risk factors of intimate partner violence (IPV) in a Greek national sample: the role of self-esteem. J Interpers Violence. 2009;24(5):732-50. [pmid: 18463309].
Paranjape A, Liebschutz J. STaT: a three-question screen for intimate partner violence. J Womens Health (Larchmt). 2003;12(3):233-9. [pmid: 12804354].
Paranjape A, Rask K, Liebschutz J. Utility of STaT for the identification of recent intimate partner violence. J Natl Med Assoc. 2006;98(10):1663-9. [pmid: 17052059].
Paranjape A, Rodriguez M, Gaughan J, Kaslow NJ. Psychometric properties of a new scale to assess family violence in older African American women: the Family Violence Against Older Women (FVOW) Scale. Violence Against Women. 2009;15(10):1213-26. [pmid: 19710297].
Parish WL, Wang T, Laumann EO, Pan S, Luo Y. Intimate partner violence in China: national prevalence, risk factors and associated health problems. Int Fam Plan Perspect. 2004;30(4):174-81. [pmid: 15590383].
Parkinson GW, Adams RC, Emerling FG. Maternal domestic violence screening in an office-based pediatric practice. Pediatrics. 2001;108(3):1-9. [pmid: 11433046].
Peralta RL, Fleming MF. Screening for intimate partner violence in a primary care setting: the validity of “feeling safe at home” and prevalence results. J Am Board Fam Pract. 2003;16(6):525-32. [pmid: 14963079].
Perciaccante VJ, Carey JW, Susarla SM, Dodson TB. Markers for intimate partner violence in the emergency department setting. J Oral Maxillofac Surg. 2010;68(6):1219-24. [pmid: 20395028].
Perciaccante VJ, Susarla SM, Dodson TB. Validation of a diagnostic protocol used to identify intimate partner violence in the emergency department setting. J Oral Maxillofac Surg. 2010;68(7):1537-42. [pmid: 20561466].
Perez-Carceles MD, Rubio L, Pereniguez JE, Perez-Flores D, Osuna E, Luna A. Suspicion of elder abuse in south eastern Spain: the extent and risk factors. Arch Gerontol Geriatr. 2009;49(1):132-7. [pmid: 18676036].
Perez-Rojo G, Castiello MT, Jaquotot MT. Spanish contribution to international advances in the linguistic and cultural adaptation of a screening tool for elder abuse. Rev Esp Geriatr Gerontol. 2008;43(3):180-8. [pmid: 18682135].
Peters R, Barlow J. Systematic review of instruments designed to predict child maltreatment during the antenatal and postnatal periods. Child Abuse Review. 2003;12(6):416-39.
Petrucci CJ, Mills LG. Domestic violence assessment: current practices and new models for improved child welfare interventions. Brief Treat Crisis Interv. 2002;2(2):153-72.
Phelan MB. Screening for intimate partner violence in medical settings. Trauma Violence Abuse. 2007;8(2):199-213. [pmid: 17545574].
Phillips LR. Domestic violence and aging women. Geriatr Nur. 2000;21(4):188-93. [pmid: 10945884].
Phillips LR. Abuse of aging caregivers: test of a nursing intervention. ANS Adv Nurs Sci. 2008;31(2):164-81. [pmid: 18497592].
Phua DH, Ng TW, Seow E. Epidemiology of suspected elderly mistreatment in Singapore. Singapore Med J. 2008;49(10):765-73. [pmid: 18946608].
Plazaola-Castano J, Ruiz-Perez I, Escriba-Aguir V, Jimenez-Martin JM, Hernandez-Torres E. Validation of the Spanish version of the Index of Spouse Abuse. J Womens Health. 2009;18(4):499-506. [pmid: 19361317].
Plichta SB. Intimate partner violence and physical health consequences: policy and practice implications. J Interpers Violence. 2004;19(11):1296-323. [pmid: 15534333].
Plichta SB. Interactions between victims of intimate partner violence against women and the health care system: policy and practice implications. Trauma Violence Abuse. 2007;8(2):226-39. [pmid: 17545576].
Post LA, Klevens J, Maxwell CD, Shelley GA, Ingram E. An examination of whether coordinated community responses affect intimate partner violence. J Interpers Violence. 2010;25(1):75-93. [pmid: 19196879].
Powers LE, Renker P, Robinson-Whelen S, Oschwald M, Hughes R, Swank P, et al. Interpersonal violence and women with disabilities: analysis of safety promoting behaviors. Violence Against Women. 2009;15(9):1040-69. [pmid: 19608856].
Bhandari M, Sprague S, Dosanjh S, Wu V, Schemitsch EH. Praise Investigators. Prevalence of Abuse and Intimate Partner Violence Surgical Evaluation (PRAISE): rationale and design of a multi-center cross-sectional study. BMC Musculoskelet Disord. 2010;11(77):2010. [pmid: 20416039].
Pullen RL. Screening for abuse and neglect. Nursing. 2007;37(2):69. [pmid: 17273093].
Punukollu M. Domestic violence: screening made practical. J Fam Pract. 2003;52(7):537-43. [pmid: 12841970].
Rabin RF, Jennings JM, Campbell JC. Intimate partner violence screening tools: a systematic review. Am J Prev Med. 2009;36(5):439-45. [pmid: 19362697].
Ramirez IL, Straus MA. The effect of question order on disclosure of intimate partner violence: an experimental test using the Conflict Tactics Scales. J Fam Violence. 2006;21(1):1-9.
Ramsay C, Rivas C, Feder G. Interventions to Reduce Violence and Promote the Physical and Psychosocial Well-Being of Women Who Experience Partner Violence: A Systematic Review of Controlled Evidence. London. Queen Mary’s School of Medicine and Dentistry. 2005.
Ramsay J, Carter Y, Davidson L, Dunne D, Eldridge S, Feder G, et al. Advocacy interventions to reduce or eliminate violence and promote the physical and psychosocial well-being of women who experience intimate partner abuse. Cochrane Database Syst Rev. 2009;3:CD005043. [pmid: 19588364].
Ramsay J, Richardson J, Carter YH, Davidson LL, Feder G. Should health professionals screen women for domestic violence? Systematic review. BMJ. 2002;325(7359):314. [pmid: 12169509].
Ramsden C, Bonner M. A realistic view of domestic violence screening in an emergency department. Accid Emerg Nurs. 2002;10(1):31-9. [pmid: 11998582].
Rathus JH, Feindler EL. Self-report measures specific to the assessment of partner abuse. Assessment of Partner Violence: A Handbook for Researchers and Practitioners. Washington, DC. American Psychological Association. 2004:151-209.
Reeves S, Wysong J. Strategies to address financial abuse. J Elder Abuse Negl. 2010;22(3–4):328-34. [pmid: 20711918].
Regan KV, Bartholomew K, Oram D, Landolt MA. Measuring physical violence in male same-sex relationships: an item response theory analysis of the Conflict Tactics Scales. J Interpers Violence. 2002;17(3):235-52.
Reichenheim ME, Klein R, Moraes CL. Assessing the physical violence component of the Revised Conflict Tactics Scales when used in heterosexual couples: an item response theory analysis. Cad Saude Publica. 2007;23(1):53-62. [pmid: 17187104].
Reichenheim ME, Moraes CL. Comparison between the Abuse Assessment Screen and the revised Conflict Tactics Scales for measuring physical violence during pregnancy. J Epidemiol Community Health. 2004;58(6):523-7. [pmid: 15143123].
Reid RJ, Bonomi AE, Rivara FP, Anderson ML, Fishman PA, Carrell DS, et al. Intimate partner violence among men: prevalence, chronicity, and health effects. Am J Prev Med. 2008;34(6):478-85. [pmid: 18471583].
Reis M, Nahmiash D. Validation of the Indicators of Abuse (IOA) screen. Gerontologist. 1998;38(4):471-80. [pmid: 9726134].
Renker PR, Tonkin P. Women’s views of prenatal violence screening: acceptability and confidentiality issues. Obstet Gynecol. 2006;107(2 Pt 1):348-54. [pmid: 16449123].
Renker PR, Tonkin P. Postpartum women’s evaluations of an audio/video computer-assisted perinatal violence screen. Comput Inform Nurs. 2007;25(3):139-47. [pmid: 17496478].
Resick PA, Galovski TE, O’Brien Uhlmansiek M, Scher CD, Clum GA, Young-Xu Y. A randomized clinical trial to dismantle components of cognitive processing therapy for posttraumatic stress disorder in female victims of interpersonal violence. J Consult Clin Psychol. 2008;76(2):243-58. [pmid: 18377121].
Rhodes KV, Drum M, Anliker E, Frankel RM, Howes DS, Levinson W. Lowering the threshold for discussions of domestic violence: a randomized controlled trial of computer screening. Arch Intern Med. 2006;166(10):1107-14. [pmid: 16717173].
Rhodes KV, Frankel RM, Levinthal N, Prenoveau E, Bailey J, Levinson W. “You’re not a victim of domestic violence, are you?” Provider patient communication about domestic violence. Ann Intern Med. 2007;147(9):620-7. [pmid: 17975184].
Rhodes KV, Lauderdale DS, He T, Howes DS, Levinson W. “Between me and the computer”: increased detection of intimate partner violence using a computer questionnaire. Ann Emerg Med. 2002;40(5):476-84. [pmid: 12399790].
Rhodes KV, Levinson W. Interventions for intimate partner violence against women: clinical applications. JAMA. 2003;289(5):601-5. [pmid: 12578493].
Richard L, Gauvin L, Gosselin C, Ducharme F, Sapinski JP, Trudel M. Integrating the ecological approach in health promotion for older adults: a survey of programs aimed at elder abuse prevention, falls prevention, and appropriate medication use. Int J Public Health. 2008;53(1):46-56. [pmid: 18522369].
Rickert VI, Davison LL, Breitbart V, Jones K, Palmetto NP, Rottenberg L, et al. A randomized trial of screening for relationship violence in young women. J Adolesc Health. 2009;45(2):163-70. [pmid: 19628143].
Rinfret-Raynor M, Turgeon J, Dube M. A systematic screening protocol of domestic violence: measurement of efficiency. Can J Commun Ment Health. 2002;21(1):85-99. [pmid: 12630133].
Robinson-Whelen S, Hughes RB, Powers LE, Oschwald M, Renker P, Swank PR, et al. Efficacy of a computerized abuse and safety assessment intervention for women with disabilities: a randomized controlled trial. Rehabil Psychol. 2010;55(2):97-107. [pmid: 20496965].
Ross J, Walther V, Epstein I. Screening risks for intimate partner violence and primary care settings: implications for future abuse. Soc Work Health Care. 2004;38(4):1-23. [pmid: 15149903].
Runyan DK, Cox CE, Dubowitz H, Newton RR, Upadhyaya M, Kotch JB, et al. Describing maltreatment: do Child Protective Service reports and research definitions agree?. Child Abuse Negl. 2005;29(5):461-77. [pmid: 15970320].
Sadowski L. Intimate partner violence towards women. Clin Evid (Online). pii. 2009;2009:1013. [pmid: 19445762].
Sanchez Y. Elder mistreatment in Mexican American communities: the Nevada and Michigan experiences. Tatara T, editor. Understanding Elder Abuse in Minority Populations. Philadelphia. Brunner/Mazel. 1999.
Scafidi EC. Understanding Partner Psychological Abuse and Depressive Symptoms: A New Measure and a New Theoretical Model. New Brunswick, NJ. Rutgers University. 2007.
Schafer SD, Drach LL, Hedberg K, Kohn MA. Using diagnostic codes to screen for intimate partner violence in Oregon emergency departments and hospitals. Public Health Rep. 2008;123(5):628-35. [pmid: 18828418].
Schofield MJ, Mishra GD. Validity of self-report screening scale for elder abuse: Women’s Health Australia study. Gerontologist. 2003;43(1):110-20. [pmid: 12604752].
Schofield MJ, Mishra GD. Three year health outcomes among older women at risk of elder abuse: Women’s Health Australia. Qual Life Res. 2004;13(6):1043-52. [pmid: 15287271].
Schofield MJ, Reynolds R, Mishra GD, Powers JR, Dobson AJ. Screening for vulnerability to abuse among older women: Women’s Heath Australia study. J Appl Gerontol. 2002;21(1):24-39.
Scholle SH, Buranosky R, Hanusa BH, Ranieri L, Dowd K, Valappil B. Routine screening for intimate partner violence in an obstetrics and gynecology clinic. Am J Public Health. 2003;93(7):1070-2. [pmid: 12835182].
Schonfeld L, Larsen RG, Stiles PG. Behavioral health services utilization among older adults identified within a state abuse hotline database. Gerontologist. 2006;46(2):193-9. [pmid: 16581883].
Schultz PN, Remick-Barlow GA, Robbins L. Equine-assisted psychotherapy: a mental health promotion/intervention modality for children who have experienced intra-family violence. Health Soc Care Community. 2007;15(3):265-71. [pmid: 17444990].
Schwartz L, Jensen MP, Romano JM. The development and psychometric evaluation of an instrument to assess spouse responses to pain and well behavior in patients with chronic pain: the Spouse Response Inventory. J Pain. 2005;6(4):243-52. [pmid: 15820912].
Senseman RL. Screening for intimate partner violence among gay and lesbian patients in primary care. Clin Excell Nurse Pract. 2002;6(4):27-32.
Sethi D, Watts S, Zwi A, Watson J, McCarthy C. Experience of domestic violence by women attending an inner city accident and emergency department. Emerg Med J. 2004;21(2):180-4. [pmid: 14988343].
Shackelford TK, Goetz AT. Men’s sexual coercion in intimate relationships: development and initial validation of the Sexual Coercion in Intimate Relationships Scale. Violence Vict. 2004;19(5):541-56. [pmid: 15844724].
Shakil A, Donald S, Sinacore JM, Krepcho M. Validation of the HITS domestic violence screening tool with males. Fam Med. 2005;37(3):193-8. [pmid: 15739135].
Sharps PW, Campbell J, Baty ML, Walker KS, Bair-Merritt MH. Current evidence on perinatal home visiting and intimate partner violence. J Obstet Gynecol Neonatal Nurs. 2008;37(4):480-90. [pmid: 18754987].
Short LM, Alpert E, Harris JM Jr, Surprenant ZJ. A tool for measuring physician readiness to manage intimate partner violence. Am J Prev Med. 2006;30(2):173-80. [pmid: 16459217].
Short LM, Hadley SM, Bates B. Assessing the success of the WomanKind program: an integrated model of 24-hour health care response to domestic violence. Women Health. 2002;35(2–3):101-19. [pmid: 12201502].
Short LM, Rodriguez R. Testing an intimate partner violence assessment icon form with battered migrant and seasonal farmworker women. Women Health. 2002;35(2–3):181-92. [pmid: 12201507].
Siemieniuk RA, Krentz HB, Gish JA, Gill MJ. Domestic violence screening: prevalence and outcomes in a Canadian HIV population. AIDS Patient Care STDS. 2010;24(12):763-70. [pmid: 21138382].
Sikkema KJ, Hansen NB, Tarakeshwar N, Kochman A, Tate DC, Lee RS. The clinical significance of change in trauma-related symptoms following a pilot group intervention for coping with HIV-AIDS and childhood sexual trauma. AIDS Behav. 2004;8(3):277-91. [pmid: 15475675].
Silverstein MN. Factors Associated With Intimate Partner Violence During Pregnancy: An Evolutionary Feminist Approach. Denver. University of Colorado at Denver. 2003.
Simpson LE, Atkins DC, Gattis KS, Christensen A. Low-level relationship aggression and couple therapy outcomes. J Fam Psychol. 2008;22(1):102-11. [pmid: 18266537].
Slep AM, Heyman RE. Severity of partner and child maltreatment: reliability of scales used in America’s largest Child and Family Protection Agency. J Fam Violence. 2004;19(2):95-106.
Smedslund G, Dalsbo TK, Steiro A, Winsvold A, Clench-Aas J. Cognitive behavioural therapy for men who physically abuse their female partner. Cochrane Database Syst Rev. 2007;3:CD006048. [pmid: 17636823].
Smith CO, Thompson MP, Johnson K, Nitsche AM, Kaslow NJ. Service utilization patterns of maltreated and nonmaltreated children from low-income, African-American families. Psychiatr Serv. 2009;60(10):1386-9. [pmid: 19797382].
Sohal H, Eldridge S, Feder G. The sensitivity and specificity of four questions (HARK) to identify intimate partner violence: a diagnostic accuracy study in general practice. BMC Fam Pract. 2007;8:49. [pmid: 17727730].
Sormanti M, Shibusawa T. Intimate partner violence among midlife and older women: a descriptive analysis of women seeking medical services. Health Soc Work. 2008;33(1):33-41. [pmid: 18326448].
Spangaro J, Zwi AB, Poulos R. The elusive search for definitive evidence on routine screening for intimate partner violence. Trauma Violence Abuse. 2009;10(1):55-68. [pmid: 19056688].
Spangaro JM. The NSW Health routine screening for domestic violence program. N S W Public Health Bull. 2007;18(5–6):86-9. [pmid: 17651662].
Spangaro JM, Zwi AB, Poulos RG. “Persist. persist.”: a qualitative study of women’s decisions to disclose and their perceptions of the impact of routine screening for intimate partner violence. Psychol Violence. 2011;1(2):150-62.
Spangaro JM, Zwi AB, Poulos RG, Man WY. Who tells and what happens: disclosure and health service responses to screening for intimate partner violence. Health Soc Care Community. 2010;18(6):671-80. [pmid: 20637041].
Spangaro JM, Zwi AB, Poulos RG, Man WYN. Six months after routine screening for intimate partner violence: attitude change, useful and adverse effects. Women Health. 2010;50(2):125-43. [pmid: 20437301].
Sprecher AG, Muelleman RL, Wadman MC. A neural network model analysis to identify victims of intimate partner violence. Am J Emerg Med. 2004;22(2):87-9. [pmid: 15011219].
Stader SR, Holmes GR, McNulty GF, Forand AQ, Myers D. Comparison of scores for abused and nonabused young adults on the Psychological Trauma and Resources Scale. Psychol Rep. 2004;94(2):687-93. [pmid: 15154203].
Stappenbeck CA, Fals-Stewart W. Measuring intimate partner violence: a comparison of the Conflict Tactics Scale and the Timeline Followback Spousal Violence Interview. Morgan JP, editor. Focus on Aggression Research. Hauppauge, NY. Nova Science Publishers. 2004:1-13.
Stayton CD, Duncan MM. Mutable influences on intimate partner abuse screening in health care settings: a synthesis of the literature. Trauma Violence Abuse. 2005;6(4):271-85. [pmid: 16217117].
Stover CS, Poole G, Marans S. The domestic violence home-visit intervention: impact on police-reported incidents of repeat violence over 12 months. Violence Vict. 2009;24(5):591-606. [pmid: 19852401].
Straus H, Cerulli C, McNutt LA, Rhodes KV, Conner KR, Kemball RS, et al. Intimate partner violence and functional health status: associations with severity, danger, and self-advocacy behaviors. J Womens Health. 2009;18(5):625-31. [pmid: 19445614].
Straus MA, Douglas EM. A short form of the Revised Conflict Tactics Scales, and typologies for severity and mutuality. Violence Vict. 2004;19(5):507-20. [pmid: 15844722].
Suellentrop K, Morrow B, Williams L, D’Angelo D. Centers for Disease Control and Prevention. Monitoring progress toward achieving Maternal and Infant Healthy People 2010 objectives: 19 states, Pregnancy Risk Assessment Monitoring System (PRAMS). MMWR Surveill Summ. 2006;55(9):1-11. [pmid: 17021594].
Sugg N. What do medical providers need to successfully intervene with intimate partner violence?. J Aggress Maltreat Trauma. 2006;13(3–4):101-20.
Svavarsdottir EK. Detecting intimate partner abuse within clinical settings: self-report or an interview. Scand J Caring Sci. 2010;24(2):224-32. [pmid: 20230520].
Swan SC. A review of research on women’s use of violence with male intimate partners. Violence Vict. 2008;23(3):301-14. [pmid: 18624096].
Swenson CC, Schaeffer CM, Henggeler SW, Faldowski R, Mayhew AM. Multisystemic therapy for child abuse and neglect: a randomized effectiveness trial. J Fam Psychol. 2010;24(4):497-507. [pmid: 20731496].
Taft A, Hegarty K, Ramsay J, Feder G, Carter Y, Davidson L, et al. Screening women for intimate partner violence in health care settings. Cochrane Database Syst Rev. 2009.
Taft A, Small R, Hegarty K, Watson L, Gold L, Lumley J. Mothers’ Advocates in the Community (MOSAIC)—non-professional mentor support to reduce intimate partner violence and depression in mothers: a cluster randomised trial in primary care. BMC Public Health. 2011;11(1):178. [pmid: 21429226].
Taft AJ, Hegarty KL. Intimate partner violence against women: what outcomes are meaningful?. JAMA. 2010;304(5):577-9. [pmid: 20682943].
Taft AJ, Small R, Hegarty KL, Lumley J, Watson LF, Gold L. MOSAIC (Mothers’ Advocates in the Community): protocol and sample description of a cluster randomised trial of mentor mother support to reduce intimate partner violence among pregnant or recent mothers. BMC Public Health. 2009;9:159. [pmid: 19473534].
Taket A, Wathen CN, Macmillan H. Should health professionals screen all women for domestic violence?. PLoS Med. 2004;1(1):e4. [pmid: 15526052].
Thackeray J, Stelzner S, Downs SM, Miller C. Screening for intimate partner violence: the impact of screener and screening environment on victim comfort. J Interpers Violence. 2007;22(6):659-70. [pmid: 17515428].
Thomas NJ, Shaffer ML, Rzucidlo S, Shirk BJ, Dias MS. Temporal factors and the incidence of physical abuse in young children: decreased nonaccidental trauma during child abuse prevention month. J Pediatr Surg. 2007;42(10):1735-9. [pmid: 17923205].
Thombs BD, Bernstein DP, Ziegelstein RC, Bennett W, Walker EA. A brief two-item screener for detecting a history of physical or sexual abuse in childhood. Gen Hosp Psychiatry. 2007;29(1):8-13. [pmid: 17189738].
Tilden VP, Shepherd P. Increasing the rate of identification of battered women in an emergency department: use of a nursing protocol. Res Nurs Health. 1987;10(4):209-24. [pmid: 3503315].
Tiwari A, Fong DY, Yuen KH, Yuk H, Pang P, Humphreys J, et al. Effect of an advocacy intervention on mental health in Chinese women survivors of intimate partner violence: a randomized controlled trial. JAMA. 2010;304(5):536-43. [pmid: 20682933].
Tiwari A, Leung WC, Leung TW, Humphreys J, Parker B, Ho PC. A randomised controlled trial of empowerment training for Chinese abused pregnant women in Hong Kong. BJOG. 2005;112(9):1249-56. [pmid: 16101604].
Torres A, Navarro P, Garcia-Esteve L, Tarragona MJ, Ascaso C, Herreras Z, et al. Detecting domestic violence: Spanish external validation of the Index of Spouse Abuse. J Fam Violence. 2010;25(3):275-86. [pmid: 21757210].
Trabold N. Screening for intimate partner violence within a health care setting: a systematic review of the literature. Soc Work Health Care. 2007;45(1):1-18. [pmid: 17804344].
Trautman DE, McCarthy ML, Miller N, Campbell JC, Kelen GD. Intimate partner violence and emergency department screening: computerized screening versus usual care. Ann Emerg Med. 2007;49(4):526-34. [pmid: 17276547].
Vega EM, O’Leary KD. Reaction time and item presentation factors in the self-report of partner aggression. Violence Vict. 2006;96(4):519-32. [pmid: 16897918].
Vest JR, Catlin TK, Chen JJ, Brownson RC. Multistate analysis of factors associated with intimate partner violence. Am J Prev Med. 2002;22(3):156-64. [pmid: 11897459].
Vivilaki VG, Dafermos V, Daglas M, Antoniou E, Tsopelas ND, Theodorakis PN, et al. Identifying intimate partner violence (IPV) during the postpartum period in a Greek sample. Arch Womens Ment Health. 2010;13(6):467-76. [pmid: 20306211].
Vreeman RC, Carroll AE. A systematic review of school-based interventions to prevent bullying. Arch Pediatr Adolesc Med. 2007;161(1):78-88. [pmid: 17199071].
Wahl RA, Sisk DJ, Ball TM. Clinic-based screening for domestic violence: use of a child safety questionnaire. BMC Med. 2004;2:25. [pmid: 15228622].
Waller A, Hohenhaus S, Shah P, Stern E. Development and validation of an emergency department screening and referral protocol for victims of domestic violence. Ann Emerg Med. 1996;27(6):754-60. [pmid: 8644964].
Waltermaurer E, McNutt LA, Mattingly MJ. Examining the effect of residential change on intimate partner violence risk. J Epidemiol Community Health. 2006;60(11):923-7. [pmid: 17053280].
Wang JJ. Psychological abuse behavior exhibited by caregivers in the care of the elderly and correlated factors in long-term care facilities in Taiwan. J Nurs Res. 2005;13(4):271-80. [pmid: 16372238].
Wang JJ, Lin JN, Lee FP. Psychologically abusive behavior by those caring for the elderly in a domestic context. Geriatr Nur. 2006;27(5):284-91. [pmid: 17045127].
Wang JJ, Lin MF, Tseng HF, Chang WY. Caregiver factors contributing to psychological elder abuse behavior in long-term care facilities: a structural equation model approach. Int Psychogeriatr. 2009;21(2):314-20. [pmid: 19138458].
Wang JJ, Tseng HF, Chen KM. Development and testing of screening indicators for psychological abuse of older people. Arch Psychiatr Nurs. 2007;21(1):40-7. [pmid: 17258108].
Wathen C, Jamieson E, MacMillan HL. Who is identified by screening for intimate partner violence?. Womens Health Issues. 2008;18(6):423-32. [pmid: 19041594].
Wathen C, MacMillan HL. Interventions for violence against women: scientific review. JAMA. 2003;289(5):589-600. [pmid: 12578492].
Wathen CN, Jamieson E, Wilson MH, Daly M, Worster A, MacMillan HL. Risk indicators to identify intimate partner violence in the emergency department. Open Med. 2007;1(2):113-22. [pmid: 20101295].
Wathen CN, Macmillan HL, Jamieson E. Screening for intimate partner violence. Am J Prev Med. 2006;31(5):453. [pmid: 17046419].
Waxman HC, Houston WR, Profilet SM, Sanchez B. The long-term effects of the Houston Child Advocates, Inc., program on children and family outcomes. Child Welfare. 2009;88(6):23-46. [pmid: 20695290].
Webster J. Screening for domestic violence: the “evidence” dilemma. Contemp Nurse. 2006;21(2):163-4. [pmid: 16696598].
Webster J, Holt V. Screening for partner violence: direct questioning or self-report?. Obstet Gynecol. 2004;103(2):299-303. [pmid: 14754699].
Weinsheimer RL, Schermer CR, Malcoe LH, Balduf LM, Bloomfield LA. Severe intimate partner violence and alcohol use among female trauma patients. J Trauma. 2005;58(1):22-9. [pmid: 15674145].
Weiss SJ, Ernst AA, Cham E, Nick TG. Development of a screen for ongoing intimate partner violence. Violence Vict. 2003;18(2):131-41. [pmid: 12816400].
Wenzel JD, Monson CL, Johnson SM. Domestic violence: prevalence and detection in a family medicine residency clinic. J Am Osteopath Assoc. 2004;104(6):233-9. [pmid: 15233329].
Wetmore M, Fairbairn CD. A regional California program to screen adolescent patients for intimate partner violence. J Emerg Nurs. 2003;29(4):373-6. [pmid: 12874565].
Wherry JN, Graves LE, King HM. The convergent validity of the trauma symptom checklist for young children for a sample of sexually abused outpatients. J Child Sex Abus. 2008;17(1):38-50. [pmid: 19842317].
Whitaker DJ, Haileyesus T, Swahn M, Saltzman LS. Differences in frequency of violence and reported injury between relationships with reciprocal and nonreciprocal intimate partner violence. Am J Public Health. 2007;97(5):941-7. [pmid: 17395835].
Whitfield CL, Anda RF, Dube SR, Felitti VJ. Violent childhood experiences and the risk of intimate partner violence in adults: assessment in a large health maintenance organization. J Interpers Violence. 2003;18(2):166-85.
Wiglesworth A, Mosqueda L, Mulnard R, Liao S, Gibbs L, Fitzgerald W. Screening for abuse and neglect of people with dementia. J Am Geriatr Soc. 2010;58(3):493-500. [pmid: 20398118].
Williams KR, Grant SR. Empirically examining the risk of intimate partner violence: the revised Domestic Violence Screening Instrument (DVSI-R). Public Health Rep. 2006;121(4):400-8. [pmid: 16827441].
Williams TL. The Development and Validation of a Multi-Dimensional Assessment Instrument of Child Sexual Abuse Experiences. College Station, TX. Texas A&M University. 2002.
Wolfe DA, Crooks C, Jaffe P, Chiodo D, Hughes R, Ellis W, et al. A school-based program to prevent adolescent dating violence: a cluster randomized trial. Arch Pediatr Adolesc Med. 2009;163(8):692-9. [pmid: 19652099].
Woodman J, Pitt M, Wentz R, Taylor B, Hodes D, Gilbert RE. Performance of screening tests for child physical abuse in accident and emergency departments. Health Technol Assess. xi. 2008;12(33):iii-xiii. 1. 95. [pmid: 18992184].
Wrangle J, Fisher JW, Paranjape A. Ha sentido sola? Culturally competent screening for intimate partner violence in Latina women. J Womens Health. 2008;17(2):261-8. [pmid: 18321177].
Wright DC, Woo WL, Muller RT, Fernandes CB, Kraftcheck ER. An investigation of trauma-centered inpatient treatment for adult survivors of abuse. Child Abuse Negl. 2003;27(4):393-406. [pmid: 12686324].
Wu V, Huff H, Bhandari M. Pattern of physical injury associated with intimate partner violence in women presenting to the emergency department: a systematic review and meta-analysis. Trauma Violence Abuse. 2010;11(2):71-82. [pmid: 20430799].
Yaffe MJ. Detection and reporting of elder abuse. Fam Med. 2010;42(2):83. [pmid: 20135557].
Yaffe MJ, Wolfson C, Lithwick M, Weiss D. Development and validation of a tool to improve physician identification of elder abuse: the Elder Abuse Suspicion Index (EASI). J Elder Abuse Negl. 2008;20(3):276-300. [pmid: 18928055].
Yoshihama M, Clum K, Crampton A, Gillespie B. Measuring the lifetime experience of domestic violence: application of the Life History Calendar method. Violence Vict. 2002;17(3):297-317. [pmid: 12102055].
Young CA, Douglass JP. Use of, and outputs from, an assault patient questionnaire within accident and emergency departments on Merseyside. Emerg Med J. 2003;20(3):232-7. [pmid: 12748137].
Zeitler MS, Paine AD, Breitbart V, Rickert VI, Olson C, Stevens L, et al. Attitudes about intimate partner violence screening among an ethnically diverse sample of young women. J Adolesc Health. 2006;39(1):e1-8. [pmid: 16781970].
Zink T, Fisher BS. Family violence quality assessment tool for primary care offices. Qual Manag Health Care. 2007;16(3):265-79. [pmid: 17627222].
Zink T, Klesges LM, Levin L, Putnam F. Abuse behavior inventory: cutpoint, validity, and characterization of discrepancies. J Interpers Violence. 2007;22(7):921-31. [pmid: 17575069].
Zink T, Levin L, Putnam F, Beckstrom A. Accuracy of five domestic violence screening questions with nongraphic language. Clin Pediatr. 2007;46(2):127-34. [pmid: 17325085].
Zink T, Lloyd K, Isham G, Mathews DJ, Crowson T. Applying the planned care model to intimate partner violence. Manag Care. 2007;16(3):54-61. [pmid: 17432168].
Zink T, Siegel R, Chen L, Levin L, Pabst S, Putnam F. Physician knowledge and management of children exposed to domestic violence in Ohio: a comparison of pediatricians and family physicians. Clin Pediatr (Phila). 2005;44(3):211-9. [pmid: 15821845].
Zun L. Violence prevention in the ED. Am J Emerg Med. 2003;21(6):454-7. [pmid: 14574650].
Zun LS, Downey L, Rosen J. The effectiveness of an ED-based violence prevention program. Am J Emerg Med. 2006;24(1):8-13. [pmid: 16338502].
Zun LS, Downey LV, Rosen J. Violence prevention in the ED: linkage of the ED to a social service agency. Am J Emerg Med. 2003;21(6):454-7. [pmid: 14574650].

### Studies of Screening Tests

Bair-Merritt MH, Jennings JM, Eaker K, Tuman JL, Park SM, Cheng TL. Screening for domestic violence and childhood exposure in families seeking care at an urban pediatric clinic. J Pediatr. 2008;152(5):734-6. [pmid: 18410785].
Bifulco A, Bernazzani O, Moran PM, Jacobs C. The Childhood Experience of Care and Abuse Questionnaire (CECA.Q): validation in a community series. Br J Clin Psychol. 2005;44(Pt 4):563-81. [pmid: 16368034].
Bremner J, Bolus R, Mayer EA. Psychometric properties of the Early Trauma Inventory-Self-Report. J Nerv Ment Dis. 2007;195(3):211-8. [pmid: 17468680].
Carr GD, Moretti MM, Cue BJ. Evaluating parenting capacity: validity problems with the MMPI-2, PAI, CAPI, and Ratings of Child Adjustment. Prof Psychol Res Pr. 2005;36(2):188-96.
Carroll JC, Reid AJ, Biringer A, Midmer D, Glazier RH, Wilson L, et al. Effectiveness of the Antenatal Psychosocial Health Assessment (ALPHA) form in detecting psychosocial concerns: a randomized controlled trial. CMAJ. 2005;173(3):253-9. [pmid: 16076821].
Cerezo MA, Pons-Salvador G. Improving child maltreatment detection systems: a large-scale case study involving health, social services, and school professionals. Child Abuse Negl. 2004;28(11):1153-69. [pmid: 15567021].
Chaffin M, Valle LA. Dynamic prediction characteristics of the Child Abuse Potential Inventory. Child Abuse Negl. 2003;27(5):463-81. [pmid: 12718957].
Chang DC, Knight VM, Ziegfeld S, Haider A, Paidas C. The multi-institutional validation of the new screening index for physical child abuse. J Pediatr Surg. 2005;40(1):114-9. [pmid: 15868569].
DiLillo D, Hayes-Skeltona SA, Fortier M, Perrya AR, Evansa SE, Messman-Moore T, et al. Development and initial psychometric properties of the Computer Assisted Maltreatment Inventory (CAMI): a comprehensive self-report measure of child maltreatment history. Child Abuse Negl Int J. 2010;34(5):305-14. [pmid: 20347148].
Feigelman S, Dubowitz H, Lane W, Prescott L, Meyer W, Tracy J, et al. Screening for harsh punishment in a pediatric primary care clinic. Child Abuse Negl. 2009;33(5):269-77. [pmid: 19477005].
Fricker AE, Smith DW, Davis JL, Hanson RF. Effects of context and question type on endorsement of childhood sexual abuse. J Trauma Stress. 2003;16(3):265-8. [pmid: 12816339].
Friedrich WN, Fisher JL, Dittner CA, Acton R, Berliner L, Butler J, et al. Child Sexual Behavior Inventory: normative, psychiatric, and sexual abuse comparisons. Child Maltreat. 2001;6(1):37-49. [pmid: 11217169].
Gully KJ. Expectations test: trauma scales for sexual abuse, physical abuse, exposure to family violence, and posttraumatic stress. Child Maltreat. 2003;8(3):218-29. [pmid: 12934639].
Harrington D, Zuravin S, DePanfilis D, Ting L, Dubowitz H. The Neglect Scale: confirmatory factor analyses in a low-income sample. Child Maltreat. 2002;7(4):359-68. [pmid: 12408247].
Hymel KP, Stoiko MA, Herman BE, Combs A, Harper NS, Lowen D, et al. Head injury depth as an indicator of causes and mechanisms. Pediatrics. 2010;125(4):712-20. [pmid: 20351004].
Kantor GK, Holt MK, Mebert CJ, Straus MA, Drach KM, Ricci LR, et al. Development and preliminary psychometric properties of the multidimensional Neglectful Behavior Scale–Child Report. Child Maltreat. 2004;9(4):409-28. [pmid: 15538039].
Kilpatrick KL. The parental empathy measure: a new approach to assessing child maltreatment risk. Am J Orthopsychiatry. 2005;75(4):608-20. [pmid: 16262518].
Lounds JJ, Borkowski JG, Whitman TL. Reliability and validity of the Mother-Child Neglect Scale. Child Maltreat. 2004;9(4):371-81. [pmid: 15538036].
Melchert TP, Kalemeera A. A brief version of the Family Background Questionnaire. Meas Eval Couns Dev. 2009;41(4):210-22.
Midmer D, Bryanton J, Brown R. Assessing antenatal psychosocial health: randomized controlled trial of two versions of the ALPHA form. Can Fam Physician. 2004;50:80-7. [pmid: 14761108].
Milner JS. Medical conditions and Child Abuse Potential Inventory specificity. Psychol Assess. 1991;3(2):208-12.
Milner JS, Gold RG, Ayoub C, Jacewitz MM. Predictive validity of the Child Abuse Potential Inventory. J Consult Clin Psychol. 1984;52(5):879-84. [pmid: 6501673].
Moran PM, Bifulco A, Ball C, Jacobs C, Benaim K. Exploring psychological abuse in childhood, I: developing a new interview scale. Bull Menninger Clin. 2002;66(3):213-40. [pmid: 12448628].
Murphy S, Orkow B, Nicola RM. Prenatal prediction of child abuse and neglect: a prospective study. Child Abuse Negl. 1985;9(2):225-35. [pmid: 4005663].
Nilsson D, Wadsby M, Svedin CG. The psychometric properties of the Trauma Symptom Checklist for Children (TSCC) in a sample of Swedish children. Child Abuse Negl. 2008;32(6):627-36. [pmid: 18584867].
Ondersma SJ, Chaffin MJ, Mullins SM, LeBreton JM. A brief form of the Child Abuse Potential Inventory: development and validation. J Clin Child Adolesc Psychol. 2005;34(2):301-11. [pmid: 15901230].
Paivio SC, Cramer KM. Factor structure and reliability of the Childhood Trauma Questionnaire in a Canadian undergraduate student sample. Child Abuse Negl. 2004;28(8):889-904. [pmid: 15350772].
Peterson L, Tremblay G, Ewigman B, Popkey C. The parental daily diary: a sensitive measure of the process of change in a child maltreatment prevention program. Behav Modif. 2002;26(5):627-47. [pmid: 12375378].
Pierce MC, Kaczor K, Aldridge S, O’Flynn J, Lorenz DJ. Bruising characteristics discriminating physical child abuse from accidental trauma. Pediatrics. 2010;125(1):67-74. [pmid: 19969620].
Pless IB, Sibald AD, Smith MA, Russell MD. A reappraisal of the frequency of child abuse seen in pediatric emergency rooms. Child Abuse Negl. 1987;11(2):193-200. [pmid: 3496143].
Prosser LA, Corso PS. Measuring health-related quality of life for child maltreatment: a systematic literature review. Health Qual Life Outcomes. 2007;5:42. [pmid: 17634122].
Reichenheim ME, Moraes CL. Psychometric properties of the Portuguese version of the Conflict Tactics Scales: Parent-child Version (CTSPC) used to identify child abuse. Cad Saude Publica. 2006;22(3):503-15. [pmid: 16583094].
Robertson KR, Milner JS. Construct validity of the Child Abuse Potential Inventory. J Clin Psychol. 1983;39(3):426-9. [pmid: 6874976].
Russell BS. Revisiting the measurement of shaken baby syndrome awareness. Child Abuse Negl. 2010;34(9):671-6. [pmid: 20638721].
Salvagni EP, Wagner MB. Development of a questionnaire for the assessment of sexual abuse in children and estimation of its discriminant validity: a case-control study. J Pediatr (Rio J). 2006;82(6):431-6. [pmid: 16951801].
Shaffer A, Huston L, Egeland B. Identification of child maltreatment using prospective and self-report methodologies: a comparison of maltreatment incidence and relation to later psychopathology. Child Abuse Negl. 2008;32(7):682-92. [pmid: 18638626].
Thombs BD. Measurement Invariance of the Childhood Trauma Questionnaire Across Gender and Race/Ethnicity: Applications of Structural Equation Modeling and Item Response Theory. New York. Fordham University. 2005.
Thombs BD, Bernstein DP, Lobbestael J, Arntz A. A validation study of the Dutch Childhood Trauma Questionnaire–Short Form: factor structure, reliability, and known-groups validity. Child Abuse Negl. 2009;33(8):518-23. [pmid: 19758699].
Thombs BD, Bernstein DP, Ziegelstein RC, Scher CD, Forde DR, Walker EA, et al. An evaluation of screening questions for childhood abuse in 2 community samples: implications for clinical practice. Arch Intern Med. 2006;166(18):2020-6. [pmid: 17030837].
Uchison TJ. Using the CBCL to screen for maltreatment in young children. Keene, NH. Antioch New England Graduate School. 2007.
Veltman MW, Browne KD. Identifying abused children using assessments and observations in the classroom: a preliminary study. Child Abuse Rev. 2003;12(5):315-34.
Walsh CA, MacMillan HL, Trocme N, Jamieson E, Boyle MH. Measurement of victimization in adolescence: development and validation of the Childhood Experiences of Violence Questionnaire. Child Abuse Negl. 2008;32(11):1037-57. [pmid: 18992940].

### Wrong Intervention (not linked to screening/risk assessment, clinic setting, or prevention)

Barlow J, Smailagic N, Bennett C, Huband N, Jones H, Coren E. Individual and group based parenting programmes for improving psychosocial outcomes for teenage parents and their children. Cochrane Database Syst Rev. 2011;5:CD002964. [pmid: 21412881].
Berzin SC, Cohen E, Thomas K, Dawson WC. Does family group decision making affect child welfare outcomes? Findings from a randomized control study. Child Welfare. 2008;87(4):35-54. [pmid: 19391466].
Brown SD. An investigation of trauma symptom reduction in a clinical sample of sexually abused children using the Trauma Symptom Checklist for Children. Atlanta. Georgia State University. 2008.
Cohen JA, Mannarino AP, Knudsen K. Treating sexually abused children: 1 year follow-up of a randomized controlled trial. Child Abuse Negl. 2005;29(2):135-45. [pmid: 15734179].
Conley A, Berrick JD. Community-based child abuse prevention: outcomes associated with a differential response program in California. Child Maltreat. 2010;15(4):282-92. [pmid: 20647255].
Finkelhor D. Prevention of sexual abuse through educational programs directed toward children. Pediatrics. 2007;120(3):640-5. [pmid: 17766537].
Lefever JB, Howard KS, Lanzi RG, Borkowski JG, Atwater J, Guest KC, et al. Cell phones and the measurement of child neglect: the validity of the Parent-Child Activities Interview. Child Maltreat. 2008;13(4):320-33. [pmid: 18612039].
Lobbestael J, Arntz A, Harkema-Schouten P, Bernstein D. Development and psychometric evaluation of a new assessment method for childhood maltreatment experiences: the Interview for Traumatic Events in Childhood (ITEC). Child Abuse Negl. 2009;33(8):505-17. [pmid: 19758701].
McWhirter PT. Differential therapeutic outcomes of community-based group interventions for women and children exposed to intimate partner violence. J Interpers Violence. 2011;26(12):2457-82. [pmid: 20889533].
Nagle GA. Maternal Participation, Depression and Partner Violence in a State Run Child Abuse Prevention Program: Louisiana Nurse Home Visitation 1999–2002. New Orleans. Tulane University. 2002.
Palmer S, Stalker CA, Harper K, Gadbois S. Balancing positive outcomes with vicarious traumatization: participants’ experiences with group treatment for long-term effects of childhood abuse. Soc Work Groups. 2007;30(4):59-77.
Prinz RJ, Sanders MR, Shapiro CJ, Whitaker DJ, Lutzker JR. Population-based prevention of child maltreatment: the U.S. Triple P System Population Trial. Prev Sci. 2009;10(1):1-12. [pmid: 19160053].
Reich DB, Winternitz S, Hennen J, Watts T, Stanculescu C. A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. J Clin Psychiatry. 2004;65(12):1601-6. [pmid: 15641864].
Resick PA, Nishith P, Griffin MG. How well does cognitive-behavioral therapy treat symptoms of complex PTSD? An examination of child sexual abuse survivors within a clinical trial. CNS Spectr. 2003;8(5):340-55. [pmid: 12766690].
Ruch LO, Wang CH. Validation of the Sexual Assault Symptom Scale II (SASS II) using a panel research design. J Interpers Violence. 2006;21(11):1440-61. [pmid: 17057161].
Sikkema KJ, Hansen NB, Kochman A, Tarakeshwar N, Neufeld S, Meade CS, et al. Outcomes from a group intervention for coping with HIV/AIDS and childhood sexual abuse: reductions in traumatic stress. AIDS Behav. 2007;11(1):49-60. [pmid: 16858634].
Smith N, Lam D, Bifulco A, Checkley S. Childhood Experience of Care and Abuse Questionnaire (CECA.Q): validation of a screening instrument for childhood adversity in clinical populations. Soc Psychiatry Psychiatr Epidemiol. 2002;37(12):572-9. [pmid: 12545234].
Thomas R, Zimmer-Gembeck MJ. Accumulating evidence for parent-child interaction therapy in the prevention of child maltreatment. Child Dev. 2011;82(1):177-92. [pmid: 21291436].
Timmer SG, Urquiza AJ, Zebell NM, McGrath JM. Parent-child interaction therapy: application to maltreating parent-child dyads. Child Abuse Negl. 2005;29(7):825-42. [pmid: 16051355].
Tourigny M, Hebert M, Daigneault I, Simoneau AC. Efficacy of a group therapy for sexually abused adolescent girls. J Child Sex Abus. 2005;14(4):71-93. [pmid: 16354649].
Wallis DA. Reduction of trauma symptoms following group therapy. Aust N Z J Psychiatry. 2002;36(1):67-74. [pmid: 11929440].

### Wrong Outcome

Ayoub CC, Milner JS. Failure to thrive: parental indicators, types, and outcomes. Child Abuse Negl. 1985;9(4):491-9. [pmid: 4084828].
Barr RG, Barr M, Fujiwara T, Conway J, Catherine N, Brant R. Do educational materials change knowledge and behavior about crying and shaken baby syndrome? A randomized controlled trial. CMAJ. 2009;180(7):727-33. [pmid: 19255065].
Conners NA, Whiteside-Mansell L, Deere D, Ledet T, Edwards MC. Measuring the potential for child maltreatment: the reliability and validity of the Adult Adolescent Parenting Inventory–2. Child Abuse Negl. 2006;30(1):39-53. [pmid: 16406026].
Crouch JL, Skowronski JJ, Milner JS, Harris B. Parental responses to infant crying: the influence of child physical abuse risk and hostile priming. Child Abuse Negl. 2008;32:702-10. [pmid: 18606450].
DiLillo D, DeGue S, Kras A, Di Loreto-Colgan AR, Nash C. Participant responses to retrospective surveys of child maltreatment: does mode of assessment matter?. Violence Vict. 2006;21(4):410-24. [pmid: 16897910].
DiLillo D, Tremblay GC, Peterson L. Linking childhood sexual abuse and abusive parenting: the mediating role of maternal anger. Child Abuse Negl. 2000;24(6):767-79. [pmid: 10888017].
Duggan A, Fuddy L, Burrell L, Higman SM, McFarlane E, Windham A, et al. Randomized trial of a statewide home visiting program to prevent child abuse: impact in reducing parental risk factors. Child Abuse Negl. 2004;28(6):625-45. [pmid: 15193852].
Duggan A, Fuddy L, McFarlane E, Burrell L, Windham A, Higman S, et al. Evaluating a statewide home visiting program to prevent child abuse in at-risk families of newborns: fathers’ participation and outcomes. Child Maltreat. 2004;9(1):3-17. [pmid: 14870994].
Eckenrode J, Campa M, Luckey DW, Henderson CR, Cole R, Kitzman H, et al. Long-term effects of prenatal and infancy nurse home visitation on the life course of youths: 19-year follow-up of a randomized trial. Arch Pediatr Adolesc Med. 2010;164(1):9-15. [pmid: 20048236].
Katz C, Hershkowitz I. The effects of drawing on children’s accounts of sexual abuse. Child Maltreat. 2010;15(2):171-9. [pmid: 19926626].
Kitzman H, Olds DL, Cole RE, Hanks CA, Anson EA, Arcoleo KJ, et al. Enduring effects of prenatal and infancy home visiting by nurses on children: follow-up of a randomized trial among children at age 12 years. Arch Pediatr Adolesc Med. 2010;164(5):412-8. [pmid: 20439791].
Kosterman R, Hawkins JD, Haggerty KP, Spoth R, Redmond C. Preparing for the drug free years: session-specific effects of a universal parent-training intervention with rural families. J Drug Educ. 2001;31(1):47-68. [pmid: 11338965].
Lane WG, Dubowitz H. Primary care pediatricians’ experience, comfort and competence in the evaluation and management of child maltreatment: do we need child abuse experts?. Child Abuse Negl. 2009;33(2):76-83. [pmid: 19278726].
McCurdy K. Risk assessment in child abuse prevention programs. Soc Work Res. 1995;19(2):77-87.
McGuigan WM, Katzev AR, Pratt CC. Multi-level determinants of retention in a home-visiting child abuse prevention program. Child Abuse Negl. 2003;27(4):363-80. [pmid: 12686322].
Moss E, Dubois-Comtois K, Cyr C, Tarabulsy GM, St-Laurent D, Bernier A. Efficacy of a home-visiting intervention aimed at improving maternal sensitivity, child attachment, and behavioral outcomes for maltreated children: a randomized control trial. Dev Psychopathol. 2011;23(1):195-210. [pmid: 21262048].
Olds DL, Robinson J, O’Brien R, Luckey DW, Pettitt LM, Henderson CR, et al. Home visiting by paraprofessionals and by nurses: a randomized, controlled trial. Pediatrics. 2002;110(3):486-96. [pmid: 12205249].
Olds DL, Robinson J, Pettitt L, Luckey DW, Holmberg J, Ng RK, et al. Effects of home visits by paraprofessionals and by nurses: age 4 follow-up results of a randomized trial. Pediatrics. 2004;114(6):1560-8. [pmid: 15574615].
Pruitt DL, Erickson MT. The Child Abuse Potential Inventory: a study of concurrent validity. J Clin Psychol. 1985;41(1):104-11. [pmid: 3973031].
Reynolds AJ, Temple JA, Ou SR, Robertson DL, Mersky JP, Topitzes JW, et al. Effects of a school-based, early childhood intervention on adult health and well-being: a 19-year follow-up of low-income families. Arch Pediatr Adolesc Med. 2007;161(8):730-9. [pmid: 17679653].
Rodriguez ML, Dumont K, Mitchell-Herzfeld SD, Walden NJ, Greene R. Effects of Healthy Families New York on the promotion of maternal parenting competencies and the prevention of harsh parenting. Child Abuse Negl. 2010;34(10):711-23. [pmid: 20850872].
Russa MB, Rodriguez CM. Physical discipline, escalation, and child abuse potential: psychometric evidence for the Analog Parenting Task. Aggress Behav. 2010;36(4):251-60. [pmid: 20540158].
Savell JK, Kinder BN, Young MS. Effects of administering sexually explicit questionnaires on anger, anxiety, and depression in sexually abused and nonabused females: implications for risk assessment. J Sex Marital Ther. 2006;32(2):161-72. [pmid: 16418106].
Thombs BD, Bennett W, Ziegelstein RC, Bernstein DP, Scher CD, Forde DR. Cultural sensitivity in screening adults for a history of childhood abuse: evidence from a community sample. J Gen Intern Med. 2007;22(3):368-73. [pmid: 17356970].
Tyrka AR, Price LH, Kao HT, Porton B, Marsella SA, Carpenter LL. Childhood maltreatment and telomere shortening: preliminary support for an effect of early stress on cellular aging. Biol Psychiatry. 2010;67(6):531-4. [pmid: 19828140].
Zelenko MA, Huffman LC, Brown BW, Daniels K, Lock J, Kennedy Q, et al. The Child Abuse Potential Inventory and pregnancy outcome in expectant adolescent mothers. Child Abuse Negl. 2001;25:1481-95. [pmid: 11766012].
Zielinski DS, Eckenrode J, Olds DL. Nurse home visitation and the prevention of child maltreatment: impact on the timing of official reports. Dev Psychopathol. 2009;21(2):441-53. [pmid: 19338692].

### Wrong Study Design

Bradshaw JM. Preventing Shaken Baby Syndrome: A Comparison of Two Parent Education Programs. Storrs-Mansfield. University of Connecticut. 2011.
Dias MS, Smith K, DeGuehery K, Mazur P, Li V, Shaffer ML. Preventing abusive head trauma among infants and young children: a hospital-based, parent education program. Pediatrics. 2005;115(4):e470-7. [pmid: 15805350].
Eckenrode J, Powers J, Olds D, Kitzman H, Cole R. Long-term effects of early home visitation on rates of state-verified cases of child abuse and neglect. Pediatr Res. 1996;39.
Margolis PA, Stevens R, Bordley WC, Stuart J, Harlan C, Keyes-Elstein L, et al. From concept to application: the impact of a community-wide intervention to improve the delivery of preventive services to children. Pediatrics. 2001;108(3):e42. [pmid: 11533360].
Mercier CE, Barry SE, Paul K, Delaney TV, Horbar JD, Wasserman RC, et al. Improving newborn preventive services at the birth hospitalization: a collaborative, hospital-based quality-improvement project. Pediatrics. 2007;120(3):481-8. [pmid: 17766519].

### No Primary Data, Editorial, Nonsystematic Review

American Medical Association. Policy Compendium. Accessed at http://www.ama-assn.org/ama1/pub/upload/mm/386/vio_policy_comp.pdf.
Anderson CL. The Parenting Profile Assessment: screening for child abuse. Appl Nurs Res. 1993;6(1):31-8. [pmid: 8439176].
Barr RG, Runyan D. Inflicted childhood neurotrauma: the problem set and challenges to measuring incidence. Am J Prev Med. 2008;34(Suppl 1):S106-11. [pmid: 18374258].
Barth RP. Preventing with parent training: evidence and opportunities. Future Child. 2009;19(2):95-118. [pmid: 19719024].
Donelan-McCall N, Eckenrode J, Olds DL. Home visiting for the prevention of child maltreatment: lessons learned during the past 20 years. Pediatr Clin North Am. 2009;56(2):389-403. [pmid: 19358923].
Dubowitz H. Tackling child neglect: a role for pediatricians. Pediatr Clin North Am. 2009;56(2):363-78. [pmid: 19358921].
Edleson JL, Ellerton AL, Seagren EA, Kirchberg SL, Schmidt SO, Ambrose AT. Assessing child exposure to adult domestic violence. Child Youth Serv Rev. 2007;29(7):961-71.
Edwards A, Lutzker JR. Iterations of the SafeCare model: an evidence-based child maltreatment prevention program. Behav Modif. 2008;32(5):736-56. [pmid: 18441332].
Futures Without Violence. National Consensus Guidelines on Identifying and Responding to Domestic Violence Victimization in Health Care Settings. Accessed at http://www.futureswithoutviolence.org/userfiles/file/Consensus.pdf.
Hayward S. Nurse home visits reduced child abuse and neglect over a 15 year period. Evid Based Nurs. 1998;1(3):77.
Howard KS, Brooks-Gunn J. The role of home-visiting programs in preventing child abuse and neglect. Future Child. 2009;19(2):119-46. [pmid: 19719025].
Hulme PA. Retrospective measurement of childhood sexual abuse: a review of instruments. Child Maltreat. 2004;9(2):201-17. [pmid: 15104889].
Hulme PA. Psychometric evaluation and comparison of three retrospective, multi-item measures of childhood sexual abuse. Child Abuse Negl. 2007;31(8):853-69. [pmid: 17825410].
Klevens J, Whitaker DJ. Primary prevention of child physical abuse and neglect: gaps and promising directions. Child Maltreat. 2007;12(4):364-77. [pmid: 17954942].
Korfmacher J. The Kempe Family Stress Inventory: a review. Child Abuse Negl. 2000;24(1):129-40. [pmid: 10660015].
Krugman SD, Lane WG, Walsh CM. Update on child abuse prevention. Curr Opin Pediatr. 2007;19(6):711-8. [pmid: 18025942].
LeCroy CW, Krysik J. Measurement issues in home visitation: a research note. Child Youth Serv Rev. 2010;32(10):1483-6.
Lock TG, Levis DJ, Rourke PA. The Sexual Abuse Questionnaire: a preliminary examination of a time and cost efficient method in evaluating the presence of childhood sexual abuse in adult patients. J Child Sex Abus. 2005;14(1):1-26. [pmid: 15914402].
MacMillan HL, Wathen CN, Barlow J, Fergusson DM, Leventhal JM, Taussig HN. Interventions to prevent child maltreatment and associated impairment. Lancet. 2009;373:250-66. [pmid: 19056113].
Marcellus L. The ethics of relation: public health nurses and child protection clients. J Adv Nurs. 2005;51(4):414-20. [pmid: 16086810].
Midmer D, Carroll J, Bryanton J, Stewart D. From research to application: the development of an antenatal psychosocial health assessment tool. Can J Public Health. 2002;93(4):291-6. [pmid: 12154533].
Mowat A. Toolkit will help GPs detect children at risk of abuse. Practitioner. 2008;252(1706):5. [pmid: 18575383].
Newton AW, Vandeven AM. Child abuse and neglect: a worldwide concern. Curr Opin Pediatr. 2010;22:226-33. [pmid: 20164772].
Olds DL. Prenatal and infancy home visiting by nurses: from randomized trials to community replication. Pediatrics. 2002;3(3):153-72. [pmid: 12387552].
Olds DL, Sadler L, Kitzman H. Programs for parents of infants and toddlers: recent evidence from randomized trials. J Child Psychol Psychiatry. 2007;48(3–4):355-91. [pmid: 17355402].
Ondersma SJ, Chaffin MJ, Mullins SM, LeBreton JM. “A brief form of the Child Abuse Potential Inventory: development and validation”: erratum. J Clin Child Adolesc Psychol. 2006;35(4):598. [pmid: 15901230].
Proeve M. Issues in the application of Bayes’ theorem to child abuse decision making. Child Maltreat. 2009;14(1):114-20. [pmid: 18495947].
Reynolds AJ, Mathieson LC, Topitzes JW. Do early childhood interventions prevent child maltreatment? A review of research. Child Maltreat. 2009;14(2):182-206. [pmid: 19240245].
Russell BS, Britner PA, Woolard JL. The promise of primary prevention home visiting programs: a review of potential outcomes. J Prev Interv Community. 2007;34(1–2):129-47. [pmid: 17890197].
Scribano PV. Prevention strategies in child maltreatment. Curr Opin Pediatr. 2010;22(5):616-20. [pmid: 20829692].
Shapiro CJ, Prinz RJ, Sanders MR. Population-based provider engagement in delivery of evidence-based parenting interventions: challenges and solutions. J Prim Prev. 2010;31(4):223-34. [pmid: 20195773].
Strand VC, Sarmiento TL, Pasquale LE. Assessment and screening tools for trauma in children and adolescents: a review. Trauma Violence Abuse. 2005;6(1):55-78. [pmid: 15574673].
Strecher V, Wang C, Derry H, Wildenhaus K, Johnson C. Tailored interventions for multiple risk behaviors. Health Educ Res. 2002;17(5):619-26. [pmid: 12408206].
Walker CA, Davies J. A critical review of the psychometric evidence base of the Child Abuse Potential Inventory. J Fam Violence. 2010;25(2):215-27.
Walsh C, Jamieson E, MacMillan H, Trocme N. Measuring child sexual abuse in children and youth. J Child Sex Abus. 2004;13(1):39-68. [pmid: 15353376].

### Risk Factor, Association, or Prevalence Study

Adams BL. Assessment of child abuse risk factors by advanced practice nurses. Pediatr Nurs. 2005;31(6):498-502. [pmid: 16411545].
Blackburn JF. Reading Skills in Children Exposed to Domestic Violence. Bloomington, IN. Indiana University. 2006.
Castelda BA, Levis DJ, Rourke PA, Coleman SL. Extension of the Sexual Abuse Questionnaire to other abuse categories: the initial psychometric validation of the Binghamton Childhood Abuse Screen. J Child Sex Abus. 2007;16(1):107-25. [pmid: 17255079].
Chang DC, Knight V, Ziegfeld S, Haider A, Warfield D, Paidas C. The tip of the iceberg for child abuse: the critical roles of the pediatric trauma service and its registry. J Trauma. 2004;57(6):1189-98. [pmid: 15625449].
Dubowitz H, Kim J, Black MM, Weisbart C, Semiatin J, Magder LS. Identifying children at high risk for a child maltreatment report. Child Abuse Negl. 2011;35(2):96-104. [pmid: 21376396].
Ekeus C, Christensson K, Hjern A. Unintentional and violent injuries among pre-school children of teenage mothers in Sweden: a national cohort study. J Epidemiol Community Health. 2004;58:680-5. [pmid: 15252071].
Lee LC, Kotch J, Cox C. Child maltreatment in families experiencing domestic violence. Violence Vict. 2004;19(5):573-91. [pmid: 15844726].
McDonald R, Jouriles EN, Tart CD, Minze LC. Children’s adjustment problems in families characterized by men’s severe violence toward women: does other family violence matter?. Child Abuse Negl. 2009;33(2):94-101. [pmid: 19303141].
Neggers Y, Goldenberg R, Cliver S, Hauth J. Effects of domestic violence on preterm birth and low birth weight. Acta Obstet Gynecol Scand. 2004;83(5):455-60. [pmid: 15059158].
Palazzi S, de Girolamo G, Liverani T. IchilMa (Italian Child Maltreatment Study Group). Observational study of suspected maltreatment in Italian paediatric emergency departments. Arch Dis Child. 2005;90(4):406-10. [pmid: 15781934].
Pulido ML, Gupta D. Protecting the child and the family: integrating domestic violence screening into a child advocacy center. Violence Against Women. 2002;8(8):917-33.
Reijneveld SA, de Meer G, Wiefferink CH, Crone MR. Detection of child abuse by Dutch preventive child-healthcare doctors and nurses: has it changed?. Child Abuse Negl. 2008;32(9):831-7. [pmid: 18945489].
Reynolds AJ, Robertson DL. School-based early intervention and later child maltreatment in the Chicago Longitudinal Study. Child Dev. 2003;74(1):3-26. [pmid: 12625433].
Reynolds AJ, Temple JA, Ou SR. School-based early intervention and child well-being in the Chicago Longitudinal Study. Child Welfare. 2003;82(5):633-56. [pmid: 14524429].
Roy CA, Perry JC. Instruments for the assessment of childhood trauma in adults. J Nerv Ment Dis. 2004;192(5):343-51. [pmid: 15126888].
Storer E. Identifying Mothers at Risk for Child Abuse Through the Development of a Maternal Prenatal Assessment Instrument. San Francisco. Alliant International University. 2003.
Strathearn L, Mamun AA, Najman JM, O’Callaghan MJ. Does breastfeeding protect against substantiated child abuse and neglect? A 15-year cohort study. Pediatrics. 2009;123(2):483-93. [pmid: 19171613].
Theodore A, Chang JJ, Runyan D. Measuring the risk of physical neglect in a population-based sample. Child Maltreat. 2007;12(1):96-105. [pmid: 17218651].
Weberling LC, Forgays DK, Crain-Thoreson C, Hyman I. Prenatal child abuse risk assessment: a preliminary validation study. Child Welfare. 2003;82(3):319-34. [pmid: 12769394].

### Systematic Reviews With Different Inclusion Criteria

Allin H, Wathen CN, MacMillan H. Treatment of child neglect: a systematic review. Can J Psychiatry. 2005;50(8):497-504. [pmid: 16127968].
Bair-Merritt MH, Blackstone M, Feudtner C. Physical health outcomes of childhood exposure to intimate partner violence: a systematic review. Pediatrics. 2006;117(2):e278-90. [pmid: 16452335].
Bilukha O, Hahn RA, Crosby A, Fullilove MT, Liberman A, Moscicki E, et al. The effectiveness of early childhood home visitation in preventing violence: a systematic review. Am J Prev Med. 2005;28(Suppl1):11-39. [pmid: 15698746].
Geeraert L, Van den Noortgate W, Grietens H, Onghena P. The effects of early prevention programs for families with young children at risk for physical child abuse and neglect: a meta-analysis. Child Maltreat. 2004;9(3):277-91. [pmid: 15245680].
Hahn RA, Bilukha OO, Crosby A, Fullilove MT, Liberman A, Moscicki EK, et al. First reports evaluating the effectiveness of strategies for preventing violence: early childhood home visitation. Findings from the Task Force on Community Preventive Services. MMWR Recomm Rep. 2003;52(RR14):1-9. [pmid: 14566220].
Harding K, Galano J, Martin J, Huntington L, Schellenbach CJ. Healthy Families America effectiveness: a comprehensive review of outcomes. J Prev Interv Community. 2007;34(1–2):149-79. [pmid: 17890198].
Hodnett ED, Roberts I. Home-based social support for socially disadvantaged mothers. Cochrane Database Syst Rev. 2000;2:CD000107. [pmid: 10796694].
Louwers EC, Affourtit MJ, Moll HA, de Koning HJ, Korfage IJ. Screening for child abuse at emergency departments: a systematic review. Arch Dis Child. 2010;95(3):214-8. [pmid: 19773222].
Lundahl BW, Nimer J, Parsons B. Preventing child abuse: a meta-analysis of parent training programs. Res Soc Work Pract. 2006;16(3):251-62.
Macdonald G, Bennett C, Dennis JA, Coren E, Patterson J, Astin M, et al. Home-based support for disadvantaged teenage mothers. Cochrane Database Syst Rev. 2007;3:CD006723. [pmid: 17636849].
Ramchandani P, Jones DP. Treating psychological symptoms in sexually abused children: from research findings to service provision. Br J Psychiatry. 2003;183:484-90. [pmid: 14645018].
Shah PS, Shah J. Knowledge Synthesis Group on Determinants of Preterm Low Birth Weight Births. Maternal exposure to domestic violence and pregnancy and birth outcomes: a systematic review and meta-analyses. J Womens Health (Larchmt). 2010;19(11):2017-31. [pmid: 20919921].
Spinks A, Turner C, Nixon J, McClure RJ. The “WHO Safe Communities” model for the prevention of injury in whole populations. Cochrane Database Syst Rev. 2009;3:CD004445. [pmid: 19588359].
Sweet MA, Appelbaum MI. Is home visiting an effective strategy? A meta-analytic review of home visiting programs for families with young children. Child Dev. 2004;75(5):1435-56. [pmid: 15369524].

### Trials Excluded for Poor Quality

Armstrong KL, Fraser JA, Dadds MR, Morris J. A randomized, controlled trial of nurse home visiting to vulnerable families with newborns. J Paediatr Child Health. 1999;35(3):237-44. [pmid: 10404442].
Hardy JB, Streett R. Family support and parenting education in the home: an effective extension of clinic-based preventive health care services for poor children. J Pediatr. 1989;115(6):927-31. [pmid: 2585229].
Krysik J, LeCroy CW. The evaluation of Healthy Families Arizona: a multisite home visitation program. J Prev Interv Community. 2007;34(1–2):109-27. [pmid: 17890196].
Larson CP. Efficacy of prenatal and postpartum home visits on child health and development. Pediatrics. 1980;66(2):191-7. [pmid: 7402804].
Starn JR. Community health nursing visits for at-risk women and infants. J Community Health Nurs. 1992;9(2):103-10. [pmid: 1624977].
Stevens-Simon C, Nelligan D, Kelly L. Adolescents at risk for mistreating their children, II: a home- and clinic-based prevention program. Child Abuse Negl. 2001;25(6):753-69. [pmid: 11525524].

## Appendix A5 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized Controlled Trials (RCTs) and Cohort Studies

#### Criteria

- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of ratings based on above criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
Poor: | Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

### Case Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variable

#### Definition of ratings based on criteria above

Good: | Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.
Fair: | Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.
Poor: | Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

Source: Harris et al, 2001^57^

## Appendix A6 Expert Reviewers of the Draft Report

Joseph Chin, MD, MS

Medical Officer, Coverage and Analysis Group, Centers for Medicare and Medicaid Services

Howard Dubowitz, MD, MS

Professor, Department of Pediatrics; Division Head of the Division of Child Protection; Director, Center for Families, University of Maryland Medical Center

Beverly L. Fortson, PhD

Behavioral Scientist, Centers for Disease Control and Prevention

Robert A. Hahn, PhD, MPH

Coordinating Scientist, Centers for Disease Control and Prevention

Harriet L. MacMillan, MD, MSc, FRCP(C)

Professor, Psychiatry and Behavioural Neurosciences and Pediatrics, McMaster University