# References

1 U.S.Preventive Services Task Force. Counseling to Prevent Tobacco Use and Tobacco-Caused Disease: Recommendation Statement. Rockville, MD. Agency for Healthcare Quality and Research. 2003.
2 Fiore MC, Bailey WC, Cohen SJ, et al. Treating Tobacco Use and Dependence: Clinical Practice Guideline. Rockville, MD. U.S. Department of Health and Human Services, Public Health Service. 2000.
3 Centers for Disease Control and Prevention. Smoking-attributable mortality, years of potential life lost, and productivity losses—United States, 2000–2004. MMWR Morb Mortal Wkly Rep. 2008;57(45):1226-8. [pmid: 19008791].
4 Centers for Disease Control and Prevention. Fact Sheet: Youth and Tobacco Use. Atlanta. Centers for Disease Control and Prevention. 2012. Accessed at http://www.cdc.gov/tobacco/data_statistics/fact_sheets/youth_data/tobacco_use/index.htm on. 30 November 2012.
5 FDA issues final rule restricting access and marketing of cigarettes and smokeless tobacco products to youth [news release]. Washington, DC. U.S. Department of Health and Human Services. March. 18. 2010. Accessed at http://www.hhs.gov/news/press/2010pres/03/20100318a.html on. 30 November 2012.
6 Substance Abuse and Mental Health Services Administration. Results From the 2010 National Survey on Drug Use and Health: Summary of National Findings. NSDUH Series H-41. HHS Publication No. (SMA) 11-4658. Rockville, MD. Substance Abuse and Mental Health Services Administration. 2011. Accessed at http://www.samhsa.gov/data/nsduh/2k10nsduh/2k10results.htm on. 30 November 2012.
7 U.S. Department of Health and Human Services. The Health Consequences of Smoking: A Report of the Surgeon General. Atlanta. Centers for Disease Control and Prevention. 2004. Accessed at http://www.surgeongeneral.gov/library/reports/smokingconsequences/index.html on. 30 November 2012.
8 U.S. Department of Health and Human Services. Preventing Tobacco Use Among Youth and Young Adults: A Report of the Surgeon General, 2012. Atlanta. Centers for Disease Control and Prevention. 2012. Accessed at http://www.surgeongeneral.gov/library/reports/preventing-youth-tobacco-use/index.html on. 30 November 2012.
9 Vickers KS, Thomas JL, Patten CA, et al. Prevention of tobacco use in adolescents: review of current findings and implications for healthcare providers. Curr Opin Pediatr. 2002;14(6):708-12. [pmid: 12436041].
10 Mowery PD, Brick PD, Farrelly MC. Pathways to Established Smoking: Results From the 1999 National Youth Tobacco Survey. Washington, DC. American Legacy Foundation. 2000. Accessed at http://www.legacyforhealth.org/4184.aspx on. 30 November 2012.
11 Curry SJ, Hollis J, Bush T, et al. A randomized trial of a family-based smoking prevention intervention in managed care. Prev Med. 2003;37(Pt 1):617-26. [pmid: 14636795].
12 Pierce JP, Choi WS, Gilpin EA, et al. Validation of susceptibility as a predictor of which adolescents take up smoking in the United States. Health Psychol. 1996;15(5):355-61. [pmid: 8891714].
13 DiFranza J, Wellman RJ, Mermelstein R, et al. The natural history and diagnosis of nicotine addiction. Curr Pediatr Rev. 2011;7:88-96.
14 Centers for Disease Control and Prevention. Tobacco use among middle and high school students—United States, 2000–2009. MMWR Morb Mortal Wkly Rep. 2010;59(33):1063-8. [pmid: 20798668].
15 Eaton DK, Kann L, Kinchen S, et al., Centers for Disease Control and Prevention. Youth risk behavior surveillance—United States, 2009. MMWR Surveill Summ. 2010;59(5):1-142. [pmid: 20520591].
16 U.S. Department of Health and Human Services. Healthy People 2020: Tobacco Use Objectives. Washington, DC. U.S. Department of Health and Human Services. 2012. Accessed at http://www.healthypeople.gov/2020/topicsobjectives2020/objectiveslist.aspx?topicId=41 on. 30 November 2012.
17 Johnston LD, O'Malley PM, Bachman JG, Schulenberg JE. Monitoring the Future National Results on Adolescent Drug Use: Overview of Key Findings, 2011. Ann Arbor, MI. Institute for Social Research, The University of Michigan. 2012. Accessed at http://www.monitoringthefuture.org/pubs/monographs/mtf-overview2011.pdf on. 30 November 2012.
18 Giovino GA. Epidemiology of tobacco use in the United States. Oncogene. 2002;21(48):7326-40. [pmid: 12379876].
19 Centers for Disease Control and Prevention. Cigarette use among high school students—United States, 1991–2009. MMWR Morb Mortal Wkly Rep. 2010;59(26):797-801. [pmid: 20613702].
20 Mermelstein R, Colby SM, Patten C, et al. Methodological issues in measuring treatment outcome in adolescent smoking cessation studies. Nicotine Tob Res. 2002;4(4):395-403. [pmid: 12521399].
21 West R, Hajek P, Stead L, et al. Outcome criteria in smoking cessation trials: proposal for a common standard. Addiction. 2005;100(3):299-303. [pmid: 15733243].
22 Brener ND, Billy JO, Grady WR. Assessment of factors affecting the validity of self-reported health-risk behavior among adolescents: evidence from the scientific literature. J Adolesc Health. 2003;33(6):436-57. [pmid: 14642706].
23 Dolcini MM, Adler NE, Lee P, Bauman KE. An assessment of the validity of adolescent self-reported smoking using three biological indicators. Nicotine Tob Res. 2003;5(4):473-83. [pmid: 12959785].
24 Dolcini MM, Alder NE, Ginsberg D. Factors influencing agreement between self-reports and biological measures of smoking among adolescents. J Res Adolesc. 1996;6(4):515-42.
25 Adams J, Parkinson L, Sanson-Fisher RW, et al. Enhancing self-report of adolescent smoking: the effects of bogus pipeline and anonymity. Addict Behav. 2008;33(10):1291-6. [pmid: 18644682].
26 SRNT Subcommittee on Biochemical Verification. Biochemical verification of tobacco use and cessation. Nicotine Tob Res. 2002;4(2):149-59. [pmid: 12028847].
27 Bricker JB, Peterson AV Jr, Andersen MR, et al. Parents' and older siblings' smoking during childhood: changing influences on smoking acquisition and escalation over the course of adolescence. Nicotine Tob Res. 2007;9(9):915-26. [pmid: 17763107].
28 Hill KG, Hawkins JD, Catalano RF, et al. Family influences on the risk of daily smoking initiation. J Adolesc Health. 2005;37(3):202-10. [pmid: 16109339].
29 Farkas AJ, Gilpin EA, White MM, et al. Association between household and workplace smoking restrictions and adolescent smoking. JAMA. 2000;284(6):717-22. [pmid: 10927780].
30 Bricker JB, Leroux BG, Peterson AV Jr, et al. Nine-year prospective relationship between parental smoking cessation and children's daily smoking. Addiction. 2003;98(5):585-93. [pmid: 12751972].
31 Smith BN, Bean MK, Mitchell KS, et al. Psychosocial factors associated with non-smoking adolescents' intentions to smoke. Health Educ Res. 2007;22(2):238-47. [pmid: 16880217].
32 Tyc VL, Hadley W, Allen D, et al. Predictors of smoking intentions and smoking status among nonsmoking and smoking adolescents. Addict Behav. 2004;29(6):1143-7. [pmid: 15236815].
33 Barton J, Chassin L, Presson CC, et al. Social image factors as motivators of smoking initiation in early and middle adolescence. Child Dev. 1982;53(6):1499-511. [pmid: 7172778].
34 Doubeni CA, Li W, Fouayzi H, et al. Perceived accessibility as a predictor of youth smoking. Ann Fam Med. 2008;6(4):323-30. [pmid: 18626032].
35 DiFranza JR, Wellman RJ, Sargent JD, et al. Tobacco promotion and the initiation of tobacco use: assessing the evidence for causality. Pediatrics. 2006;117(6):e1237-48. [pmid: 16740823].
36 Hu MC, Griesler P, Schaffran C, Kandel D. Risk and protective factors for nicotine dependence in adolescence. J Child Psychol Psychiatry. 2011;52(10):1063-72. [pmid: 21250992].
37 Rivara FP, Ebel BE, Garrison MM, et al. Prevention of smoking-related deaths in the United States. Am J Prev Med. 2004;27(2):118-25. [pmid: 15261898].
38 Carson KV, Brinn MP, Labiszewski NA, et al. Community interventions for preventing smoking in young people. Cochrane Database Syst Rev. 2011;(7):CD001291. [pmid: 21735383].
39 Grimshaw GM, Stanton A. Tobacco cessation interventions for young people. Cochrane Database Syst Rev. 2006;(4):CD003289. [pmid: 17054164].
40 Stead LF, Lancaster T. Interventions for preventing tobacco sales to minors. Cochrane Database Syst Rev. 2005;(1):CD001497. [pmid: 15674880].
41 Brinn MP, Carson KV, Esterman AJ, et al. Mass media interventions for preventing smoking in young people. Cochrane Database Syst Rev. 2010;(11):CD001006. [pmid: 21069667].
42 DiFranza JR. Which interventions against the sale of tobacco to minors can be expected to reduce smoking?. Tob Control. 2012;21(4):436-42. [pmid: 21994275].
43 Thomas RE, Baker P, Lorenzetti D. Family-based programmes for preventing smoking by children and adolescents. Cochrane Database Syst Rev. 2007;(1):CD004493. [pmid: 17253511].
44 Centers for Disease Control and Prevention. Best Practices for Comprehensive Tobacco Control Programs—2007. Atlanta. Centers for Disease Control and Prevention. 2007. Accessed at http://www.cdc.gov/tobacco/stateandcommunity/best_practices/index.htm on. 30 November 2012.
45 Task Force on Community Preventive Services. Tobacco. The Guide to Community Preventive Services: What Works to Promote Health?. New York. Oxford University Press. 2005:3-79.
46 Backinger CL, McDonald P, Ossip-Klein DJ, et al. Improving the future of youth smoking cessation. Am J Health Behav. 2003;27(Suppl 2):S170-84. [pmid: 14521244].
47 Curry SJ, Mermelstein RJ, Sporer AK. Therapy for specific problems: youth tobacco cessation. Annu Rev Psychol. 2009;60:229-55. [pmid: 19035825].
48 Garrison MM, Christakis DA, Ebel BE, et al. Smoking cessation interventions for adolescents: a systematic review. Am J Prev Med. 2003;25(4):363-7. [pmid: 14580641].
49 Gervais A, O'Loughlin J, Dugas E, et al. A systematic review of randomized controlled trials of youth smoking cessation interventions. Drogues Sante Societe. 2007;6(Suppl 2):1-26.
50 Grenard JL, Ames SL, Pentz MA, et al. Motivational interviewing with adolescents and young adults for drug-related problems. Int J Adolesc Med Health. 2006;18(1):53-67. [pmid: 16639859].
51 Heckman CJ, Egleston BL, Hofmann MT. Efficacy of motivational interviewing for smoking cessation: a systematic review and meta-analysis. Tob Control. 2010;19(5):410-6. [pmid: 20675688].
52 Hutton HE, Wilson LM, Apelberg BJ, et al. A systematic review of randomized controlled trials: web-based interventions for smoking cessation among adolescents, college students, and adults. Nicotine Tob Res. 2011;13(4):227-38. [pmid: 21350042].
53 Kim Y, Myung SK, Jeon YJ, et al. Effectiveness of pharmacologic therapy for smoking cessation in adolescent smokers: meta-analysis of randomized controlled trials. Am J Health Syst Pharm. 2011;68(3):219-26. [pmid: 21258027].
54 McDonald P, Colwell B, Backinger CL, et al. Better practices for youth tobacco cessation: evidence of review panel. Am J Health Behav. 2003;27(Suppl 2):S144-58. [pmid: 14521242].
55 Myung SK, McDonnell DD, Kazinets G, et al. Effects of web- and computer-based smoking cessation programs. Arch Intern Med. 2009;169(10):929-37. [pmid: 19468084].
56 Rooke S, Thorsteinsson E, Karpin A, et al. Computer-delivered interventions for alcohol and tobacco use: a meta-analysis. Addiction. 2010;105(8):1381-90. [pmid: 20528806].
57 Schepis TS, Rao U. Smoking cessation for adolescents: a review of pharmacological and psychosocial treatments. Curr Drug Abuse Rev. 2008;1(2):142-55. [pmid: 19630713].
58 Sussman S, Lichtman K, Ritt A, et al. Effects of thirty-four adolescent tobacco use cessation and prevention trials on regular users of tobacco products. Subst Use Misuse. 1999;34(11):1469-503. [pmid: 10468104].
59 Sussman S. Effects of sixty six adolescent tobacco use cessation trials and seventeen prospective studies of self-initiated quitting. Tob Induc Dis. 2002;1(1):35-81. [pmid: 19570247].
60 Sussman S, Sun P, Dent CW. A meta-analysis of teen cigarette smoking cessation. Health Psychol. 2006;25(5):549-57. [pmid: 17014271].
61 Sussman S, Sun P. Youth tobacco use cessation: 2008 update. Tob Induc Dis. 2009;5:3. [pmid: 19183452].
62 Warnakulasuriya S. Effectiveness of tobacco counseling in the dental office. J Dent Educ. 2002;66(9):1079-87. [pmid: 12374269].
63 Fiore M. A clinical practice guideline for treating tobacco use and dependence: 2008 update. Am J Prev Med. 2008;35(2):158-76. [pmid: 18617085].
64 U.S. Food and Drug Administration. Public Health Advisory: FDA Requires New Boxed Warnings for the Smoking Cessation Drugs Chantix and Zyban. Rockville, MD. U.S. Food and Drug Administration. 2009. Accessed at http://www.fda.gov/Drugs/DrugSafety/PostmarketDrugSafetyInformationforPatientsandProviders/DrugSafetyInformationforHeathcareProfessionals/PublicHealthAdvisories/ucm169988.htm on. 30 November 2012.
65 Shelley D, Cantrell J, Faulkner D, et al. Physician and dentist tobacco use counseling and adolescent smoking behavior: results from the 2000 National Youth Tobacco Survey. Pediatrics. 2005;115(3):719-25. [pmid: 15741377].
66 Centers for Disease Control and Prevention. 2009 National Youth Tobacco Survey: Dataset, Format Library, and Codebook. Atlanta. Centers for Disease Control and Prevention. 2011. Accessed at http://www.cdc.gov/tobacco/data_statistics/surveys/nyts/index.htm on. 30 November 2012.
67 Alfano CM, Zbikowski SM, Robinson LA, et al. Adolescent reports of physician counseling for smoking. Pediatrics. 2002;109(3):e47. [pmid: 11875175].
68 Price JH, Jordan TR, Dake JA. Pediatricians' use of the 5 A's and nicotine replacement therapy with adolescent smokers. J Community Health. 2007;32(2):85-101. [pmid: 17571523].
69 Malarcher A, Easton A, Husten C, et al. Smoking cessation counseling: training and practice among women pediatricians. Clin Pediatr (Phila). 2002;41(5):341-9. [pmid: 12086200].
70 Committee on Environmental Health, Committee on Substance Abuse, Committee on Adolescence, Committee on Native American Child Health. From the American Academy of Pediatrics: policy statement—tobacco use: a pediatric disease. Pediatrics. 2009;124(5):1474-87. [pmid: 19841108].
71 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. Agency for Healthcare Quality and Research. 2011. Accessed at http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm on. 30 November 2012.
72 U.S. Department of Health and Human Services Public Health Service. Treating Tobacco Use and Dependence: 2008 Update. Washington, DC. U.S. Department of Health and Human Services. 2008. Accessed at http://www.ncbi.nlm.nih.gov/books/NBK63952/ on. 30 November 2012.
73 Christakis DA, Garrison MM, Ebel BE, et al. Pediatric smoking prevention interventions delivered by care providers: a systematic review. Am J Prev Med. 2003;25(4):358-62. [pmid: 14580640].
74 Civljak M, Sheikh A, Stead LF, et al. Internet-based interventions for smoking cessation. Cochrane Database Syst Rev. 2010;(9):CD007078. [pmid: 20824856].
75 Hopkins DP, Briss PA, Ricard CJ, et al. Reviews of evidence regarding interventions to reduce tobacco use and exposure to environmental tobacco smoke. Am J Prev Med. 2001;20(2 Suppl):16-66. [pmid: 11173215].
76 Muller-Riemenschneider F, Bockelbrink A, Reinhold T, et al. Long-term effectiveness of behavioural interventions to prevent smoking among children and youth. Tob Control. 2008;17(5):301-2. [pmid: 18522963].
77 Petrie J, Bunn F, Byrne G. Parenting programmes for preventing tobacco, alcohol or drugs misuse in children <18: a systematic review. Health Educ Res. 2007;22(2):177-91. [pmid: 16857779].
78 Skara S, Sussman S. A review of 25 long-term adolescent tobacco and other drug use prevention program evaluations. Prev Med. 2003;37(5):451-74. [pmid: 14572430].
79 Pbert L, Flint AJ, Fletcher KE, et al. Effect of a pediatric practice-based smoking prevention and cessation intervention for adolescents: a randomized, controlled trial. Pediatrics. 2008;121(4):e738-47. [pmid: 18381502].
80 Pbert L, Druker S, DiFranza JR, et al. Effectiveness of a school nurse-delivered smoking-cessation intervention for adolescents. Pediatrics. 2011;128(5):926-36. [pmid: 22007015].
81 Hovell MF, Slymen DJ, Jones JA, et al. An adolescent tobacco-use prevention trial in orthodontic offices. Am J Public Health. 1996;86(12):1760-6. [pmid: 9003134].
82 Higgins JP, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. Oxford, England. The Cochrane Collaboration. 2011. Accessed at http://handbook.cochrane.org/ on. 30 November 2012.
83 Murray DM, Short BJ. Intraclass correlation among measures related to tobacco use by adolescents: estimates, correlates, and applications in intervention studies. Addict Behav. 1997;22(1):1-12. [pmid: 9022867].
84 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
85 Ausems M, Mesters I, van Breukelen G, et al. Short-term effects of a randomized computer-based out-of-school smoking prevention trial aimed at elementary schoolchildren. Prev Med. 2002;34(6):581-9. [pmid: 12052017].
86 Bauman KE, Ennett ST, Foshee VA, et al. Influence of a family program on adolescent smoking and drinking prevalence. Prev Sci. 2002;3(1):35-42. [pmid: 12002557].
87 Colby SM, Monti PM, O'Leary TT, et al. Brief motivational intervention for adolescent smokers in medical settings. Addict Behav. 2005;30(5):865-74. [pmid: 15893085].
88 Fidler W, Lambert TW. A prescription for health: a primary care based intervention to maintain the non-smoking status of young people. Tob Control. 2001;10(1):23-6. [pmid: 11226356].
89 Gray KM, Carpenter MJ, Baker NL, et al. Bupropion SR and contingency management for adolescent smoking cessation. J Subst Abuse Treat. 2011;40(1):77-86. [pmid: 20934835].
90 Haggerty KP, Skinner ML, MacKenzie EP, et al. A randomized trial of parents who care: effects on key outcomes at 24-month follow-up. Prev Sci. 2007;8(4):249-60. [pmid: 17987388].
91 Hollis JF, Polen MR, Whitlock EP, et al. Teen reach: outcomes from a randomized, controlled trial of a tobacco reduction program for teens seen in primary medical care. Pediatrics. 2005;115(4):981-9. [pmid: 15805374].
92 Jackson C, Dickinson D. Enabling parents who smoke to prevent their children from initiating smoking: results from a 3-year intervention evaluation. Arch Pediatr Adolesc Med. 2006;160(1):56-62. [pmid: 16389212].
93 Kentala J, Utriainen P, Pahkala K, et al. Can brief intervention through community dental care have an effect on adolescent smoking?. Prev Med. 1999;29(2):107-11. [pmid: 10446036].
94 Killen JD, Robinson TN, Ammerman S, et al. Randomized clinical trial of the efficacy of bupropion combined with nicotine patch in the treatment of adolescent smokers. J Consult Clin Psychol. 2004;72(4):729-35. [pmid: 15301658].
95 Lando HA, Hennrikus D, Boyle R, et al. Promoting tobacco abstinence among older adolescents in dental clinics. J Smok Cessat. 2007;2(1):23-30.
96 Muramoto ML, Leischow SJ, Sherrill D, et al. Randomized, double-blind, placebo-controlled trial of 2 dosages of sustained-release bupropion for adolescent smoking cessation. Arch Pediatr Adolesc Med. 2007;161(11):1068-74. [pmid: 17984409].
97 Prado G, Pantin H, Briones E, et al. A randomized controlled trial of a parent-centered intervention in preventing substance use and HIV risk behaviors in Hispanic adolescents. J Consult Clin Psychol. 2007;75(6):914-26. [pmid: 18085908].
98 Stevens MM, Olson AL, Gaffney CA, et al. A pediatric, practice-based, randomized trial of drinking and smoking prevention and bicycle helmet, gun, and seatbelt safety promotion. Pediatrics. 2002;109(3):490-7. [pmid: 11875146].
99 Bauman KE, Ennett ST, Foshee VA, et al. Influence of a family-directed program on adolescent cigarette and alcohol cessation. Prev Sci. 2000;1(4):227-37. [pmid: 11523750].
100 Bauman KE, Foshee VA, Ennett ST, et al. The influence of a family program on adolescent tobacco and alcohol use. Am J Public Health. 2001;91(4):604-10. [pmid: 11291373].
101 Huang M, Hollis J, Polen M, et al. Stages of smoking acquisition versus susceptibility as predictors of smoking initiation in adolescents in primary care. J Smok Cessat. 2005;30(6):1183-94.
102 Jackson C, Dickinson D. Can parents who smoke socialise their children against smoking? Results from the Smoke-free Kids intervention trial. Tob Control. 2003;12(1):52-9. [pmid: 12612363].
103 Jaszyna-Gasior M, Schroeder JR, Moolchan ET. Alcohol use and tobacco abstinence among adolescents in cessation treatment: preliminary findings. Addict Behav. 2007;32(3):617-21. [pmid: 16814935].
104 Colby SM, Nargiso J, Tevyaw TO, et al. Enhanced motivational interviewing versus brief advice for adolescent smoking cessation: results from a randomized clinical trial. J Smok Cessat. 2012;37(7):817-23.
105 Thomas R, Perera R. School-based programmes for preventing smoking. Cochrane Database Syst Rev. 2006;(3):CD001293. [pmid: 16855966].
106 Hanson K, Allen S, Jensen S, et al. Treatment of adolescent smokers with the nicotine patch. Nicotine Tob Res. 2003;5(4):515-26. [pmid: 12959789].
107 Kang HC, Shin KK, Kim KK, et al. The effects of the acupuncture treatment for smoking cessation in high school student smokers. Yonsei Med J. 2005;46(2):206-12. [pmid: 15861492].
108 Yiming C, Changxin Z, Ung WS, et al. Laser acupuncture for adolescent smokers: a randomized double-blind controlled trial. Am J Chin Med. 2000;28(3-4):443-9. [pmid: 11154059].
109 White AR, Rampes H, Campbell JL. Acupuncture and related interventions for smoking cessation. Cochrane Database Syst Rev. 2006;(1):CD000009. [pmid: 16437420].
110 Chassin L, Presson C, Rose J, et al. Parental smoking cessation and adolescent smoking. J Pediatr Psychol. 2002;27(6):485-96. [pmid: 12177249].
111 Farkas AJ, Distefan JM, Choi WS, et al. Does parental smoking cessation discourage adolescent smoking?. Prev Med. 1999;28(3):213-8. [pmid: 10072737].
112 Rosen LJ, Noach MB, Winickoff JP, et al. Parental smoking cessation to protect young children: a systematic review and meta-analysis. Pediatrics. 2012;129(1):141-52. [pmid: 22201152].
113 Curry SJ, Ludman EJ, Graham E, et al. Pediatric-based smoking cessation intervention for low-income women: a randomized trial. Arch Pediatr Adolesc Med. 2003;157(3):295-302. [pmid: 12622686].
114 Kandel DB, Hu MC, Griesler PC, et al. On the development of nicotine dependence in adolescence. Drug Alcohol Depend. 2007;91(1):26-39. [pmid: 17553635].
115 Pallonen UE, Prochaska JO, Velicer WF, et al. Stages of acquisition and cessation for adolescent smoking: an empirical integration. Addict Behav. 1998;23(3):303-24. [pmid: 9668929].
116 Escobedo LG, Marcus SE, Holtzman D, et al. Sports participation, age at smoking initiation, and the risk of smoking among US high school students. JAMA. 1993;269(11):1391-5. [pmid: 8441214].
117 National Institutes of Health. Estimates of Funding for Various Research, Condition, and Disease Categories. Bethesda, MD. National Institutes of Health. 2011. Accessed at http://report.nih.gov/categorical_spending.aspx on. 30 November 2012.
118 Wakefield MA, Chaloupka FJ, Kaufman NJ, et al. Effect of restrictions on smoking at home, at school, and in public places on teenage smoking: cross sectional study. BMJ. 2000;321(7257):333-7. [pmid: 10926588].
119 Kellam SG, Brown CH, Poduska JM, et al. Effects of a universal classroom behavior management program in first and second grades on young adult behavioral, psychiatric, and social outcomes. Drug Alcohol Depend. 2008;95(Suppl 1):S5-28. [pmid: 18343607].
120 Abroms LC, Padmanabhan N, Thaweethai L, et al. iPhone apps for smoking cessation: a content analysis. Am J Prev Med. 2011;40(3):279-85. [pmid: 21335258].
121 Abroms LC, Windsor R, Simons-Morton B. Getting young adults to quit smoking: a formative evaluation of the X-Pack Program. Nicotine Tob Res. 2008;10(1):27-33. [pmid: 18188742].
122 Strecher VJ, Shiffman S, West R. Randomized controlled trial of a web-based computer-tailored smoking cessation program as a supplement to nicotine patch therapy. Addiction. 2005;100(5):682-8. [pmid: 15847626].
123 Adelman WP, Duggan AK, Hauptman P, et al. Effectiveness of a high school smoking cessation program. Pediatrics. 2001;107(4):e50. [pmid: 11335771].
124 Ary DV, Biglan A, Glasgow R, et al. The efficacy of social-influence prevention programs versus “standard care”: are new initiatives needed?. J Behav Med. 1990;13(3):281-96. [pmid: 2213870].
125 Audrey S, Holliday J, Campbell R. It's good to talk: adolescent perspectives of an informal, peer-led intervention to reduce smoking. Soc Sci Med. 2006;63(2):320-34. [pmid: 16459004].
126 Aveyard P, Sherratt E, Almond J, et al. The change-in-stage and updated smoking status results from a cluster-randomized trial of smoking prevention and cessation using the transtheoretical model among British adolescents. Prev Med. 2001;33(4):313-24. [pmid: 11570836].
127 Baskerville B, Hotte A, Dunkley G. Evaluation of a High School Quit and Win Smoking Cessation Program. Ottawa, Ontario. University of Ottawa. 1993.
128 Beaglehole R, Brough D, Harding W, et al. A controlled smoking intervention programme in secondary schools. N Z Med J. 1978;87(610):278-80. [pmid: 275656].
129 Biglan A, Glasgow R, Ary D, et al. How generalizable are the effects of smoking prevention programs? Refusal skills training and parent messages in a teacher-administered program. J Behav Med. 1987;10(6):613-28. [pmid: 3437450].
130 Bloor M, Frankland J, Langdon NP, et al. A controlled evaluation of an intensive, peer-led, schools-based, anti-smoking programme. Health Educ J. 1999;58(1):17-25.
131 Brown RA, Ramsey SE, Strong DR, et al. Effects of motivational interviewing on smoking cessation in adolescents with psychiatric disorders. Tob Control. 2003;12(Suppl 4):3-10. [pmid: 12612347].
132 Chan CW, Witherspoon JM. Health risk appraisal modifies cigarette smoking behavior among college students. J Gen Intern Med. 1988;3(6):555-9. [pmid: 3230458].
133 Charlton A. Smoking cessation help for young people: the process observed in two case studies. Health Educ Res. 1992;7(2):249-57.
134 Cinnomin D, Sussman S. Unpublished study. Sussman S, Dent CW, Burton D, et al., editors. Developing School Based Tobacco Use Prevention and Cessation Programs. Thousand Oaks, CA. Sage Publications. 1995.
135 Coleman-Wallace D, Lee JW, Montgomery S, et al. Evaluation of developmentally appropriate programs for adolescent tobacco cessation. J Sch Health. 1999;69(8):314-9. [pmid: 10544364].
136 Connell AM, Dishion TJ, Yasui M, et al. An adaptive approach to family intervention: linking engagement in family-centered intervention to reductions in adolescent problem behavior. J Consult Clin Psychol. 2007;75(4):568-79. [pmid: 17663611].
137 Cullen KJ, Cullen AM. Long-term follow-up of the Busselton six-year controlled trial of prevention of children's behavior disorders. J Pediatr. 1996;129(1):136-9. [pmid: 8757573].
138 DiGuisto E. Pros and cons of cessation interventions for adolescent smokers at school. Richmond R, editor. Interventions for Smokers: An International Perspective. Baltimore. Williams & Wilkins. 1994.
139 Dino GA, Horn KA, Meit H. A pilot study of Not On Tobacco: a stop smoking programme for adolescents. Health Educ. 1998;98(6):230-41.
140 Dino G, Horn K, Goldcamp J, et al. A 2-year efficacy study of Not On Tobacco in Florida: an overview of program successes in changing teen smoking behavior. Prev Med. 2001;33(6):600-5. [pmid: 11716656].
141 Dino GA, Horn KA, Goldcamp J, et al. Statewide demonstration of Not On Tobacco: a gender-sensitive teen smoking cessation program. J Sch Nurs. 2001;17(2):90-7. [pmid: 11885118].
142 Dishion TJ, Andrews DW. Preventing escalation in problem behaviors with high-risk young adolescents: immediate and 1-year outcomes. J Consult Clin Psychol. 1995;63(4):538-48. [pmid: 7673531].
143 Elder JP, Perry CL, Stone EJ, et al. Tobacco use measurement, prediction, and intervention in elementary schools in four states: the CATCH Study. Prev Med. 1996;25(4):486-94. [pmid: 8812826].
144 Etter JF, Ronchi A, Perneger T. Short-term impact of a university based smoke free campaign. J Epidemiol Community Health. 1999;53(11):710-5. [pmid: 10656100].
145 Forman SG, Linney JA, Brondino MJ. Effects of coping skills training on adolescents at risk for substance use. Psychol Addict Behav. 1990;4(2):67-76.
146 Forster JL, Murray DM, Wolfson M, et al. The effects of community policies to reduce youth access to tobacco. Am J Public Health. 1998;88(8):1193-8. [pmid: 9702146].
147 Glasgow RE, Strycker LA, Eakin EG, et al. Concern about weight gain associated with quitting smoking: prevalence and association with outcome in a sample of young female smokers. J Consult Clin Psychol. 1999;67(6):1009-11. [pmid: 10596524].
148 Greenberg JS, Deputat Z. Smoking intervention: comparing three methods in a high school setting. J Sch Health. 1978;48(8):498-502. [pmid: 250596].
149 Hamilton G, Cross D, Resnicow K, et al. A school-based harm minimization smoking intervention trial: outcome results. Addiction. 2005;100(5):689-700. [pmid: 15847627].
150 Hancock L, Sanson-Fisher R, Perkins J, et al. The effect of a community action intervention on adolescent smoking rates in rural Australian towns: the CART Project. Prev Med. 2001;32(4):332-40. [pmid: 11304094].
151 Hoffman J, Nemes S, Weil J, et al. Evaluation of the ASCENT smoking cessation program for adolescents. J Smok Cessat. 2008;3(1):2-8.
152 Horn K, Dino G, Gao X, et al. Feasibility evaluation of Not On Tobacco: the American Lung Association's new stop smoking programme for adolescents. Health Educ. 1999;99(5):192-207.
153 Horn KA, Dino GA, Kalsekar ID, et al. Appalachian teen smokers: Not On Tobacco 15 months later. Am J Public Health. 2004;94(2):181-4. [pmid: 14759924].
154 Horn K, Dino G, Kalsekar I, et al. The impact of Not on Tobacco on teen smoking cessation. J Adolesc Res. 2005;20(6):640-61.
155 Horn K, McGloin T, Dino G, et al. Quit and reduction rates for a pilot study of the American Indian Not On Tobacco (N-O-T) program. Prev Chronic Dis. 2005;2(4):a13. [pmid: 16164817].
156 Horn K, Dino G, Hamilton C, et al. Efficacy of an emergency department-based motivational teenage smoking intervention. Prev Chronic Dis. 2007;4(1):a08. [pmid: 17173716].
157 Horswell L, Horton S. Telling Our Story: “PITS”—Pack In Those Smokes: A Team Support Group Quit Smoking Program. A report presented to the Community Action Initiatives Program, Tobacco Demand Reduction Strategy. Ottawa, Ontario. Health Canada. 1997.
158 Hotte A, Ellis E, Lindsay L, et al. Dissemination and Evaluation of the Quit-4-Life Cessation Program for Teenagers in Ottawa-Carleton High Schools. A report presented to the Community Action Initiatives Program, Tobacco Demand Reduction Strategy. Ottawa, Ontario. Health Canada. 1997.
159 Jason LA, Mollica M, Ferrone L. Evaluating an early secondary smoking prevention intervention. Prev Med. 1982;11(1):96-102. [pmid: 7079250].
160 Josendal O, Aaro LE, Bergh IH. Effects of a school-based smoking prevention program among subgroups of adolescents. Health Educ Res. 1998;13(2):215-24. [pmid: 10181020].
161 Kelly AB, Lapworth K. The HYP program: targeted motivational interviewing for adolescent violations of school tobacco policy. Prev Med. 2006;43(6):466-71. [pmid: 16920183].
162 Killen JD, Telch MJ, Robinson TN, et al. Cardiovascular disease risk reduction for tenth graders: a multiple-factor school-based approach. JAMA. 1988;260(12):1728-33. [pmid: 3411756].
163 Schoenberger Y, Kohler C, Kawamura Y. Relationship between session attendance and smoking related variables in students attending a smoking cessation program. Paper presented at: 11th Annual Meeting of the Society for Research on Nicotine and Tobacco. March 2005. Prague.
164 Knutsen SF, Knutsen R. The Tromso Survey: the family intervention study—the effect of intervention on some coronary risk factors and dietary habits, a 6-year follow-up. Prev Med. 1991;20(2):197-212. [pmid: 2057468].
165 Kohler CL, Schoenberger YM, Beasley TM, et al. Effectiveness evaluation of the N-O-T smoking cessation program for adolescents. Am J Health Behav. 2008;32(4):368-79. [pmid: 18092897].
166 Lazovich D, Ford J, Forster J, et al. A pilot study to evaluate a tobacco diversion program. Am J Public Health. 2001;91(11):1790-1. [pmid: 11684602].
167 Lipkus IM, McBride CM, Pollak KI, et al. A randomized trial comparing the effects of self-help materials and proactive telephone counseling on teen smoking cessation. Health Psychol. 2004;23(4):397-406. [pmid: 15264976].
168 Lotecka L, MacWhinney M. Enhancing decision behavior in high school “smokers”. Int J Addict. 1983;18(4):479-90. [pmid: 6629558].
169 Moolchan ET, Robinson ML, Ernst M, et al. Safety and efficacy of the nicotine patch and gum for the treatment of adolescent tobacco addiction. Pediatrics. 2005;115(4):e407-14. [pmid: 15805342].
170 Murray DM, Prokhorov A, Harty KC. Effects of a statewide antismoking campaign on mass media messages and smoking beliefs. Prev Med. 1994;23(1):54-60. [pmid: 8016033].
171 Myers MG, Brown SA. A controlled study of a cigarette smoking cessation intervention for adolescents in substance abuse treatment. Psychol Addict Behav. 2005;19(2):230-3. [pmid: 16011397].
172 Nutbeam D, Macaskill P, Smith C, et al. Evaluation of two school smoking education programmes under normal classroom conditions. BMJ. 1993;306(6870):102-7. [pmid: 8435601].
173 Olds D, Henderson CR Jr, Cole R, et al. Long-term effects of nurse home visitation on children's criminal and antisocial behavior: 15-year follow-up of a randomized controlled trial. JAMA. 1998;280(14):1238-44. [pmid: 9786373].
174 Patten CA, Croghan IT, Meis TM, et al. Randomized clinical trial of an Internet-based versus brief office intervention for adolescent smoking cessation. Patient Educ Couns. 2006;64(1-3):249-58. [pmid: 16616449].
175 Pbert L, Osganian SK, Gorak D, et al. A school nurse-delivered adolescent smoking cessation intervention: a randomized controlled trial. Prev Med. 2006;43(4):312-20. [pmid: 16828858].
176 Perry C, Killen J, Telch M, et al. Modifying smoking behavior of teenagers: a school-based intervention. Am J Public Health. 1980;70(7):722-5. [pmid: 7386709].
177 Peterson AJ, Clark AW. Using group decision to reduce adolescent girls' smoking. Psychol Rep. 1986;58(1):179-85. [pmid: 3961060].
178 Peterson AV Jr, Kealey KA, Mann SL, et al. Group-randomized trial of a proactive, personalized telephone counseling intervention for adolescent smoking cessation. J Natl Cancer Inst. 2009;101(20):1378-92. [pmid: 19822836].
179 Quinlan KB, McCaul KD. Matched and mismatched interventions with young adult smokers: testing a stage theory. Health Psychol. 2000;19(2):165-71. [pmid: 10762100].
180 Reddy KS, Arora M, Perry CL, et al. Tobacco and alcohol use outcomes of a school-based intervention in New Delhi. Am J Health Behav. 2002;26(3):173-81. [pmid: 12018753].
181 Rigotti NA, DiFranza JR, Chang Y, et al. The effect of enforcing tobacco-sales laws on adolescents' access to tobacco and smoking behavior. N Engl J Med. 1997;337(15):1044-51. [pmid: 9321533].
182 Robinson LA, Vander Weg MW, Riedel BW, et al. “Start to stop”: results of a randomised controlled trial of a smoking cessation programme for teens. Tob Control. 2003;12(Suppl 4):26-33.
183 Rodgers A, Corbett T, Bramley D, et al. Do u smoke after txt? Results of a randomised trial of smoking cessation using mobile phone text messaging. Tob Control. 2005;14(4):255-61. [pmid: 16046689].
184 Salminen M, Vahlberg T, Ojanlatva A, et al. Effects of a controlled family-based health education/counseling intervention. Am J Health Behav. 2005;29(5):395-406. [pmid: 16201856].
185 Schinke SP, Schwinn TM, Di Noia J, et al. Reducing the risks of alcohol use among urban youth: three-year effects of a computer-based intervention with and without parent involvement. J Stud Alcohol. 2004;65(4):443-9. [pmid: 15376818].
186 Sherbot NA. The use of motivational enhancement therapy and the Quit 4 Life program as a means to facilitate adolescent smoking cessation. Dissert Abstr Int B Sci Eng. 2005;66(1-B):574.
187 Spoth RL, Redmond C, Shin C. Randomized trial of brief family interventions for general populations: adolescent substance use outcomes 4 years following baseline. J Consult Clin Psychol. 2001;69(4):627-42. [pmid: 11550729].
188 Spoth RL, Redmond C, Trudeau L, et al. Longitudinal substance initiation outcomes for a universal preventive intervention combining family and school programs. Psychol Addict Behav. 2002;16(2):129-34. [pmid: 12079251].
189 Stoddard AM, Fagan P, Sorensen G, et al. Reducing cigarette smoking among working adolescents: results from the SMART study. Cancer Causes Control. 2005;16(10):1159-64. [pmid: 16215865].
190 Storr CL, Ialongo NS, Kellam SG, et al. A randomized controlled trial of two primary school intervention strategies to prevent early onset tobacco smoking. Drug Alcohol Depend. 2002;66(1):51-60. [pmid: 11850136].
191 Suedfeld P, Landon PB, Pargament R, et al. An experimental attack on smoking. (Attitude manipulation in restricted environments, 3). Int J Addict. 1972;7(4):721-33. [pmid: 4659594].
192 Sussman S, Dent C, Burton D, et al., editors. Developing School-Based Tobacco Use Prevention and Cessation Programs. Thousand Oaks, CA. Sage Publications. 1995.
193 Sussman S, Dent CW, Lichtman KL. Project EX: outcomes of a teen smoking cessation program. Addict Behav. 2001;26(3):425-38. [pmid: 11436934].
194 Sussman S, Dent CW, Stacy AW. Project towards no drug abuse: a review of the findings and future directions. Am J Health Behav. 2002;26(5):354-65. [pmid: 12206445].
195 Sussman S, Miyano J, Rohrbach LA, et al. Six-month and one-year effects of project EX-4: a classroom-based smoking prevention and cessation intervention program. Addict Behav. 2007;32(12):3005-14. [pmid: 17628346].
196 Winkleby MA, Feighery E, Dunn M, et al. Effects of an advocacy intervention to reduce smoking among teenagers. Arch Pediatr Adolesc Med. 2004;158(3):269-75. [pmid: 14993087].
197 Woodruff SI, Conway TL, Edwards CC, et al. Evaluation of an Internet virtual world chat room for adolescent smoking cessation. Addict Behav. 2007;32(9):1769-86. [pmid: 17250972].
198 Wu Y, Stanton BF, Galbraith J, et al. Sustaining and broadening intervention impact: a longitudinal randomized trial of 3 adolescent risk reduction approaches. Pediatrics. 2003;111(1):e32-8. [pmid: 12509592].
199 Zack SL, Hoffman J, Nemes S, et al. Participation in a successful and multifaceted teen cessation program. Paper presented at: 2005 National Conference on Tobacco or Health. May 2005. Chicago.
200 Zavela KJ, Harrison LR, Owens S. Factors related to smokeless tobacco cessation in young adults. Poster presented at: 119th Meeting of the American Public Health Association. November 1991. Atlanta.
201 Zheng H, Sussman S, Chen X, et al. Project EX: a teen smoking cessation initial study in Wuhan, China. Addict Behav. 2004;29(9):1725-33. [pmid: 15530717].