# RESULTS

We identified 19 trials examining the effects and harms of interventions designed to prevent the initiation of tobacco use and/or promote cessation among children and adolescents.11,79-81,85-98 These trials' results were reported in 24 publications.11,79-81,85-104 All of the trials were considered primary care relevant interventions, as they were conducted in primary care or were judged to be feasible for or applicable to primary care. Seven trials examined interventions that included both prevention and cessation (hereafter referred to as “combined” trials),79,86,91,93,95,97,98 six additional trials only examined the benefits of prevention interventions among baseline nonsmokers,11,81,85, 88,90,92 and five additional trials examined the benefits of cessation interventions among baseline smokers.80,87,94,96,104 Two of the cessation studies included a medication-based intervention.94,96 Of the seven combined trials that included both smokers and nonsmokers, four reported the effect of the intervention among baseline nonsmokers and smokers separately and are discussed in the “Prevention” and “Cessation” sections below.79,86,91,95,99,100 Table 3 displays the overall structure of the trials as defined by their intervention focus. Table 4 presents study characteristics of all of the included studies.

Table 3 Included Studies by Group/Primary Outcome

Trial | Combined | Prevention | Cessation (Behavior) | Cessation (Bupropion)
Trial | Prevalence | Initiation | Cessation | Cessation
Ausems 2002^85^ | | X
Bauman 2002^86^ | X | X | X
Colby 2005^87^ | | | X
Colby 2012^104^ | | | X
Curry 2003^11^ | | X
Fidler 2001^88^ | | X
Gray 2011^89^ | | | | X
Haggerty 2007^90^ | | X
Hollis 2005^91^ | X | X | X
Hovell 1996^81^ | | X
Kentala 1999^93^ | X
Killen 2004^94^ | | | | X
Jackson 2006^92^ | | X
Lando 2007^95^ | X | X | X
Muramoto 2007^96^ | | | | X
Pbert 2008^79^ | X | X | X
Pbert 2011^80^ | | | X
Prado 2007^97^ | X
Stevens 2002^98^ | X
Total Number of Studies | 7 | 10 | 7 | 3

Table 4 Study Characteristics of Included Trials

Trial, Quality Rating | Focus | Location, Intervention Setting | IG N^*^ | CG N^*^ | Months to Followup | % Followup | Age Range (Mean), Years | % Female | % Nonwhite
Bauman 2002^86^ Fair | Combined, Prevention, Cessation | U.S., home | 658 | 658 | 7^‡^, 16 | 81.2 | 12–14 (13.9) | 50.7 | 26.6
Hollis 2005^91^ Good | Combined, Prevention, Cessation | U.S., medical office | 1254 | 1272 | 12^‡^, 24 | 93.7 | 14–17 (15.4) | 59.2 | 21.8
Kentala 1999^93^ Fair | Combined | Finland, dental clinic | 1348 | 1238 | 12^‡^, 24 | 84.2 | NR (13.1) | 49.0 | NR
Lando 2007^95^ Fair | Combined, Prevention, Cessation | U.S., dental clinic | 175 | 169 | 12 | 65.4 | 14–17 (15.4) | 52.0 | 19.0
Pbert 2008^79^ Fair | Combined, Prevention, Cessation | U.S., pediatric clinic | 1346 | 1365 | 6, 12^‡^ | 99.2 | 13–17 (16.9) | 54.1 | 8.6
Prado 2007^97^ Fair | Combined | U.S., home and community | 91 | 84 | 12^‡^, 24, 36 | 88.0 | NR (13.4) | 53.7 | 100
Stevens 2002#98 Good | Combined | U.S., pediatric office | 1780 | 1331 | 12^‡^, 24, 36 | 95.5 | NR (11.0) | 48.3 | NR
Ausems 2002#85 Fair | Prevention | The Netherlands, home | 871 | 793 | 6 | 91.5 | NR (11.7) | 50.6 | NR
Curry 2003^11^ Fair | Prevention | U.S., home (optional primary care) | 2020 | 2006 | 20 | 88.5 | 10–12 (11.0) | 52.0 | NR
Fidler 2001^88^ Fair | Prevention | United Kingdom, home | 1456 | 1486 | 12 | 75.3 | 10–15 (NR) | 55.3 | NR
Haggerty 2007^90^ Fair | Prevention | U.S., home (IG1), after school (IG2)^†^ | IG1: 107 IG2: 118^†^ | 83 | 12^‡^, 24 | 92.5 | NR (13.7) | 48.6 | 50.8
Hovell 1996^81^ Good | Prevention | U.S., orthodontic office | 7149 | 7626 | 24 | 92.5 | 11–19 (14.4) | 54.0 | 27.0
Jackson 2006^92^ Fair | Prevention | U.S., home | 426 | 447 | 36 | 87.5 | 7–8 (NR) | 52.6 | 23.7
Colby 2005^87^ Fair | Cessation | U.S., NR | 43 | 42 | 6 | 80.0 | 12–19 (16.3) | 61.0 | 45.0
Colby 2012^104^ Fair | Cessation | U.S., NR | 79 | 83 | 6 | 81.5 | 14-18 (16.2) | 47.5 | 27.8
Pbert 2011^80^ Good | Cessation | U.S., school health clinic | 486 | 582 | 12 | 88.4 | NR (16.9) | 47.7 | 7.4
Killen 2004^94^ Fair | Cessation (medication) | US, NR | 103 | 108 | 6 | 63.5 | 15–18 (17.3) | 31.3 | 49.8
Muramoto 2007^96^ Fair | Cessation (medication) | U.S., research clinic | IG1: 105^†^ IG2: 104 | 103 | 6 | 61.9 | 14–17 (16.0) | 45.8 | 26.0

* Randomized.

† Intervention group utilized in the meta-analysis.

‡ Data from this followup point used.

§ Calculated based on presented data.

∥ Calculated based on data requested from the author.

¶ Includes “experimenters,” smokers, and recent quitters/former smokers.

# Study not included in meta-analysis.

Abbreviations: CG = control group; IG = intervention group; N = number; NR = not reported; U.S. = United States.

## Key Question 1 Do Interventions in Primary Care Designed to Prevent Tobacco Use or Improve Tobacco Cessation Rates in Children and Adolescents Improve Health Outcomes in Children and Adolescents and Reduce the Likelihood of Adult Smoking?

We identified no primary care relevant trials designed to prevent tobacco use or improve tobacco cessation rates that assessed health outcomes in children and adolescents or examined subsequent rates of adult smoking. None of the included studies assessed the intervention's impact on other potential positive outcomes (e.g., improved mental health, reduced alcohol and drug use). We do not discuss outcomes that are primarily psychosocial mediators of behavior (e.g., beliefs, motivation to quit, parent-child communication, perception of peer smoking), although these measures were reported in many of our included studies.

## Key Question 2 Do Interventions in Primary Care Prevent Tobacco Use in Children and Adolescents or Improve Tobacco Cessation Rates in Children and Adolescents Who Use Tobacco? What Are Elements of Efficacious Interventions? Are There Differences in Outcomes in Different Subgroups?

### Combined Prevention and Cessation Interventions

General characteristics of the trials. Seven trials included both nonsmokers and smokers at baseline and therefore were considered combined primary prevention and cessation intervention (n=12,769 randomized).79,86,91,93,95,97,98 The majority of the trials were conducted in the United States, with one trial conducted in Finland.93 Five of the studies were individual randomized, controlled trials (RCTs),86,91,93,95,97 whereas the remaining two were cluster randomized trials (CRTs) with randomization of pediatric practices.79,98

Intervention approaches, settings, intensities, and components were very heterogeneous across these studies (Table 5 and Appendix G). Four of the trials79,91,93,95 targeted their intervention messages to the youths' baseline smoking status (i.e., nonsmokers vs. smokers), while the remaining three trials implemented the same intervention with all youth regardless of whether they were nonsmokers or smokers at baseline.86,97,98 These three trials were also the only trials in this group that targeted additional behaviors beyond tobacco use, including alcohol and other substance use,86,98 unsafe sexual behaviors, and parental involvement.97 Two of these interventions86,97 generally focused on messages regarding parent-child communication and family management skills (e.g., monitoring, limit setting, problem solving) rather than tobacco use directly. Additionally, these trials either primarily targeted parents86,97 or included intervention components for both youth and their parents.98 The remaining four trials targeted youth directly. Of these four targeted trials, three tailored their interventions to individual participants.79,91,95 That is, intervention messages via motivational interviewing, counseling, or computer programs were individualized according to youths' reports regarding their stage of smoking initiation or cessation or relevant to their specific barriers or attitudes toward smoking.

Table 5 Intervention Characteristics of Included Trials

Trial | Focus | Targeted According to Smoking Status (Y/N) | Included Multiple Behaviors (Y/N) | Person Targeted (Youth, Parent, Both) | Role of PC | Mode of Intervention | Duration of Intervention | Estimated Hours of Contact With Interventionist | Included Group Sessions (Y/N) | Included MI (Y/N) | Control Group Description
Bauman 2002^86^ | Combined, Prevention, Cessation | N | Y | Parent | None | Phone, print | 15 weeks | 0.96 | N | N | Not described
Hollis 2005^91^ | Combined, Prevention, Cessation | Y | N | Youth | Conducted in PC, provider delivered part | Face, computer | 1 visit + 2 booster sessions within 12 months | 0.25 | N | Y | Attention control
Kentala 1999^93^ | Combined | Y | N | Youth | Conducted in dental, provider delivered most | Face | 1 visit | 0.08 | N | N | Usual care
Lando 2007^95^ | Combined, Prevention, Cessation | Y | N | Youth | Conducted in dental, provider delivered part | Face, phone | 1 visit + 3–6 booster calls within 6 months | 1.2 | N | Y | Low intensity
Pbert 2008^79^ | Combined, Prevention, Cessation | Y | N | Youth | Conducted in PC, provider delivered part | Face, phone | 1 visit + 4 booster calls over 21 weeks | 1.1 | N | Y | Usual care
Prado 2007^97^ | Combined | N | Y | Parent | None | Face | 12 months | 49 | Y | N | Attention control
Stevens 2002^98^ | Combined | N | Y | Both | Conducted in PC, provider delivered part | Face, phone, print | 36 months | NR | N | N | Attention control
Ausems 2002^85^ | Prevention | Y | N | Youth | None | Print | 9 weeks | 0 | N | N | Not described
Curry 2003^11^ | Prevention | Y | N | Both | Recruitment only, optional PC | Print, phone | 6 weeks + 1 booster call within 14 months | NR | N | N | Usual care
Fidler 2001^88^ | Prevention | Y | N | Youth | Recruitment only | Print | 12 months | 0 | N | N | Usual care
Haggerty 2007^90^ | Prevention | Y | Y | Both | None | Face | 7 weeks | 15.5 | Y | N | No interaction
Hovell 1996^81^ | Prevention | Y | N | Youth | Conducted in dental, provider delivered most | Face, print | 2 years | NR | N | N | Usual care
Jackson 2006^92^ | Prevention | Y | N | Both | None | Print | 10 weeks + 1 booster guide within 12 months | 0 | N | N | Low intensity
Colby 2005^87^ | Cessation | Y | N | Youth | Recruitment only | Face, phone, print | 1 visit + 1 booster call within 1 week | 0.875 | N | Y | Low intensity
Colby 2012^104^ | Cessation | Y | N | Both | Recruitment only | Face, phone, print | 1 visit + 1 booster call within 1 week + 1 parent discussion | 1.25 | N | Y | Low intensity
Pbert 2011^80^ | Cessation | Y | N | Youth | None | Face | 4 weeks | 1.5 | N | N | Low intensity
Killen 2004^94^ | Cessation (Medication) | Y | N | Youth | None | Face | 10 weeks | 7.5 | Y | N | Placebo
Muramoto 2007^96^ | Cessation (Medication) | Y | N | Youth | None | Face | 7 weeks | 2.25 | N | N | Placebo

Abbreviations: Face = face-to-face; MI = motivational interviewing; NR = not reported; PC = primary care.

Five of the interventions were conducted in a primary care setting79,91,98 or dental practice93,95 and included face-to-face interaction with a health care provider (e.g., primary care clinicians, dental hygienists, dentists, pediatricians, nurse practitioners, physician's assistants, and pediatric residents). Provider interaction included brief advice to quit smoking or to remain abstinent91,93,95 or a single counseling session based on the 5A model (i.e., ask, advise, assess, assist, and arrange followup).79 In three of the trials, trained health counselors continued more in-depth counseling and followup phone calls with participants after interaction with the primary health care provider.79,91,95 In one study, the health counselors were female college students ages 21–25 years who had smoked as adolescents and had successfully quit (termed as “peer” counselors).79

The most provider-intensive intervention, by Stevens and colleagues, included optional physician-delivered messages for participating youth and parents at all office visits over 36 months. In addition, the child, parent, and pediatrician signed a contract stating that the family would talk about the risks of tobacco (and alcohol) use at home and develop a family policy. Approximately 10 days after the visit, families received a signed letter from their clinician reinforcing the agreement. Families also received printed materials sent to their home on a quarterly basis and biannual telephone calls over the course of the 3-year trial. All pediatricians, nurse practitioners, and practice staff received intensive training according to their practices' treatment condition (i.e., tobacco and alcohol vs. safety) and ongoing practice support. Training included general education and role playing with feedback and ongoing support, including a “message of the month,” feedback from chart audits, and regular office visits to touch base about any problems encountered.98

The two studies that were not conducted in a primary care or dental office setting were considered primary care feasible or referable, as they consisted of mailed print materials, phone calls to the participants' homes, or group sessions for parents and parent-child pairs.86,97 While they were not conducted in a primary care setting or linked with the health care system, it is conceivable that the interventions themselves could be feasibly implemented in such settings or be referred to, if widely available.

The samples for all of the trials were recruited directly by study staff. Potential participants were approached in person at the clinics or by recruitment phone calls or letters. Most of the studies identified age-eligible children through clinic medical records and subsequently sent letters or approached youth in the clinic's waiting room before their appointment or during the actual dental or well-child visit. One study also included posted signs in the waiting rooms of clinics,79 thus allowing participants to self-elect to enroll.

The majority of the trials included fairly minimal personal interaction (i.e., an hour or less of interventionist contact) and the combinations of intervention modes varied considerably. All but one intervention included some form of face-to-face contact; this trial86 used print materials in addition to telephone followup. Four studies included brief counseling sessions with a health care provider and/or trained health counselor in addition to followup phone counseling.79,91,95,98 Three studies employed motivational interviewing conducted by health counselors, peer counselors, or other study staff.79,91,95 One study incorporated an interactive computer program91 and another study included group sessions for parents.97

The study with the highest amount of interventionist contact (49 hours) was designed to increase parental involvement, positive parenting, and family support among Hispanic families.97 The assumption was that increased family functioning would lead to lower prevalence of substance use among adolescents. Both intervention and control groups also incorporated intervention messages focused on increasing parent-child communication about sex and HIV risk. Hence, while one of the intervention's objectives was to decrease tobacco use among adolescents in the intervention group, the hours of contact with an interventionist that specifically focused on tobacco use and communication regarding tobacco use was presumably only a fraction of the total time spent interacting with an interventionist.

All of the studies relied on self-reported smoking or cigarette use as the primary outcome (Table 6). Three of the trials measured lifetime or “ever” use,86,93,98 two trials examined the proportion of youth smoking in the past 30 days,91,95 one evaluated the past 90 days,97 and one examined the proportion of youth reporting “regular or occasional” use.79 Three trials included secondary measures of additional tobacco products, including chewing tobacco, cigars, and pipes.86,91,93 No studies used a measure of biochemical verification (e.g., CO or cotinine levels) to confirm self-reported smoking status. However, one study showed participants a CO monitor and told them that they might use it to confirm their self-reported smoking status (i.e., a bogus pipeline approach)79—presumably to increase the validity of the self-report measures.

Table 6 Measurement of Tobacco Use

Study | Focus | Smoking-Related Eligibility Criteria | Primary Smoking Outcome | N Analyzed | Biochemical Measures | Additional Tobacco-Related Measures
Bauman 2002^86^ | Combined | None | % of full sample reporting ever smoking (even one puff) at posttest | 1,135 | None | Ever use of chewing tobacco or snuff
Hollis 2005^91^ | Combined | None | % of full sample reporting smoking ≥1 cigarettes in the past 30 days at posttest^†^ | 2,524 | None | 30-day use of cigarettes, cigars, pipes, and chewing tobacco; susceptibility; stage of acquisition; stage of cessation
Kentala 1999^93^ | Combined | None | % of full sample reporting ever smoking (assumed) at posttest | 2,178 | None | Ever use of chewing tobacco or snuff; number of cigarettes smoked per day; number of cigarettes smoked per week
Lando 2007^95^ | Combined | Included those who smoked in previous 30 days, were former smokers (smoked in past, not past 30 days), or nonsmokers with an inclination to start (i.e., “susceptible smokers”) | % of full sample reporting smoking in past 30 days | 280 | None | None
Pbert 2008^79^ | Combined | None | % of smokers (smoke “occasionally or regularly”) and nonsmokers (never smoked or 1–2 puffs but not in the past year) not abstinent at posttest (specific measure NR) | 2,478 | Patients were shown a CO monitor and told it might be used to confirm their self-reported smoking status | None
Prado 2007^97^ | Combined | None | % of full sample reporting smoking in the past 90 days at posttest | 154 | None | None
Stevens 2002^98^ | Combined | None | % of full sample reporting ever smoked at posttest | 3,070 | None | Ever use of smokeless tobacco
Ausems 2002^85^ | Prevention | None | % of baseline nonsmokers (not even one puff) reporting ever smoking or smoking in the past 30 days at posttest | 912 | None | Intention to smoke
Bauman 2001^100^ | Prevention | None | % of baseline nonsmokers (not ever smoking, even one puff) reporting ever smoking (even one puff) at posttest | 828 | None | Ever use of chewing tobacco or snuff
Curry 2003^11^ | Prevention | None | % of full sample^*^ reporting smoking (even a puff) in past 30 days at posttest | 3,552 | None | Susceptibility; experimenting (ever smoking)
Fidler 2001^88^ | Prevention | Excluded those who smoked one or more cigarette a week | % of full sample reporting “starting to smoke” at posttest (specific measure NR) | 2,212 | None | None
Haggerty 2007^90^ | Prevention | None | % of baseline nonsmokers (specific measure NR) reporting initiating smoking postintervention (specific measure NR) | 241 | None | None
Hollis 2005^91^ | Prevention | None | % of baseline nonsmokers (no smoking in past 30 days) reporting smoking ≥1 cigarettes in the past 30 days at posttest^†^ | 1,935 | None | 30-day use of cigarettes, cigars, pipes, and chewing tobacco; susceptibility; stage of acquisition; stage of cessation
Hovell 1996^81^ | Prevention | None | % of baseline nonusers (no 30-day tobacco use or having ever used tobacco more than 100 times)^‡^ reporting tobacco use in the past 30 days at posttest | 14,775 | None | Ever used any form of tobacco more than 100 times
Jackson 2006^92^ | Prevention | Excluded ever smokers, even one puff | % of full sample reporting ever smoking (even a puff) at posttest | 776 | None | None
Lando 2007^95^ | Prevention | Included those who smoked in previous 30 days, were former smokers (smoked in past, not past 30 days), or nonsmokers with an inclination to start (i.e., “susceptible smokers”) | % of baseline nonsmokers (never smoked but susceptible) and baseline former smokers (ever smoked, but not in past 30 days) reporting smoking in the past 30 days at posttest | 156 | None | None
Pbert 2008^79^ | Prevention | None | % of baseline nonsmokers (never smoked or 1–2 puffs but not in the past year) abstinent at posttest (specific measure NR) | 2,216 | Patients were shown a CO monitor and told it might be used to confirm their self-reported smoking status | None
Bauman 2000^99^ | Cessation | None | % of baseline smokers (≥1 days in the past 30 days) reporting having smoked ≥1 days in past 30 days at posttest | 85 | None | Ever use of chewing tobacco or snuff; average number of days smoked in past 30 days
Colby 2005^87^ | Cessation | Included only those who reported daily smoking for the past 30 days | % of full sample reporting 7-day abstinence at posttest | 68 | Expired CO level; saliva cotinine level | Average cigarettes per day
Colby 2012^104^ | Cessation | Included those who reported smoking at least once per week in the past 30 days | % of full sample reporting 7-day abstinence and biochemically confirmed expired CO <9 ppm and saliva cotinine <14 ng/mL | 132 | Expired CO and saliva cotinine levels | None
Hollis 2005^91^ | Cessation | None | % of baseline smokers (smoking ≥1 cigarettes in the past 30 days) reporting smoking ≥1 cigarettes in the past 30 days at posttest^†^ | 589 | None | 30-day use of cigarettes, cigars, pipes, and chewing tobacco; susceptibility; stage of acquisition; stage of cessation
Lando 2007^95^ | Cessation | Included those who smoked in previous 30 days, were former smokers (smoked in past, not past 30 days), or nonsmokers with an inclination to start (i.e., “susceptible smokers”) | % of baseline smokers (smoked in past 30 days) reporting smoking in past 30 days at posttest | 124 | None | None
Pbert 2008^79^ | Cessation | None | % of baseline smokers (smoke “occasionally or regularly”) abstinent at posttest (specific measure NR) | 262 | Patients were shown a CO monitor and told it might be used to confirm their self-reported smoking status | None
Pbert 2011^80^ | Cessation | Included those who reported smoking in past 30 days and were interested in quitting in next 2 weeks | % full sample reporting 30-day abstinence at posttest | 1,068 | Saliva cotinine level (secondary analysis among those reporting 3-day abstinence) | Number of cigarettes smoked per day and number of smoking days
Killen 2004^94^ | Cessation (Medication) | Included those who currently smoked at least 10 cigarettes per day, smoked for at least 6 months, had made one or more failed attempts to quit, and scored ≥10 on the mFTQ | % of full sample reporting 7-day abstinence (not even a puff) and biochemically confirmed saliva cotinine level <20 ng/mL at posttest | 134 | Saliva cotinine level | Number of cigarettes smoked per day
Muramoto 2007^96^ | Cessation (Medication) | Included those who reported smoking at least 6 cigarettes per day, had an exhaled CO level ≥10 ppm, and had at least 2 previous quit attempts and were motivated to quit; excluded those using other tobacco products | % of baseline smokers (≥6 cigarettes per day, exhaled CO level ≥10 ppm, ≥2 previous quit attempts, and were motivated to quit ) reporting 7-day abstinence at posttest | 122 | Expired CO level (secondary analysis) | 30-day prolonged abstinence

* An estimated 1.2% of the sample had smoked in the past 30 days at baseline.

† Originally reported as the percentage of participants reporting no smoking; reversed for consistency.

‡ Tobacco use includes the use of cigarettes, pipes, cigars, or smokeless tobacco.

§ Baseline ever smokers are not included in this analysis.

Abbreviations: CO = carbon monoxide; Face = face-to-face; mFTQ = modified Fagerström Tolerance Questionnaire; MI = motivational interviewing; NA = not applicable; PC = primary care.

The overall weighted average age in all of the combined trials was 14 years. All of the trials included a fairly even distribution of males and females. Most of the participants in these trials were white, while the one group-based trial with high interventionist contact specifically targeted Hispanic youth.97

Quality of included trials. Two of the seven trials were rated as good quality,91,98 while the remaining five trials were rated as fair quality due to varying threats to validity (see Appendix F for quality criteria). Table 7 presents the main quality concerns for each trial. Among the fair-quality trials, randomization methods were not reported or not appropriate (e.g., based on participants' birth dates) in several trials. In addition, allocation concealment was commonly not reported or uncertain leading to potential selection bias. One study suffered from high attrition, with only 65 percent of the sample retained at 12-months followup.95 Participant compliance and/or intervention completion were also relatively low in this study. Only 70 percent of the intervention group actually received the face-to-face components (i.e., brief provider advice and motivational interviewing), and only one third of the sample received at least one (of potentially six) followup counseling telephone call.

Table 7 Results of Interventions, Combined Primary Prevention and Cessation

Study | Targeted Multiple Behaviors (Y/N) | Person Targeted (Youth, Parent, Both) | Role of Primary Care | Mode of Intervention | Months to Followup | Primary Outcome Measure | % Smoking at BL, IG^†^ | % Smoking at BL, CG^†^ | % Smoking at Followup, IG^‡^ | % Smoking at Followup, CG^‡^ | Relative Risk (95% CI) | Quality Rating, Main Quality Concerns
Bauman 2002^86^ | Y | Parent | None | Phone, print | 7 | Ever smoked even 1 puff of a cigarette | 19.3^§^ | 24.8^§^ | 36.0 | 43.0 | 0.84 (0.72 to 0.97) | Fair, randomization methods NR; blinding of outcomes assessment uncertain; retention <90% in CG; baseline differences between groups not presented (although controlled for in analysis)
Hollis 2005^91^ | N | Youth | Conducted in PC, provider delivered part | Face, computer | 12 | Smoked ≥1 cigarettes in the past 30 days | 23.3∥ | 23.4∥ | 22.8 | 27.2 | 0.84 (0.73 to 0.96) | Good, no concerns
Kentala 1999^93^ | N | Youth | Conducted in dental, provider delivered most | Face | 12 | NR (ever smoked assumed) | 5.5 | 6.0 | 13.3 | 12.2 | 1.09 (0.87 to 1.36) | Fair, no description of how smoking was measured or defined; randomization based on birth date, so allocation concealment and outcomes assessment unlikely to be blind; retention <90% in both groups; NR proportion received intervention; smokers more likely to drop out
Lando 2007^95^ | N | Youth | Conducted in dental, provider delivered part | Face, phone | 12 | Smoked in past 30 days | 34.9^§^ | 37.3^§^ | 48.1 | 47.6 | 1.01 (0.79 to 1.29) | Fair, retention <70% in both groups; allocation concealment and blinding of outcome assessment NR; no information on baseline comparability; poor adherence to intervention; ITT only among current smokers
Pbert 2008^79^ | N | Youth | Conducted in PC, provider delivered part | Face, phone | 12 | Smoked occasionally or regularly | 8.7 | 10.6 | 9.4 | 11.7 | 0.80 (0.50 to 1.26) | Fair, detail about how random number generated NR; allocation concealment and blinding of outcomes assessment NR
Prado 2007^97^ | Y | Parent | None | Face | 12 | Smoked cigarettes in past 90 days | 3.3 | 1.2 | 7.6 | 4.0 | 1.90 (0.49 to 7.32) | Fair, participant adherence NR (e.g., number of sessions attended); retention <90% in all groups
Stevens 2002^*,98^ | Y | Both | Conducted in PC, provider delivered part | Face, phone, print | 12 | Ever smoked (specific measure NR) | 5.3^§^ | 4.5^§^ | NR | NR | NR^**^ | Good, blinding of outcome assessors NR

* Not included in meta-analysis.

† Among those randomized.

‡ Among those analyzed at followup.

§ Calculated based on presented data.

∥ Calculated based on data requested from the author.

** The adjusted odds ratio for having ever smoked for the intervention group compared with the control group was 1.05 (95% CI, 0.80 to 1.39).

Abbreviations: BL = baseline; CG = control group; CI = confidence interval; Face = face-to-face; IG = intervention group; ITT = intention to treat; NR = not reported; OR = odds ratio; PC = primary care.

Summary of findings. A meta-analysis combining six of the seven studies that reported overall smoking prevalence found a nonstatistically significant pooled risk ratio (RR) of smoking for youth assigned to the intervention compared with the control group of 0.91 at 6- to 12-months followup (RR, 0.91 [95% confidence interval (CI), 0.81 to 1.01]; I^2^=29.4%; k=6; n=8,749) (Figure 2). The absolute risk reduction for these trials was 2 percentage points, which translates into a number needed to treat (NNT) of 50 (pooled risk difference [RD], -0.02 [95% CI, -0.05 to 0.01]). In a sensitivity analysis of the four studies79,91,95,97 that had similar outcome measures (e.g., current smoking in the past 30 or 90 days), the effect was similar in magnitude.

Figure 2 Forest Plot of Smoking for Intervention Group Compared With Control Group, Study Target Combined Prevention and Cessation, Prevention, or Cessation, All Behavioral Trials

Note: Due to the clustering adjustment, the denominators for Hovell,81 Pbert,79 and Pbert80 and the subtotal denominators do not match what is reported in the text and tables.

Figure 2 displays a forest plot of combined, prevention, and cessation behavior-based studies reporting the relative risk of smoking in the intervention group versus the control group. Data from Figure 2 are presented in Tables 7, 8, and 9. This figure is described further in the report as follows: “A meta-analysis combining six of the seven studies that reported overall smoking prevalence found a nonstatistically significant pooled risk ratio (RR) of smoking for youth assigned to the intervention compared with the control group of 0.91 at 6- to 12-months followup (RR, 0.91 [95% CI, 0.81 to 1.01]; I2=29.4%; k=6; n=8,749).” This figure is also described as follows: “A meta-analysis of the data from nine of the 10 studies examining smoking initiation among baseline nonsmokers showed a statistically significant pooled effect of the intervention in reducing the risk of smoking initiation among youth at 6- to 36-months followup (RR, 0.81 [95% CI, 0.70 to 0.93]; I2=37.8%; k=9; n=26,624) compared with the control.” This figure is also described as follows: “A meta-analysis of the seven behavior-based trials that included an examination of smoking cessation at 6 to 12 months showed a small, but not statistically significant, pooled effect on quitting smoking favoring the intervention (RR, 0.96 [95% CI, 0.90 to 1.02]; I2=48.7%; k=7; n=2,328).”

Examined individually, two of the seven trials showed a statistically significant effect on the overall prevalence of smoking at 6- to 12-months followup, with a decreased risk of smoking in favor of the intervention groups over the control groups (Table 7).86,91 The most relevant study to primary care in the United States was the Teen Reach program (Research Approaches to Cancer in a Health Maintenance Organization) by Hollis and colleagues.91 In this study, adolescents ages 14–17 years who were members of Kaiser Permanente Northwest were recruited through their pediatric and family practice clinics. Youth randomized to the intervention group (n=1,254) received brief clinician advice (i.e., 30 to 60 seconds), the Pathways to Change (PTC) interactive computer program (10–12 minutes), and brief motivational counseling by a trained health counselor immediately after the clinic visit (3–5 minutes). All intervention components were highly individualized and tailored to the youths' smoking status and stage of readiness to begin smoking (for nonsmokers) or stage of change to quit smoking (for smokers). In addition, the intervention group received two booster sessions with the PTC computer program and health counselor (primarily by phone) during the remaining 11 months of the study. Adolescents allocated to the control group (n=1,272) received brief health counseling and print materials promoting increased consumption of fruits and vegetables. At 12-months followup, there was a 16 percent statistically significant reduced risk of smoking during the past 30 days among all youth in the intervention group compared with the control group (RR, 0.84 [95% CI, 0.73 to 0.96]). The absolute risk reduction was 4 percentage points, or a NNT of 25. Although data was not shown, the authors also report a consistent pattern of results when the outcome included other forms of tobacco (i.e., pipes, cigars, and smokeless tobacco). This study was rated as high quality and was strengthened by relatively high retention (93.7% after 1 year) and its approach for handling missing smoking outcome data (multiple imputations).

None of the remaining five trials showed a statistically significant difference between the intervention and control group at 6- to 12-months followup. However, one trial had a consistent positive effect, although not statistically significant (RR, 0.80 [95% CI, 0.64 to 1.00]).79 The remaining three trials showed a slight52,93,95 or relatively large97 increased risk of smoking among the intervention groups compared with the control groups, although none of these studies were statistically significant. In the family-based trial by Prado and colleagues that targeted multiple behaviors among Hispanic youth, the risk of smoking among the intervention group was almost two times that of the control group at 12 months, although the CI for this effect was very wide, likely given the small sample size (RR, 1.90 [95% CI, 0.49 to 7.32]).97

We were unable to include one trial in the meta-analysis due to the limited data presented (we contacted the author of this study requesting the data needed but did not receive the data).52 This study, however, was among the most applicable interventions to the U.S. primary care setting, as it was conducted in 12 pediatric primary care practices serving a diverse population. Families of children in the 5th or 6th grade visiting their primary care providers for a well-child visit were recruited directly to participate. Consenting families were randomized to either the intervention group (focused on alcohol and tobacco use) or attention control (focused on safety behaviors, including bicycle helmet and seatbelt use and safe gun storage). The intervention began during the well-child visit, during which the clinician discussed the risks of tobacco and alcohol use with both the child and parent. At all subsequent office visits over 3 years, clinicians reinforced the intervention's messages, offered help, and answered any questions. The child, parent, and pediatric clinician also signed a contract that the family would talk about the risks at home and develop a family policy about alcohol and tobacco use. About 10 days later, the family received a letter signed by their clinician reinforcing the agreement. Over the next 36 months, children and parents were reminded of the importance of family communication regarding alcohol and tobacco use at all subsequent office visits. After adjusting for child and family baseline characteristics, there was no effect of the intervention on ever smoking (odds ratio [OR], 1.05 [95% CI, 0.80 to 1.39]) or ever using smokeless tobacco (OR, 1.00 [95% CI, 0.39 to 2.54]) at 12 months.

Five of the seven studies presented outcomes beyond 12 months.86,91,93,97,98 One study presented additional data at 16 months,86 four presented outcomes at 24 months,91,93,97,98 and one measured outcomes again at 36 months.98 This intervention by Stevens and colleagues was the only intervention that spanned the full duration of the assessment period (i.e., the intervention lasted 36 months and followup measurements occurred at 12, 24, and 36 months). The remaining studies did not include any intervention components beyond 12 months. Among all of the studies, the long-term findings generally mirrored the effects seen at 6 or 12 months. In the trial by Hollis and colleagues, the statistically significant treatment effect found at 12 months diminished somewhat at 24-months followup, but remained statistically significant.91 In the trial by Pbert and co-authors, outcomes were presented at both 6 and 12 months.79 We included the outcomes at 12 months in the meta-analysis to be consistent with the other studies in this group. At 6 months, a relatively large statistically significant effect was seen; the intervention decreased the risk of smoking by almost 50 percent (RR, 0.51 [95% CI, 0.31 to 0.84]). However, the effect attenuated at 12 months and was no longer statistically significant (RR, 0.80 [95% CI, 0.64 to 1.00]). The remaining trials did not find any statistically significant differences between the intervention and control groups at 24 or 36 months.86,91,93,97,98 One of these studies found a statistically significant effect of the intervention at 7 months, but not 16 months.50

Common elements of efficacious interventions. We qualitatively examined a number of specific intervention characteristics (e.g., face-to-face interaction, hours of contact, role of primary care, individual targeted) and study design issues (e.g., measurement of the primary outcome) to see if they were associated with effect size. The components examined were based on expert advice and our ability to robustly identify that component in the published trials. Despite this effort, however, no clear pattern emerged that explained why some trials had beneficial effects and others did not.

Differences in patient subgroups. No data were found to explore whether some subpopulations benefited more from tobacco-use interventions than others.

### Prevention Interventions

General characteristics of the trials. Five trials included a behavior-based intervention designed to prevent the initiation of tobacco use among children and adolescents,11,81,88,90,92 and one additional trial85 with a broad-based approach also reported a prevention effect among nonsmoking children and adolescents (total n=22,401). This last trial did not meet inclusion criteria for the combined and cessation groups, however, and did not present adequate data to be included in the meta-analysis.85 In addition to these six trials, four of the combined trials described above analyzed baseline nonsmokers separately to evaluate the effect of the intervention on smoking initiation (n=5,135).79,91,95,100

We identified a large variation in the types and intensities of interventions, which ranged from no interaction with an interventionist (i.e., zero “sessions”) to seven group sessions totaling over 15.5 hours (Table 5). As in the combined trials listed above, the one trial90 with high amount of interventionist contact (15.5 hours) was the only study in this group to target multiple behaviors (i.e., “universal” substance abuse and problem behaviors). Six of the 10 studies in this group targeted youth directly,79,81,85,88,91,95 three included intervention components for both youth and their parents,11,90,92 and one trial primarily targeted parents.100

Two of the 10 trials of prevention effects were conducted outside of the United States, one was conducted in the Netherlands,85 and one was conducted in the United Kingdom.88 The two interventions conducted outside of the United States were similar and both targeted youth directly and consisted primarily of mailed print materials to the youths' homes. Children in the Ausems study were recruited from elementary schools and were sent tailored materials according to their baseline smoking status.85 In the Fidler study, children and adolescents ages 10–15 years were recruited from 14 health centers serving a mix of urban “deprived,” city center, suburban, and rural areas; participants were sent materials largely about the advantages of remaining a nonsmoker.88

In total, two studies were conducted in a primary care setting (Hollis 2005^91^ and Pbert 2008^79^) and two were conducted in a dental care setting (Lando 2007^95^ and the prevention study by Hovell and colleagues81). In the study by Hovell and colleagues, orthodontic clinics with at least 75 active patients ages 11–18 years were randomized to implement a minimal tobacco prevention intervention or usual care.81 For the intervention group, clinic staff gave an antitobacco “prescription” to their patient, briefly discussed the prescription message, and requested that the patient not start smoking. Clinics were offered modest monetary incentives ($0.50) for every prescription dispensed. Children and adolescents in this trial received zero to more than seven unique prescriptions over 2 years, although it was not clear how this was measured. The remaining six studies that were not conducted directly in a primary care or dental office setting were primarily home-based studies and primarily included mailed print materials and/or followup phone counseling.11,85,88,90,92,100 One study included two intervention arms in addition to a no treatment control group.90 One intervention arm consisted of a self-administered intervention (i.e., video and workbook activities) with telephone support and the other, more intensive arm, consisted of family group sessions focused on multiple forms of substance use and problem behavior in general. None of the five prevention-only focused trials included the use of motivational interviewing.

One prevention study relied on a volunteer sample of youth.92 For this study, recruitment letters were sent home with all 3rd grade youth within 28 school districts; interested parents could enroll in the study with their child by mailing a signed consent form to the project office. Interestingly, in this family-based study, parents and children were only eligible if the parents reported current smoking at baseline. The remaining nine studies all contacted participants directly through study staff (although one study, as described above, also posted signs in the waiting rooms of clinics79).

The primary outcome for smoking initiation in all of the trials was based on self-report (Table 6). One study used a measure that included all forms of tobacco use (i.e., cigarettes, pipes, cigars, or smokeless tobacco)81 and the remaining nine studies only reported cigarette use. The one study in the United Kingdom reported smoking initiation as “starting to smoke” at 12 months, although the specific measure was not reported.88 Ever smoking or smoking within the past 30 days among baseline nonsmokers and/or former smokers were the primary outcome measures reported in the remaining trials. One study only reported ever smoking since the posttest.90 That is, it did not capture any smoking initiation that occurred during the intervention (7–10 weeks in duration), an important limitation that we discuss below.

The weighted average age of the samples in all 10 prevention studies was 14 years. However, the age range of the six prevention-only studies included slightly younger participants overall (e.g., as young as age 7 years in one trial) (Table 4). The weighted average does not include data from two prevention-only studies (Jackson 2006,92 whose participants ranged in age from 10–15 years, and Fidler 2001,88 with participants ages 7–8 years) that did not report the average age of their participants. All 10 of the trials included a fairly even distribution of males and females. The sample in the only family-based prevention study by Haggerty and colleagues was approximately half African American families and half white families.90

Quality of included trials. The body of included studies was generally of fair quality, with two of the 10 studies rated as good quality.81,91 The one good-quality trial that focused on only prevention was published in 1996 and was a CRT of orthodontist clinics.81 Office compliance was relatively high in delivering the intervention, and participant followup was 92.8 and 92.3 percent for the intervention and control groups, respectively.

Among trials rated as fair quality, randomization procedures were frequently not reported or uncertain, including allocation concealment. Blinding of outcome assessment was not reported in all but one trial.92 However, the lack of blinding for outcome assessors was unlikely to produce bias in those studies using standardized data collection tools such as computer-assisted telephone interviewing.11 Three studies did not report baseline values of the intervention and control groups, respectively,88,92,95 making it difficult to determine if the groups were comparable at baseline. As stated above, one study relied on self-reported smoking initiation from the posttest immediately following the intervention rather than baseline.90 The authors report that 28.7 percent of the sample initiated some substance use prior to the posttest. These youth, however, are not included among those that initiated smoking. The authors' rationale was that “this initiation in the interim may or may not have occurred before exposure to the intervention.” However, this omission may have led to reporting bias and is a noted limitation to this study's internal validity.

Summary of findings. A meta-analysis of the data from nine of the 10 studies examining smoking initiation among baseline nonsmokers showed a statistically significant pooled effect of the intervention in reducing the risk of smoking initiation among youth at 6- to 36-months followup (RR, 0.81 [95% CI, 0.70 to 0.93]; I^2^=37.8%; k=9; n=26,624) (Figure 2) compared with the control. That is, the interventions reduced the risk of smoking initiation at followup by 19 percent. The pooled absolute RD was 2 percentage points (pooled RD, -0.02 [95% CI, -0.03 to 0.00]), resulting in a NNT of 50. We also conducted a sensitivity analysis, in which we excluded two studies92,100 that both operationalized smoking initiation as “ever” smoking postbaseline assessment, as we felt this may be an overly sensitive measure of smoking uptake. The pooled intervention effect remained statistically significant (RR, 0.83 [95% CI, 0.71 to 0.98]; I^2^=42.8%; k=7; n=25,020).

Two of the trials that focused exclusively on prevention in nonsmoking youth88,92 and one of the combined trials that tailored the intervention according to smoking status91 found statistically significant effects of the intervention relative to the control groups for smoking initiation (Table 8 Figure 2). The two prevention-focused trials with statistically significant effects included minimal interventions that only consisted of mailed print materials,88,92 one of which was conducted outside the United States.88 This study in the United Kingdom found that 5 percent of the intervention group initiated smoking at 12-months followup (RR, 0.65 [95% CI, 0.47 to 0.90]) compared with 7.8 percent of the control group. The trial by Hollis and colleagues was the only trial conducted in a primary care setting that included face-to-face interaction with a clinician or other health counselor and showed a statistically significant intervention effect among baseline nonsmokers at 12 months (RR, 0.76 [95% CI, 0.59 to 0.99]). As discussed later, this effect diminished at 2 years and was no longer statistically significant. In this trial, 91 percent of the baseline nonsmokers reported that they were not thinking about smoking in the future. Interestingly, the trial by Jackson and colleagues only included longer-term outcomes measured at 36 months and found a statistically significant difference among groups—11.9 percent of participants in the intervention group initiated smoking at 36 months compared with 19.3 percent of the control group (RR, 0.62 [95% CI, 0.47 to 0.90]).92 This study included the youngest sample among this group of studies (ages 7–8 years at baseline). The intervention consisted of four mailed activity guides over 10 weeks in addition to one mailed activity guide within 12 months.

Table 8 Results of Interventions, Prevention Interventions

Study | Person Targeted (Youth, Parent, Both) | Role of Primary Care | Mode of Intervention | Months to Followup | Primary Outcome Measure | % Initiating Smoking at Followup, IG | % Initiating Smoking at Followup, CG | Relative Risk (95% CI) | Quality Rating, Main Quality Concerns
Ausems 2002^85^ | Youth | None | Print | 6 | Ever smoked even 1 puff of a cigarette or smoked in past 30 days | 10.4† | 18.0^†^ | NR^†^ | Fair, randomization methods and allocation concealment NR; eligibility criteria not specified
Bauman 2001^100^ | Parent | None | Phone, print | 7 | Ever smoked even 1 puff of a cigarette | 17.0 | 21.0 | 0.81 (0.61 to 1.07) | Fair, randomization methods NR; blinding of outcomes assessment uncertain; retention <90% in CG; baseline differences between groups not presented (although controlled for in analysis)
Curry 2003^11^ | Both | Recruitment only | Phone, print | 20 | Smoked in past 30 days | 2.4^‡^ | 2.3^‡^ | 1.04 (0.68 to 1.58) | Fair, randomization methods uncertain; retention <90% in IG; among assessment cohort, more children in the IG than CG report smoking in prior 30 days; smokers included in randomization
Fidler 2001^88^ | Youth | Recruitment only | Print | 12 | “Started to smoke” postbaseline | 5.1 | 7.8 | 0.65 (0.47 to 0.90) | Fair, randomization based on birth date; allocation likely not concealed; relatively high attrition with completers analysis only; no information on baseline comparability; no measure of adherence to intervention; smokers included in randomization
Haggerty 2007^90^ | Both | None | Face | 12 | “Started to smoke” postintervenetion | 11.8^§^ | 9.0^§^ | 1.31 (0.52 to 3.28) | Fair, randomization methods, allocation concealment, blinding of outcome assessors NR; smokers included in randomization
Hollis 2005^91^ | Youth | Conducted in PC, provider delivered part | Face, computer | 12 | Smoked ≥1 cigarettes in past 30 days | 9.3 | 12.1 | 0.76 (0.59 to 0.99) | Good, no concerns
Hovell 1996^81^ | Youth | Conducted in dental, provider delivered most | Face, print | 24 | Used tobacco^*^ in past 30 days | 12.0∥ | 12.6∥ | 0.95 (0.84 to 1.07) | Good, randomization methods and allocation concealment uncertain
Jackson 2006^92^ | Both | None | Print | 36 | Ever smoked even 1 puff | 11.9 | 19.3 | 0.62 (0.44 to 0.87) | Fair, randomization methods and allocation concealment NR; do not report baseline values for all youth randomized; do not present number randomized to each group; adherence to intervention unknown
Lando 2007^95^ | Youth | Conducted in dental, provider delivered part | Face, phone | 12 | Smoked in past 30 days | 9.7 | 16.7 | 0.58 (0.25 to 1.37) | Fair, retention <70% in both groups; allocation concealment and blinding of outcome assessment NR; no information on baseline comparability; poor adherence to intervention; ITT only among current smokers
Pbert 2008^79^ | Youth | Conducted in PC, provider delivered part | Face, phone | 12 | Smoked occasionally or regularly | 3.2 | 4.5 | 0.69 (0.30 to 1.58) | Fair, detail about how random number generated NR; allocation concealment and blinding of outcomes assessment NR

* Tobacco use includes the use of cigarettes, pipes, cigars, or smokeless tobacco.

† The number of baseline nonsmokers and the number of children initiating smoking at followup were not reported. The percentage of children initiating smoking at followup (as reported in the article) were 10.4% (95% CI, 6.9% to 14.0%) in the intervention group and 18.1% (95% CI, 12.5% to 23.7%) in the control group.

‡ Among the assessment cohort (n=492), 2.5% of the IG and 0% of the CG reported smoking in the past 30 days at baseline. Author does not report whether baseline smokers were included in the followup,

§ At baseline, 22.0% of the IG and 21.7% of the CG reported smoking at baseline; these individuals were excluded from the analysis at followup.

∥ Baseline smokers were excluded from the analysis (specific numbers not reported).

Abbreviations: CG = control group; CI = confidence interval; Face = face-to-face; IG = intervention group; ITT = intention to treat; NR = not reported; PC = primary care.

All but two11,90 of the remaining seven trials found positive effects of the intervention on smoking initiation compared with the control groups, although none of these effects were statistically significant. The broad family-based intervention by Haggerty and colleagues showed a nonsignificant negative effect of the intervention.90 They found a 31 percent higher risk of initiating smoking at 12 months among participants in the intervention group compared with controls (RR, 1.31 [95% CI, 0.52 to 3.28]).

Three of the 10 studies only presented long-term smoking initiation outcomes (i.e., longer than 12 months), including one study with 20-month outcomes,11 one with 24-month outcomes,81 and the study by Jackson and colleagues with only 36-month outcomes.92 Three trials presented additional effects beyond 12 months, including one trial with 16-month outcomes86 and two studies with 24-month outcomes.90,91 Results in all of the trials remained consistent over time, except in the trial by Hollis.91 Among the nonsmokers in this study, the intervention significantly reduced smoking initiation at 12 months, but the prevention effect was no longer statistically significant at 2 years (RR, 0.84 [95% CI, 0.69 to 1.04]). Again, in the study by Pbert and colleagues,79 a statistically significant effect of the intervention was seen on smoking initiation at 6 months (RR, 0.51 [95% CI, 0.31 to 0.84]), but the effect attenuated at the 12-month followup (RR, 0.70 [95% CI, 0.47 to 1.05]).

Common elements of efficacious interventions. After qualitative examination of the studies in this group, there did not appear to be any clear relationship between any of the specific intervention characteristics or methods and the effects seen within this group of studies. As mentioned previously, two out of the three trials that found statistically significant effects on smoking initiation were very minimal interventions that consisted exclusively of mailed print materials to the participants' homes.88,92 Other factors such as the population targeted (i.e., youth vs. parent vs. both), sample characteristics, followup time, and measurement of smoking initiation did not appear to be related to the intervention's effects.

Differences in patient subgroups. There were insufficient indicators reported on participant characteristics to be able to conduct subgroup analyses.

### Cessation Interventions

General characteristics of the trials. Five trials focused on smoking cessation among child and adolescent smokers (n=1,554 randomized).80,87,94,96,104 An additional four of the combined studies presented outcomes for baseline smokers separately (n=1,060).79,91,95,99 Two of the cessation-focused trials included the use of medication (i.e., sustained-release [SR] bupropion hydrochloride) in addition to a behavioral counseling component (n=256).94,96 We did not identify any trials that estimated the independent effect of NRT or included the use of varenicline (Chantix) that met our eligibility criteria. These trials were primarily excluded because they included followup assessments of less than 6 months postbaseline.

Eligibility criteria and the definition of what constituted a smoker at baseline differed among all of the cessation trials (Table 6), with the two medication trials using the most selective criteria. For instance, youth were only eligible in a trial comparing the use of a nicotine patch and 150 mg bupropion versus a nicotine patch plus a placebo pill if they reported: 1) currently smoking 10 or more cigarettes a day; 2) smoking for 6 months or more; 3) had at least one failed quit attempt; and 4) high nicotine dependence scores.94 The three behavior-based interventions that focused exclusively on smoking cessation included youth if they reported daily smoking for the past 30 days,87 smoked at least once per week for the past month,104 or if they reported any smoking in the past 30 days and were interested in quitting in the next 2 weeks.80 The majority of the combined prevention and cessation trials considered youth to be smokers at baseline if they reported smoking at least one cigarette during the previous 30 days. In the four combined trials, baseline smoking prevalence ranged from 9.7 to 36.1 percent (100% of the samples in the cessation-only trials were smokers) (Table 4).

Four of the trials87,94,96,104 used 7-day point prevalence abstinence as the primary outcome. Four studies used 30-day point prevalence abstinence,80,91,95,99 and the remaining trial reported “occasional or regular” smoking at followup.79 All five of the trials that were exclusively designed to help smokers quit smoking included a biochemical measure of smoking via exhaled CO levels or saliva or urinary cotinine levels, including the two medication trials. Three of these five trials87,94,104 used these measures as biological confirmation (vs. as a secondary measure) of abstinence (Table 6).

Within this group of trials, all but one targeted youth directly and included face-to-face contact with an interventionist, such as a clinician, health counselor, or other study personnel. This same trial was the only trial that did not tailor the intervention messages according to the youths' baseline smoking status (Table 5).99 Two of the studies were CRTs,79,80 while the remaining included randomization at the individual level. One study80 randomized high schools and the other randomized pediatric primary care clinics.79

Three of the behavioral counseling trials were specifically designed to encourage quitting among smoking adolescents. The most recent cessation trial by Colby and colleagues104 built off of their previous trial,87 described below. In this study, 162 adolescents ages 14–18 years who smoked at least once per week for the past 30 days were randomized to receive one 45-minute motivational interviewing session, with a 15- to 20-minute booster phone call to reinforce progress toward their goals. Parents of the intervention participants were also asked to participate in a 15- to 20-minute discussion focused on increasing parent support for the adolescent's goals for changing their smoking behavior. Control group participants received brief advice. Another recent cessation trial by Pbert and co-authors consisted of a counseling intervention delivered by a school health nurse based on the 5A model (“Calling It Quits”).80 In this study, 35 high schools were randomized to either a counseling intervention or an attention control condition. Students who had smoked within the past 30 days and were interested in quitting in the next 2 weeks were eligible to participate (n=1,068). The intervention consisted of four weekly private one-on-one sessions over 1 month in the school health clinic. Two of the sessions were held prior to the self-elected quit date and two sessions were conducted after the scheduled quit date. Attention-control subjects also received four weekly visits with the school nurse where they delivered informational pamphlets and checked smoking status and efforts to quitting. The other behavior-based cessation intervention by Colby and colleagues87 was conducted at an urban hospital among 85 daily smokers ages 12–19 years, many of whom reported having psychosocial risk factors (e.g., substance use, mental health problems, and parental estrangement). Most of the sample (81%) reported having no immediate plans to quit smoking. The intervention consisted of a 35-minute motivational interview session with a booster telephone call at 1 week. Control subjects received one session that only included brief advice (5 minutes).

The two medication trials94,96 both evaluated the use of bupropion SR in addition to behavioral counseling to encourage smokers to quit smoking. In the trial by Killen and colleagues,94 adolescent smokers ages 15–18 years were recruited from nine high schools. Youth (n=211) were randomized to one of two treatment groups: 1) a nicotine patch plus 150 mg bupropion (intervention group) or 2) a nicotine patch plus a placebo pill (control group). Both groups took part in weekly group skills-based training sessions led by trained counselors that lasted 45 minutes. Sessions focused on self-regulatory skills, including modeling high-risk situations and developing action plans designed to promote nonsmoking in self-identified, high-risk situations. This intervention was of 9 weeks duration and followup assessment took place at 6 months postbaseline assessment. Similarly, in the trial by Muramoto et al,96 a volunteer sample of 312 youth ages 14–17 years was recruited and randomized to one of three groups: 1) 150 mg bupropion SR, 2) 300 mg bupropion SR, or 3) a placebo pill. In addition, all groups included weekly individual cessation counseling sessions (10–20 minutes each) for the duration of the intervention (9–10 weeks). Counseling addressed skills related to identifying social support, identifying motivators and barriers to quitting smoking, managing cravings and withdrawal symptoms, and stress management. This trial conducted followup measures at 6 months postbaseline. Both of the medication trials excluded youth with current major depression or a history or current diagnosis of panic disorder, psychosis, bipolar disorder, eating disorder, current clinical depression, or attention deficit hyperactivity disorder, presumably because of the negative behavioral symptoms reported by adults while taking bupropion to stop smoking (Zyban), including changes in behavior, hostility, agitation, depressed mood, and suicidal thoughts.64

The average weighted age of participants was 15.9 and 16.7 years in the behavior-based cessation and medication cessation trials, respectively. In general, the five trials that exclusively focused on smoking cessation (vs. the four combined trials) included older participants (average age, 16–17 years). The percent of females in each study ranged from 31.3 percent in one of the medication trials94 to 61.0 percent in one of the behavioral trials.87 Nearly half of the samples in both of these two trials were of nonwhite race (Table 4).

Quality of included trials. Across all nine studies that examined cessation among baseline smokers, two studies were rated as good quality,80,91 while the remaining trials were rated as fair quality (Table 9). The two good-quality studies include the trial by Hollis and colleagues that is included in all three sections and the recent behavior-based trial conducted by Pbert and colleagues, which was designed specifically as a cessation trial among high school students.80 This study was well designed, included a relatively large sample (n=1,068), used valid randomization methods, possessed good intervention fidelity, and had high participant compliance to the intervention. The main quality concern with this study was that there were statistically significant baseline differences in intentions to quit between the intervention and treatment groups—66 percent of the intervention group participants versus 57 percent of the control group participants planned to quit smoking within the next 12 months. The main threats to internal validity of the remaining behavior-based cessation trials include unclear randomization methods and retention below 90 percent (Table 9). The majority of studies took a conservative approach to missing outcome data and assumed that all participants lost to followup remained smokers.

Table 9 Results of Interventions, Cessation Interventions

Study | Role of Primary Care | Mode of Intervention | Months to Followup | Definition of Smoker at Baseline | Primary Outcome Measure | % Smoking at Followup, IG | % Smoking at Followup, CG | % Quitting at Followup, IG | % Quitting at Followup, CG | Relative Risk (95% CI) | Quality Rating, Main Quality Concerns
Bauman 2000^99^ | None | Phone, print | 7 | Smoked ≥1 days in past 30 days | Smoked ≥1 days in past 30 days | 59.5 | 62.5 | 40.5 | 37.5 | 0.95 (0.67 to 1.34) | Fair, randomization methods NR; blinding of outcomes assessment uncertain; retention <90% in CG; baseline differences between groups not presented (although controlled for in analysis)
Colby 2005^87^ | Recruitment only | Face, phone, print | 6 | Daily smoking for the past 30 days | Smoked in past 7 days | 76.5 | 97.1 | 23.5 | 2.9 | 0.79 (0.65 to 0.96) | Fair, randomization methods and allocation concealment NR; followup not presented by group (although states there were no significant differences); overall retention only 80% with completers-only analysis; possible selective reporting
Colby 2012^104^ | Recruitment only | Face, phone, print | 6 | Smoked ≥1 time a week for past 30 days | Smoked in past 7 days | 95.1 | 97.2 | 4.9 | 2.8 | 0.98 (0.91 to 1.05) | Fair, CO levels higher among IG participants than CG participants at baseline; retention <80% in IG; overall retention 81.5%
Hollis 2005^91^ | Conducted in PC, provider delivered part | Face, computer | 12 | Smoked ≥1 cigarettes in past 30 days | Smoked ≥1 cigarettes in past 30 days | 67.5^*^ | 76.8^*^ | 32.5^*^ | 23.2^*^ | 0.88 (0.79 to 0.97) | Good, no concerns
Lando 2007^95^ | Conducted in dental, provider delivered part | Face, phone | 12 | Smoked in past 30 days | Smoked in past 30 days | 93.4 | 88.9 | 6.6 | 11.1 | 1.05 (0.94 to 1.17) | Fair, low retention overall, very low in some subgroups; allocation concealment and blinding of outcome assessment NR; no information on baseline comparability; poor adherence to intervention; ITT only among current smokers
Pbert 2008^79^ | Conducted in PC, provider delivered part | Face, phone | 12 | Smoked occasionally or regularly | Smoked occasionally or regularly | 74.4 | 72.4 | 25.6 | 27.6 | 1.02 (0.75 to 1.38) | Fair, detail about how random number generated NR; allocation concealment and outcomes assessment NR
Pbert 2011^80^ | None | Face | 12 | Smoked in past 30 days and interested in quitting in next 2 weeks | Smoked in past 30 days | 84.8 | 85.7 | 15.2 | 14.3 | 0.99 (0.93 to 1.05) | Good, followup slightly below 90%; IG significantly more likely to want to quit at baseline
Killen 2004^94^ (Med) | None | Face | 6 | Smoked ≥10 cigarettes per day, smoked ≥6 months, had made one or more failed quit attempts, and scored ≥10 on mFTQ | Smoked in past 7 days and biochemically confirmed saliva cotinine level <20 ng/mL | 87.5 | 90.0 | 12.5 | 10.0 | 0.97 (0.86 to 1.10) | Fair, randomization methods NR; very low compliance; retention <70% in both groups but conservative methods for handling missing data
Muramoto 2007^96^ (Med) | None | Face | 6 | Smoked ≥6 cigarettes per day, had an exhaled CO level ≥10 ppm, and had at least 2 previous quit attempts and motivated to quit; excluded those using other tobacco products | Smoked in past 7 days | 93.8 | 89.7 | 6.3 | 10.3 | 1.05 (0.94 to 1.16) | Fair, retention <70% in all groups; intervention adherence NR; baseline differences between IG and CG in previous quit attempts and amount smoked; unclear analysis and data substitution

* Includes self-described experimenters and smokers.

Abbreviations: CG = control group; CI = confidence interval; CO = carbon monoxide; Face = face-to-face; IG = intervention group; ITT = intention to treat; Med = medication; NR = not reported; mFTQ = modified Fagerström Tolerance Questionnaire; PC = primary care.

The two cessation trials that included a pharmacological component were both rated as fair quality.94,96 Both of these trials had high attrition, with only 63.5^94^ and 61.9 percent96 of the sample retained after 6 months. Participant compliance was also a concern in both studies. For example, in the trial by Killen and colleagues, only 22 percent of participants reported taking all their pills (i.e., 150 mg bupropion or placebo pill) in at least six of nine treatment weeks, and 44 percent reported that they only used all their pills in two treatment weeks or less.94

Summary of findings: behavior-based trials. A meta-analysis of the seven behavior-based trials that included an examination of smoking cessation at 6 to 12 months showed a small, but not statistically significant, pooled effect on quitting smoking favoring the intervention (RR, 0.96 [95% CI, 0.90 to 1.02]; I^2^=48.7%; k=7; n=2,328) (Figure 2). A sensitivity analysis only including the four trials that included tailored intervention components for baseline smokers, 12-month followup, and similar definitions of baseline smoking79,80,91,95 yielded a consistent result (RR, 0.98 [95% CI, 0.91 to 1.05]; I^2^=57.3%; k=4; n=2,043).

When viewed individually, two of the seven behavior-based trials found statistically significant effects of the intervention on smoking cessation among baseline smokers compared with the control group at 6- or 12-months followup (Table 9).87,91 For instance, the trial by Colby and co-authors in 2005 that was specifically designed to promote quitting among daily smokers ages 12–19 years showed a 21 percent reduced risk of smoking in the previous 7 days among the intervention group (primarily motivational interviewing) versus the brief advice control group.87 At 6 months, 23 percent (n=8) of the intervention group versus 3 percent (n=1) of the control group reported 7-day abstinence. However, half of those self-reported abstinent smokers were reclassified as smokers based on their biomarker data. Based on biochemical data, abstinence rates were 9 percent (vs. 23%) and 2 percent (vs. 3%) in the intervention and control groups, respectively (a nonsignificant difference). In this study, if biochemical data were not obtained or participants were not followed up, they were classified as smokers at followup.

In the trial by Hollis and colleagues, adolescents were considered smokers at baseline if they reported smoking one or more cigarettes in the past 30 days. This included those who self-described themselves as “experimenters,” “smokers,” and “recent quitters.” Although the intervention had a statistically significant effect among all past-30-day smokers, the intervention had no effect on the small subgroup (n = 140) of youth who self-described themselves as experimenters at baseline. In contrast, a large, statistically significant effect of the intervention was found among those who considered themselves to be smokers at baseline (OR, 2.45 [95% CI, 1.43 to 4.20]). Results were similar when the outcome was defined as no tobacco (as opposed to just cigarette smoking) in the past 30 days. Eighty-two percent of adolescents who had smoked one or more cigarettes in the previous 30 days reported that they were thinking about quitting.

The recent good-quality study by Pbert and colleagues found statistically significant effects of the intervention among boys in the short term (3 months), but failed to find statistically significant effects at 12 months among both boys and girls.80 At the 12-month followup, both conditions produced fairly equal 30-day abstinence rates in both boys and girls (13.9% and 16.6%, respectively, in the intervention group; 13.2% and 15.5%, respectively, in the control group). It is plausible that the attention-control condition that also included ongoing support from the school nurse was too intensive to show a difference between the two groups. More youth in the attention control group reported using NRT than youth in the intervention group, although NRT use was still generally low (19.0% vs. 13.7% in the control group vs. the intervention group; p=0.04). In addition, the control group received written materials on pharmacotherapy, whereas the intervention group did not. When comparing the three behavioral trials that exclusively focused on cessation, the 2005 study by Colby87 that found statistically significant effects in self-reported behavior included a sample of daily smokers who were generally not motivated to quit, whereas the study by Pbert and colleagues that did not find a statistically significant effect purposefully recruited youth who expressed an interest in quitting within the 2 weeks following baseline assessments. However, youth in this study were considered smokers if they smoked at all during the past 30 days. The other trial by Colby104 included adolescents who reported smoking at least once a week for the past month and were generally motivated to quit.

Additional long-term outcomes were presented at 16 months99 or 24 months91 for two of the behavior-based trials. Outcomes were similar to the first followup time points. In the Hollis study, among all those who had smoked one or more cigarettes in the past 30 days at baseline, the intervention produced statistically significant effects at both 12 and 24 months (RR, 0.89 [95% CI, 0.81 to 0.98]).91 Similar to the combined and prevention-only analyses of the Pbert 2008 study,79 a statistically significant effect of the intervention was found at 6 months among baseline occasional or regular smokers (RR, 0.84 [95% CI, 0.71 to 0.99]); however, this effect was not statistically significant at 12 months.

Common elements of efficacious interventions. We investigated the relationship between various intervention and population characteristics on intervention effects by visual inspection of the forest plots, and none helped explain any pattern of effects.

Differences in patient subgroups. Very little data were found to explore whether some subpopulations benefited more from tobacco cessation messages than others. In the combined trial by Hollis and colleagues, posthoc analyses of baseline smokers found that the intervention compared with the control produced a statistically significant effect of not smoking among nonwhite youth.91 The effect on nonwhite youth was nearly double that seen for white youth, although the CI of the two groups overlapped. As mentioned above, the large study by Pbert and colleagues found significant effects of the intervention on smoking prevalence among boys at 3 months, but not girls.80 In this same study, however, there were no statistically significant effects or differences among boys or girls at 12 months.

Summary of findings: medication-based trials. Neither of the two trials examining the effect of bupropion compared with a placebo showed a benefit of bupropion. In the trial by Killen, 12.5 percent of youth (n=8) in the intervention group and 10 percent (n=7) of the youth in the control group reported 7-day abstinence at 6 months.94 Similarly, in the trial by Muramoto, 6.3 percent of adolescents in the intervention group receiving 150 mg/d bupropion (n=4) and 10.3 percent of adolescents in the control group (n=6) reported 7-day abstinence at 6 months (Table 9).96 Among those assigned 300 mg/d of bupropion, 16.9 percent reported 7-day abstinence. Results were similar when examining rates of abstinence via biological confirmation through expired CO. There were no statistically significant differences in either self-reported or biologically-confirmed 30-day prevalence abstinence rates and no outcomes were presented for the medication trials beyond 6 months.

## Key Question 3 What Adverse Effects Are Associated With Interventions to Improve Tobacco Cessation Rates or Prevent Tobacco Use in Children and Adolescents?

None of the trials of behavior-based interventions explicitly reported on harms of treatment. Some trials reported higher absolute prevalence of smoking in the intervention than the control groups after completing the interventions, but none were statistically significant.11,90,93,95,97 In most of these cases, the risk of smoking was increased by less than 10 percent, but in one case, the risk of being a smoker was almost doubled in the intervention group compared with the control group (RR, 1.90 [95% CI, 0.49 to 7.32]).97 This study provided the greatest number of intervention contacts of all included trials (25 contacts over 49 hours). It was a smaller trial (n=175) limited to Miami-area 7th graders with at least one parent born in a Spanish-speaking county in the Americas. It focused primarily on parent-child communication, positive parenting, and family support, with minimal focus on smoking prevention or cessation specifically. Again, however, there was not a statistically significant difference between groups.

Both of the bupropion trials that were included for benefits of treatment (KQ 2) reported on harms,94,96 and one additional trial of bupropion also met inclusion criteria for harms (KQ 3) (Table 10).89 This trial was not included in KQ 2 because it only reported outcomes at 6 weeks, and a minimum of 6 months of followup was required for KQ 2. Altogether, these three trials included 385 youth taking 150 to 300 mg of bupropion daily and 272 youth taking a placebo medication. All trials were conducted in the United States among youth smoking at least 5–10 cigarettes per day. In one trial, all participants used a nicotine patch in addition to taking either bupropion or a placebo.94

Table 10 Bupropion Harms Summary Table

Trial | N Randomized | Participants | Daily Dose, Duration | Adverse Effects Summary
Muramoto 2007^96^ | IG1: 105 IG2: 104 CG: 103 | Ages 14–17 years smoking at least 6 cigarettes per day, recruited through media and from multiple other sources | IG1: 150 mg IG2: 300 mg 6 weeks | Discontinued medication due to adverse effects/concerns: IG: 3.8% (specific complaints were feeling depressed, irritable, or angry; sleep disturbance; headache; urticaria; anxiety; heart palpitations; suicide attempt; anticholinergic crisis related to recreational drug use; and pregnancy) CG: NR No group differences in throat symptoms, sleep disturbance, nausea (only reported adverse events that were reported by at least 4% of participants). Greater proportion of CG reported headache, cough than IG.
Killen 2004^94^ | IG: 103 CG: 108 | Ages 18 years and younger smoking at least 10 cigarettes per day with ≥1 previous quit attempts, recruited from high schools | 150 mg 9 weeks (plus both groups used nicotine patch) | Proportion discontinuing bupropion or placebo due to adverse effect NR. Adverse events warranting followup with study staff: IG: 22 CG: 25 0 events judged severe No group differences in blood pressure, heart rate, 10 other specific adverse effects or “other” adverse effects.
Gray 2011^89^ | IG: 73 CG: 61 | Ages 12–21 years smoking at least 5 cigarettes per day and interested in quitting, recruited through media and schools/universities | 300 mg 6 weeks | Discontinued medication due to adverse effects: IG: 4.1% CG: 4.9% Any adverse effect: IG: 64% CG: 48% (p=0.05) Reports of dream disturbance only in IG (n=9); other adverse events most commonly reported were headache, insomnia, and irritability; unclear if greater frequency in IG than CG

Abbreviations: CG = control (placebo) group; IG = intervention group; N = number; NR = not reported.

In one trial, a greater proportion of bupropion users (64%) reported an adverse effect than those taking the placebo (48%).89 The other two studies, however, reported no increased risk of a number of specific adverse effects with bupropion use, such as high blood pressure, increased heart rate, nausea, throat symptoms, sleep disturbance, headache, and cough.94,96 Two trials reported that approximately 4 percent of participants discontinued bupropion due to adverse effects or tolerability concerns.89,96 In one of these two trials, the control group reported a similar level of withdrawal due to adverse effects (4.1% among those taking bupropion, 4.9% among those taking placebo),89 but withdrawals due to adverse effects were not reported for the control group in the other trial.96