# INTRODUCTION

## Scope and Purpose

In 2003, the U.S. Preventive Services Task Force (USPSTF) issued a recommendation on screening and counseling to prevent initiation and promote cessation of tobacco use in children and adolescents.1 This recommendation was based on evidence synthesized for the 2000 Public Health Service (PHS) “Clinical Practice Guideline on Treating Tobacco Use and Dependence.”2 The PHS report focused specifically on tobacco-use treatment, including a review of the effectiveness of tobacco-use interventions for adolescent smokers. In contrast, the current systematic review examines the benefits and harms of strategies designed to reduce the prevalence of tobacco use through primary care relevant prevention and cessation interventions in children and adolescents. The USPSTF will use this review to update its 2003 recommendation.

Most tobacco users in the United States are cigarette smokers. As a result, the majority of research in this field has focused on the assessment, prevention, and treatment of cigarette smoking. In this report, every effort has been made to describe the research according to the specific form of tobacco (e.g., cigarette smoking or all tobacco use) that was examined. In particular, the term “smoker” is used instead of “tobacco user” to indicate if the evidence comes from studies of cigarette smokers. We included trials conducted in, referred from, or potentially feasible for (or referable from) health care settings. We describe these collectively as “primary care relevant.” In addition, in this report, “prevention” refers to preventing the initiation of tobacco use or maintaining abstinence among nonusers, whereas “cessation” refers to supporting a smoker or tobacco user in stopping use/quitting.

## Burden of Tobacco Use

Tobacco use is the leading cause of preventable death in the United States. An estimated 443,000 deaths occur annually that are attributable to smoking, including nearly 161,000 deaths from cancer, 128,000 by cardiovascular diseases, and 103,000 by respiratory diseases (excluding deaths from secondhand smoking and residential fires).3 Tobacco use leads to more deaths than HIV, illegal drug use, alcohol use, motor vehicle injuries, suicides, and murders combined.4 Tobacco's toll is not only physical, but also economic, as smoking costs the United States approximately $96 billion each year in direct medical costs and $97 billion from productivity losses due to premature death.3 While cigarette smoking is the predominant form of tobacco use in the United States, other tobacco products include cigars, pipes, and smokeless tobacco products (e.g., chewing tobacco, dipping tobacco, and snuff). Newer tobacco products include bidis, kreteks, smoking tobacco through the use of a hookah (i.e., waterpipe), snus, dissolvables, electronic nicotine delivery systems, and little cigars/cigarillos.

## Prevalence and Natural History of Tobacco Use

Despite the fact that the legal age for purchasing tobacco products is 18 years,5 nearly 90 percent of adults who have ever smoked daily smoked their first cigarette by the age of 18 (99% initiated tobacco use by the age of 26).6 Each day in the United States, over 3,800 children and adolescents between the ages of 12 and 17 years smoke their first cigarette, and an estimated 1,000 persons younger than age 18 years begin smoking on a daily basis.6 While the most serious health outcomes associated with adolescent tobacco use typically appear during adulthood, there are immediate adverse health effects among child and adolescent smokers, including increased negative respiratory effects such as impaired lung growth, early onset of lung function decline, respiratory and asthma-related symptoms (e.g., coughing and wheezing), and early abdominal aortic atherosclerosis.7,8

An individual's path to daily smoking and nicotine dependence has been described in five stages: 1) not susceptible to smoking; 2) susceptible or preparing to smoke; 3) initiation or experimentation (trying the first cigarette); 4) nondaily or irregular smoking; and 5) established or regular smoking (e.g., smoking every day or almost every day).9,10 Although children as young as age 10 years may be susceptible to smoking, it can take up to 2 years to progress from early experimentation to addiction.11,12 While this is the path for most adolescent smokers, some children and adolescents progress rapidly to nicotine dependence, underscoring the need to prevent initial smoking uptake.13

Findings from the Centers for Disease Control and Prevention's (CDC's) National Youth Tobacco Survey (NYTS), a school-based survey of middle school (grades 6–8) and high school (grades 9–12) students, indicated that prevalence of current tobacco and cigarette use and experimentation declined between 2000 and 2009; however, no declines were seen for the period of 2006 to 2009. In 2009, 8.2 percent of middle school students and 23.9 percent of high school students reported current use of any tobacco product; 5.2 percent of middle school students and 17.2 percent of high school students reported current use of cigarettes.14 The prevalence of current use of all tobacco products by school level (i.e., middle school vs. high school) is presented in Table 1.

Table 1 Percentage of Middle and High School Students Who Currently Use^*^ Tobacco, by Product and School Level—National Youth Tobacco Survey, United States, 2009

School level | Any tobacco^†^ % (95% CI) | Cigarettes % (95% CI) | Cigars % (95% CI) | Smokeless tobacco % (95% CI) | Pipes % (95% CI) | Bidis % (95% CI) | Kreteks % (95% CI)
Middle school | 8.2 (7.2 to 9.2) | 5.2 (4.3 to 6.1) | 3.9 (3.4 to 4.4) | 2.6 (2.0 to 3.2) | 2.3 (1.8 to 2.8) | 1.6 (1.2 to 2.0) | 1.2 (0.9 to 1.5)
High school | 23.9 (21.1 to 26.7) | 17.2 (15.0 to 19.4) | 3.7 (3.2 to 4.2) | 10.9 (8.9 to 12.9) | 2.9 (2.5 to 3.3) | 2.4 (1.9 to 2.9) | 2.4 (2.0 to 2.8)

* Current use of cigarettes was determined by asking, “During the past 30 days, on how many days did you smoke cigarettes?”; current use of cigars was determined by asking, “During the past 30 days, on how many days did you smoke cigars, cigarillos, or little cigars?; current use of smokeless tobacco was determined by asking, “During the past 30 days, on how many days did you use chewing tobacco, snuff, or dip?”; current use of pipe was determined by asking, “During the past 30 days, on how many days did you smoke tobacco in a pipe?”; current use of bidis was determined by asking, “During the past 30 days, on how many days did you smoke bidis?”; current use of kreteks was determined by asking, “During the past 30 days, on how many days did you smoke kreteks?” Current use = use on ≥1 day.

† Any tobacco use = use of cigarettes, cigars, smokeless tobacco, tobacco pipes, bidis, or kreteks on at least 1 day in the past 30 days.

Additionally, 15.0 percent of middle school and 30.1 percent of high school students reported experimentation with cigarette smoking as defined by having ever smoked any cigarettes, even one or two puffs, but fewer than 100 cigarettes. Susceptibility to initiate cigarette smoking was 21.2 percent in middle school students and 24.0 percent in high school students. Those who were susceptible to initiate cigarette smoking were defined as never smokers (never tried smoking cigarettes, even one or two puffs) who reported being open to trying cigarette smoking.14

These findings are consistent with those of the national Youth Risk Behavior Survey (YRBS) for recent years.15 Results from the 2009 YRBS found that 19.5 percent of high school students were current cigarette users, a figure well above the Healthy People 2020 objective of 16 percent or less.16 In 2009, 26.0 percent of high school students nationwide reported current cigarette use, current smokeless tobacco use, or current cigar use. Additionally, 7.8 percent of those who reported currently smoking had smoked more than 10 cigarettes per day on the days they smoked during the 30 days before the survey, and 7.3 percent smoked frequently (on 20 or more days during the 30 days before the survey). Overall, the prevalence of current tobacco use was higher among male (19.8%) than female (19.1%) students. The prevalence was also higher among white male (35.1%) and Hispanic male (23.6%) than white female (24.9%) and Hispanic female (18.1%) students, respectively. Among the 19.5 percent of students who currently smoked cigarettes, 50.8 percent had tried to quit smoking during the 12 months before the survey. The prevalence of trying to quit was higher among female (54.2%) than male (48.0%) students.15

More recently, the Monitoring the Future (MTF) Survey showed decreases in cigarette smoking from 2010 to 2011 for adolescents in grades 8, 10, and 12 (all the grades under study). The proportion reporting smoking at least 1 day in the prior 30 days fell significantly for all adolescents, from 12.8 percent in 2010 to 11.7 percent in 2011. Individually, over 6 percent of 8th grade students and nearly 12 and 19 percent of 10th and 12th grade students, respectively, reported currently smoking in 2011.^17^

## Measurement of Tobacco Use in Children and Adolescents

The literature typically defines current tobacco use in children and adolescents as any tobacco use during the previous 30 days. There are several other commonly used measures, however, including tobacco use during the previous 7 days or tobacco use at any point during the person's lifetime (“ever” use).18,19 Three large epidemiological surveys, MTF, YRBS, and NYTS, all defined adolescent lifetime smoking (i.e., ever smoked) as having had even one or two puffs. These studies defined current smoking as having smoked on 1 or 2 days during the previous 30-day period. MTF defined “daily smoking” as an average of one or more cigarettes per day during the previous 30-day period, while YRBS and NYTS measured “frequent smoking,” defined as 20 or more cigarettes in the past 30 days.18 Experimentation is often inferred from responses to questions about ever smoking or age of first use. In addition, there is no standard definition for describing smoking cessation among children and adolescents.20 The two most common measures of cessation are “point prevalence” abstinence (i.e., not smoking at the point of followup; typically measured as no smoking for the past 7 or 30 days) and “continuous abstinence” (i.e., no smoking through the followup period).21 Table 2 summarizes common measures of tobacco use, including how each measure is defined and operationalized.

Table 2 Common Tobacco Use Measures

Tobacco use term | Common measures and definitions
Susceptible | Defined as the absence of a firm resolve to not smoke in the future. Operationally determined with three questions: 1) Do you think you will try a cigarette soon [yes/no]? 2) If one of your best friends were to offer you a cigarette, would you smoke it [definitely yes/probably yes/probably not/definitely not]? 3) Do you think you will be smoking 1 year from now [definitely yes/probably yes/probably not/definitely not]? Youths are susceptible if they answer “yes” to the first question or if they fail to answer “definitely not” to the second or third question, or if they had smoked a cigarette in the past 30 days
Experimentation | Often measured as ever smoking, even one or two puffs, or inferred from age at first smoking or youth's self-description of being an experimenter
Lifetime (“ever”) use | Ever smoked, even one or two puffs
Former use | Ever smoked, but not in the past 30 days (some studies also use ever smoked, but not in the past year)
Current use | Any tobacco/cigarette use (even a puff) during the previous 30 days or 1 or more days in the past 30 days; this is also referred to as “monthly smoking” in some studies. Some studies consider current use to be in the past 7 or 90 days.
Daily smoking | Average of one or more cigarettes per day during the previous 30-day period
Frequent smoking | 20 or more cigarettes in the past 30 days
Point prevalence abstinence | Not smoking at the point of followup; often measured as the past 7 or 30 days
Continuous abstinence | No smoking through the followup period, also referred to as “sustained” abstinence

While self-reported smoking status is the most commonly used measure, it may not accurately measure actual tobacco use due to faulty recall and over- or underreporting bias.20 This may be particularly true for children and adolescents who only smoke sporadically and may underreport their tobacco use or fail to identify themselves as a smoker.22,23 Additionally, studies examining the validity of self-reported risk behaviors have found that the prevalence of tobacco use is higher when surveys are administered in school settings compared with household settings, which may reflect the fact that adolescents appear to underreport smoking behavior when they feel their confidentiality may be at risk.22 The magnitude and extent of underreporting is unclear. Studies examining the validity of self-reported tobacco use compared with a bogus pipeline approach (e.g., threat of biological validation) have yielded mixed results.24,25

Biochemical measures, including measures of thiocyanate (SCN) in saliva or blood samples; cotinine in blood, urine, or saliva samples; or monitoring of carbon monoxide (CO) levels in expired air are frequently used to substantiate self-reports. These measures, however, can also be unreliable in adolescents who may only smoke sporadically.24 All of the biochemical measures have a relatively short half-life (e.g., cotinine has a half-life of 19 hours, CO has a half-life of 2– 5 hours, and SCN has a half-life of 14 days),23 and many cannot detect light smoking due to additional environmental sources (in the case of CO) or possible dietary sources (in the case of SCN). Additionally, studies have found that the correlation between smoking status and biochemical markers is lower for younger teens, as they may not fully inhale and metabolize tobacco smoke.23 The Society for Research on Nicotine and Tobacco (SRNT) subcommittee on biochemical verification in clinical trials considers that verification is not necessary when a trial includes a large population with limited face-to-face contact, and where the optimal data collection methods are through the mail, telephone, or Internet.26 However, the SRNT subcommittee recommends that biochemical verification be used in most studies of smoking cessation in special populations, including adolescents.26

## Risk Factors

Many variables influence the likelihood of smoking initiation and continuation in children and adolescents. The risk of smoking initiation involves a complex mix of personal, social, and environmental factors. Parental smoking (including parental nicotine dependence) is among the strongest factors associated with increased risk of smoking initiation.27-29 One study found that a child's odds of daily smoking were reduced by 71 percent when both parents never smoked versus when both parents were current smokers.30 In addition, low parental monitoring, easy access to cigarettes, and absence of restrictions on smoking in the home are related to smoking initiation.28,29 Children and adolescents are more likely to start smoking if they perceive a high prevalence of smoking among their peers,31,32 in part, to gain social status or acceptability.33 Findings from the Development and Assessment of Nicotine Dependence in Youth study indicated that the perceived ease by which children and adolescents could obtain tobacco products was associated with a higher level of smoking initiation and regular smoking.34 In addition, exposure to tobacco promotions increases the risk for initiation or progression toward regular tobacco use.35

Evidence also suggests that multiple factors influence a child or adolescent's decision to continue smoking and the probability they will become nicotine dependent. Among smokers, pleasant initial sensitivity to tobacco use, parental nicotine dependence, adolescent nicotine dependence, and extensiveness of smoking at the initial interview were the strongest predictors of adolescent nicotine dependence 2 years later.36

## Rationale for Tobacco Use Interventions in Primary Care

Given the fact that primary care clinicians have regular and ongoing contact with children and adolescents and their families, they have a unique opportunity to address smoking prevention and cessation efforts. Research establishing the effectiveness of prevention and cessation interventions in children and adolescents are needed to reduce the burden of tobacco use in adulthood and to minimize the immediate adverse health effects experienced by children and adolescents. If effective, these interventions could help reduce the physical and economic burden of tobacco use. It has been estimated that a 26 percent decrease in adolescent smoking prevalence from community and policy interventions would result in an annual savings of more than 100,000 lives and 1.6 million years of potential life lost in the United States.37

## Prevention and Cessation Interventions

Tobacco prevention and cessation interventions can rely on one of several theoretic approaches and frameworks, including targeting intrapersonal factors through strategies such as motivational interviewing, tailoring messages and activities using the transtheoretical model (i.e., stages of change), or life skills enhancement; social/normative factors that target the social situation, context, or norms through approaches such as improving parent/child communication or designing interventions based on social learning theory; and through targeting environmental factors that address cultural and environmental influences such as broad-based policy changes.8, 38-42 For example, increasing the enforcement of existing regulations that restrict sales to minors can decrease access to tobacco products, which may impact uptake and continued use.8,40,42 Likewise, because youths living in households with parents who have never smoked or have quit smoking have a significantly lower risk of initiating smoking, researchers have theorized that targeting parental behavior and parent-child communications and interactions can reduce tobacco use in children and adolescents.43

The recently released “Surgeon General's Report on Preventing Tobacco Use Among Youth and Young Adults” concluded that there is a “large, robust, and consistent” evidence base that documents known effective strategies for reducing tobacco use among youth and young adults. The evidence was organized into three sections: 1) large community environments (i.e., mass media campaigns, community interventions, and comprehensive state-level tobacco control programs); 2) legislative and regulatory approaches (i.e., taxation, policies on clean indoor air, regulations on youth access, bans on advertising, and product labeling); and 3) small social environments (i.e., the family, clinical settings, schools, and youth empowerment and activism programs). The report also included a section on youth cessation interventions. One of the major conclusions of the report states, “Coordinated, multicomponent interventions that combine mass media campaigns, price increases including those that result from tax increases, school-based policies and programs, and statewide or community-wide changes in smokefree policies and norms are effective in reducing the initiation, prevalence, and intensity of smoking among youth and young adults.”8 Earlier recommendations from the CDC44 and the Community Preventive Services Task Force45 similarly recommend comprehensive state- and communitywide tobacco control programs and policies that incorporate a mix of educational, clinical, regulatory, economic, and social strategies. While the Surgeon General's report states there is no clear evidence to suggest that prevention strategies delivered in health care settings are effective in reducing adolescent smoking initiation, these results should be interpreted with caution, given the limited data and the lack of replication of specific approaches.8

Several systematic and narrative reviews have also been conducted that examine the effects of tobacco cessation interventions in encouraging adolescent smokers to quit smoking.39,46-62 The most recent review by Sussman and Sun, whose findings were generally consistent with previous cessation reviews, included 64 controlled trials that targeted cessation among adolescent smokers ages 12–19 years.61 The majority (n=40) were based in schools. Effects were estimated according to four main predictors: 1) focus (i.e., social influences, cognitive-behavioral, motivational, medical [e.g., managing the effects of withdrawal or recovery], and other); 2) modality (i.e., classroom, school clinics, medical clinics, family, systemwide, computer, sensory deprivation, court diversion, and other public settings); 3) number of sessions (i.e., one to four, five to eight, nine or more); and 4) length of followup (i.e., 0 to 3 months, 4 to 12 months, and more than 12 months). Overall, meta-analysis found a 4 percent difference in quitting among the intervention groups compared with the control groups (11.8% vs. 7.5%), although most studies were statistically underpowered to detect differences with reasonable certainty and most studies failed to use appropriate analyses (e.g., accounting for nesting in cluster randomized trials). The authors concluded that programs based on social influences, cognitive-behavioral theory, or enhancing motivation were the most effective and that cessation interventions might be best delivered in a school-based context. Interventions set in medical clinics were also found to have statistically significant effects, although it was not clear if it was the setting itself or the underlying theory used in the interventions (i.e., eight of the nine interventions that took place in a medical setting were motivation-enhancement based).

A Cochrane Collaboration review by Grimshaw and Staton included 24 good-quality trials that examined the effects of tobacco cessation interventions for young people age 19 years and younger.39 They concluded that complex approaches, particularly those that incorporated components based on the stages of change model, motivational enhancement, and/or cognitive behavioral therapy, showed promise in promoting abstinence. However, they acknowledged that there is a need for more well-designed, adequately powered trials of cessation interventions for this age group. The use of pharmacologic adjuncts as an aid in cessation for adolescent smokers is also of interest, given the positive effects of these therapies seen among adults.63 However, currently, there are no medications approved for tobacco cessation in adolescents and children. The Food and Drug Administration (FDA) instructs adolescents to see their doctors if they are interested in nicotine replacement therapy (NRT). Because the safety and effectiveness of these drugs in pediatric patients have not been established, bupropion hydrochloride (known as Zyban^®^), an aminoketone antidepressant, and varenicline tartrate (known as Chantix^®^) are not recommended for smoking cessation for people younger than age 18 years. In July 2009, the FDA required both bupropion and varenicline tartrate to carry boxed warnings on their labels for health care professionals citing serious risks for users taking these drugs.64 These risks include changes in behavior, depressed mood, hostility, and suicidal thoughts or actions.

## Current Clinical Practice

Few adolescents report having discussed tobacco use with a health care provider. Recent studies indicate that less than half of adolescents who visited a physician or a dentist in the past year reported receiving preventive counseling regarding tobacco use.65 According to the 2000 NYTS, 33 percent of children and adolescents in grades 6–12 who visited a physician in the past year reported that they were counseled about the dangers of tobacco use; 20 percent reported that a dentist provided such counseling. Among children and adolescents who smoked in the past year, 16.4 and 11.6 percent reported receiving advice to quit from a physician or dentist, respectively. Those defined as current smokers (i.e., reported smoking in the past 30 days) were significantly more likely to have received advice to quit when visiting a physician or dentist than individuals who had smoked in the past year but not in the past 30 days. This advice to quit was positively related to one or more quit attempts during that period.65 More recent data from the 2009 NYTS found that only 21 percent of adolescents recalled that a doctor, dentist, or nurse asked them whether they smoked in the past 12 months, and of those who did smoke, only 7 percent reported that their provider told them to stop smoking.66

Another recent study of 16- to 19-year-olds found that 43.4 percent of adolescents surveyed reported ever being asked by their physician whether they smoked and 42.1 percent reported ever being counseled by their physician not to smoke; 28.8 percent reported receiving both screening and counseling. Among those adolescents who reported current smoking, 79.3 percent reported that they would admit that they smoked if their physician asked.67

A recent survey of pediatricians found that less than half (44%) of practicing pediatricians who responded to the survey felt confident in their ability to help adolescents quit smoking.68 Additionally, few of the pediatricians who were surveyed reported referring their adolescent patients to smoking cessation programs (10%) or prescribing NRT (2%). A separate national survey of female pediatricians found similar results—only 41 percent of survey respondents reported providing smoking cessation counseling to their smoking patients at least once a year.69

## Recommendations of Other Groups

In May 2008, the PHS updated its 2000 clinical practice guidelines and presented its recommendations in “Treating Tobacco Use and Dependence: Clinical Practice Guideline, 2008 Update.”63 The PHS guideline panel reviewed the effectiveness of tobacco-use interventions for adolescent smokers. As a result of this review, the panel made the following recommendations (p. 157):

- Recommendation 1: Clinicians should ask pediatric and adolescent patients about tobacco use and provide a strong message regarding the importance of totally abstaining from tobacco use (Strength of Evidence = C).
- Recommendation 2: Counseling has been shown to be effective in treatment of adolescent smokers. Therefore, adolescent smokers should be provided with counseling interventions to aid them in quitting smoking (Strength of Evidence = B).
- Recommendation 3: Secondhand smoke is harmful to children. Cessation counseling delivered in pediatric settings has been shown to be effective in increasing cessation among parents who smoke. Therefore, to protect children from secondhand smoke, clinicians should ask parents about tobacco use and offer them cessation advice and assistance (Strength of Evidence =B).

Due to a lack of evidence on the effectiveness of pharmacologic therapy in adolescents, a previous recommendation was eliminated from the updated 2008 PHS guideline (p. 245):

- PHS 2000, Recommendation: When treating adolescents, clinicians may consider prescriptions for bupropion SR or NRT when there is evidence of nicotine dependence and desire to quit tobacco use (Strength of Evidence = C).

In 2009, the American Academy of Pediatrics (AAP) published a policy statement on tobacco use.70 While the policy statement recommended pharmacotherapy for parents of pediatric patients, it stopped short of recommending nicotine replacement or other medications for children or adolescents. AAP recommended that all pediatricians should counsel patients against initiating tobacco and provide counseling on tobacco cessation. This policy statement also recommended that pediatricians should include initial guidance regarding tobacco use to patients as young as age 5 years. Further, AAP recommended that pediatricians should advise all families to make their homes and cars smoke free.

## Previous USPSTF Recommendation

In 2003, the USPSTF updated its 1996 recommendation and concluded there was insufficient evidence to recommend for or against routine screening for tobacco use or interventions to prevent and treat tobacco use and dependence among children or adolescents (I statement).1