# Trials Pending Assessment

Study Reference | Study Name | Aim | Location | Number of Participants | Intervention Description | Relevant Outcomes | 2012 Status
Cremers HP, Mercken L, Oenema A, de Vries H. A web-based computer-tailored smoking prevention programme for primary school children: intervention design and study protocol. BMC Public Health. 2012;12:277. PMID: 22490110 | Fun Without Smokes | Prevention | The Netherlands | 3,240 (estimated enrollment) | Personalized feedback including information about nonsmoking, positive attitudes toward nonsmoking, negative attitudes toward smoking, and skills and plans to refuse cigarettes. Email and SMS messages will be used as prompts to promote visits to the intervention Web site. | Self-reported smoking status | Protocol
Fellows JL, Hollis JF, Laferriere D, et al. Proactive Recruitment for Teen Tobacco Cessation: The Power of the Teachable Moment. Paper presented at: 16th Annual Meeting of the Society for Research on Nicotine and Tobacco; Baltimore; February 24–27, 2010. | Quithelper | Cessation | United States | 266 | Five proactive telephone counseling calls. Highly-interactive Web site to assess readiness, barriers, confidence, quit plans, triggers, relapse prevention, peer support, and information. Coach-Web interaction enhanced tailoring. | 30-day abstinence | Baseline data; manuscript in preparation
Hiemstra M, Ringlever L, Otten R, et al. Efficacy of smoking prevention program “Smoke-free Kids”: study protocol of a randomized controlled trial. BMC Public Health. 2009;9:477. PMID: 20025727. | Smoke-free Kids | Prevention | The Netherlands | 1,479 | Five printed activity modules at 4-week intervals. Each module aims to modify different socialization variables (general communication about smoking, influence of smoking messages, setting rules about smoking, creating a smokefree house, increased awareness of peer influence). Three emailed newsletters. Booster module on staying smokefree and motivational information throughout high school years. | Initiation of cigarette smoking; asthma symptoms | Protocol
Klein JD. Adolescent smoking cessation in pediatric primary care. 2011. | Smokebusters | Cessation | United States | 8,160 (estimated enrollment) | 5A model: ask if the patient smokes; advise every patient to quit; assess readiness to quit; assist in quitting and finding services; arrange for cessation services and followup. | Self-reported smoking status | Recruiting participants
Pierce JP, James LE, Messer K, et al. Telephone counseling to implement best parenting practices to prevent adolescent problem behaviors. Contemp Clin Trials. 2008;29:324-34. PMID: 17964223. | Parenting to Prevent Problem Behaviors | Prevention | United States | 1,036 | Self-help manual on best parenting practice mailed to participating families with assistance working through the manual provided by phone calls with a lay facilitator. Scheduled quarterly telephone calls during which the facilitator follows a computer-assisted structured counseling script (including motivational interviewing). | Tobacco use | Protocol; baseline data
Schepis TS, Warren KA, Rao U. Evaluation of a cognitive-behavioral smoking cessation treatment for adolescents and young adults (POS2-53). Paper presented at 12th Annual Meeting of Society for Research on Nicotine and Tobacco; Orlando; February 15–18, 2006. | NR | Cessation | NR | NR | Cognitive-behavioral treatment (Modified Brief Office Intervention) and bupropion | Smoking status | 4-week results presented at a meeting